# Key Informants

In preparing this update, the EPC did not consult Key Informants who represent the end-users of research. For Comparative Effectiveness Review No. 20, the earlier report, the EPC sought Key Informant input on the priority areas for research and synthesis. Key Informants were not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions did not necessarily represent the views of individual Key Informants.