# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia Bonnell, R.N., M.L.S., Hussein Noorani, M.S., and Kathleen Ziegler, Pharm.D.