# Discussion

## CER Update Strength of Evidence Relative to CER No. 20 Findings

Table 11 provides a summary of the conclusions we drew for the relevant interventional comparisons for each Key Question in CER No. 20 and in this update. Because 2DRT and SBRT are not commonly addressed in CER No. 20 and the update, they are not included in Table 11. Moderate strength evidence from the update shows a reduction of the incidence of late grade 2 or higher xerostomia with IMRT compared with 3DCRT. This increases the SOE on this toxicity from CER No. 20, raising it to “high” based on a body of evidence including 2 RCTs and observational studies that are in agreement on this outcome. Evidence in the update is insufficient to show a difference between IMRT and 3DCRT in overall survival or locoregional tumor control rates. We found no new evidence to alter any conclusions of CER No. 20 for any other toxicity, oncologic outcomes, or comparisons.

Table 11 Comparison of relevant CER No. 20 and update conclusions

Key Question | Comparison | Clinical Outcome | CER No. 20 Total Evidence Base | CER No. 20 Conclusions | CER No. 20 Update Total Evidence Base | CER No. 20 Update Conclusions | Cumulative Update Conclusions (Action Needed)
Key Question 1: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding adverse events and QOL? | 3DCRT vs. IMRT | Grade ≥ 2 late xerostomia | One good quality RCT and six poor quality non-RCTs | Moderate SOE shows significant reduction in incidence | One fair quality RCT, six poor quality non-RCTs | Moderate SOE shows significant reduction in incidence | Raises final SOE to “high” based on a body of evidence including 2 RCTs (no further study required)
Key Question 1: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding adverse events and QOL? | 3DCRT vs. IMRT | Other RT-associated grade > 2 toxicities (e.g., acute or late dysphagia, salivary gland dysfunction, swallowing function) | Variously, one good quality RCT, 13 poor quality non-RCTs | Insufficient evidence to draw conclusions | Variously, one good quality RCT, nine poor quality non-RCTs | Insufficient evidence to draw conclusions | Insufficient evidence to draw conclusions (further study required)
Key Question 1: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding adverse events and QOL? | 3DCRT vs. IMRT | QOL | Three poor quality non-RCTs | Insufficient evidence to draw conclusions | One fair quality RCT, one poor quality non-RCT | Insufficient evidence to draw conclusions | Insufficient evidence to draw conclusions (further study required)
Key Question 1: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding adverse events and QOL? | 3DCRT or IMRT vs. PBT | Any | No evidence identified | No evidence identified, insufficient | No evidence identified | No evidence identified, insufficient | Insufficient evidence to draw conclusions (further study required)
Key Question 1: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding adverse events and QOL? | 3DCRT or IMRT vs. SBRT | Any | Not applicable (SBRT not included) | Not applicable (SBRT not included) | One poor quality non-RCT | Insufficient evidence to draw conclusions | Insufficient evidence to draw conclusions (further study required)
Key Question 2: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding tumor control and patient survival? | 3DCRT vs. IMRT | Overall survival, local control, locoregional control, disease-free survival | Variously, one good quality RCT, six poor quality non-RCTs | Insufficient evidence to draw conclusions | One fair quality RCT, nine poor quality non-RCTs | Insufficient evidence to draw conclusions | Insufficient evidence to draw conclusions (further study required)
Key Question 2: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding tumor control and patient survival? | 3DCRT or IMRT vs. PBT | Any | No evidence identified | No evidence identified, insufficient | No evidence identified | No evidence identified, insufficient | Insufficient evidence to draw conclusions (further study required)
Key Question 2: What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding tumor control and patient survival? | 3DCRT or IMRT vs. SBRT | Any | Not applicable (SBRT not included) | Not applicable (SBRT not included) | One poor quality non-RCT | Insufficient evidence to draw conclusions | Insufficient evidence to draw conclusions (further study required)
Key Question 3: Are there differences in comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT for specific patient and tumor characteristics? | 3DCRT or IMRT vs. PBT or SBRT | Any | No evidence identified | No evidence identified, insufficient | No evidence identified | No evidence identified, insufficient | Insufficient evidence to draw conclusions (further study required)
Key Question 4: Is there variation in comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT because of differences in user experience, treatment planning, treatment delivery, and target volume delineation? | 3DCRT or IMRT vs. PBT or SBRT | Any | No evidence identified | No evidence identified, insufficient | No evidence identified | No evidence identified, insufficient | Insufficient evidence to draw conclusions (further study required)

Abbreviations: CER = Comparative Effectiveness Review; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; QOL = quality of life; RCT = randomized controlled trial; RT = radiotherapy; SBRT = stereotactic body radiotherapy; SOE = strength of evidence; 3DCRT = three-dimensional conformal radiotherapy.

## Applicability of the Findings

In general, applicability assessment would depend on a body of evidence sufficient to form new conclusions about the comparative outcomes of 3DCRT, IMRT, SBRT, and PBT in treatment of head and neck cancer. However, comparative evidence that meets study selection criteria for this CER update is sparse for 3DCRT, IMRT, and SBRT, and nonexistent for PBT. In the absence of sufficient evidence, additional factors may be considered in making a treatment decision. Those could include relative convenience and cost, issues outside the scope of this CER.

In preparing this update, we reconsidered the RT modalities included in CER No. 20 and whether all remained applicable to current radiation oncology practice. In particular, we examined the role of opposed beam 2DRT in modern radiation oncology practice. Based on the current literature and input from our TEP members, we concluded 2DRT is no longer used in the U.S. for definitive treatment of head and neck cancer, thus we excluded it from the update. We realize in doing so we excluded evidence from a RCT performed in China that showed a statistically significant improvement in overall survival with IMRT compared to 2DRT, which to our knowledge is the only study that has shown a statistically significant survival benefit of one RT modality compared to another.54 However, this did not alter our overall conclusion to exclude 2DRT from the current report.

We also re-examined whether to include brachytherapy in this update; it was not part of CER No. 20. Although brachytherapy can be used in select cases as a means of dose escalation in conjunction with external beam irradiation for head and neck cancer,3,4 this practice has become uncommon because sufficient dose escalation can often be achieved in these cases with a noninvasive approach (e.g., conformal RT). Brachytherapy alone is very rarely employed, except in small (T1) tumors of the nasal vestibule, lip, or oral cavity, which are relatively uncommon (1 percent to perhaps 5 percent of all cases).5–9 Therefore, because use of brachytherapy alone for primary management of head and neck malignancies has limited applicability in modern head and neck radiation oncology practice, we did not seek evidence of it for this CER; we focused instead on RT modalities that are used as the sole RT modality for a given presentation of head and neck cancer.

We considered including dosimetry studies in CER No. 20, and this update. For both reports, our ultimate conclusion not to include dosimetry studies was agreed upon among our EPC team, among AHRQ personnel, and in discussion with our TEP. The primary rationale for this conclusion is that dosimetry studies do not provide a link to actual clinical outcomes that are realized by patients. Dosimetry modeling is clearly needed to advance research in RT methods, but it does not provide evidence for clinical efficacy.

### Key Questions 1 and 2

The degree to which the evidence presented in this update is applicable to clinical practice is a function of the similarity between populations in the included studies and the patient population that receives clinical care in diverse settings. It also is related to the relative availability of the modalities. Because of the overall weakness of evidence for Key Questions 1 and 2, we have primarily limited comments to the relevance of the PICOTS elements, a practical and useful structure to review the applicability in a systematic manner (Table 12).

Table 12 Summary of applicability of evidence for Key Questions 1 and 2

PICOTS Domain | Applicability of Evidence
Populations | - Overall patients included in the evidence base of this CER update are typical of the head and neck cancer population treated with RT based on age, sex, and tumor characteristics.
Interventions | - 3DCRT, IMRT, and SBRT represent different technological approaches to the delivery of conformal photon RT. The major advantage of these interventions compared with traditional wide-field 2DRT is the ability to deliver tightly focused ionizing radiation by delineating the shape and size of the tumor using a CT-based or other imaging planning system.; - 3DCRT represents a minimum technical standard for delivery of forward-planned conformal RT. It involves static fields with a fixed shape, modified by compensators (wedges and segments). 3DCRT is widely available.; - IMRT offers beam strength attenuation through a multileaf collimator (tungsten), with dynamic field shapes for each beam angle. IMRT is as widely available as 3DCRT, but requires labor-intensive inverse planning and a higher level of quality assurance.; - SBRT is a hypofractionated technique to administer RT in far fewer fractions than 3DCRT and IMRT.; - SBRT is not as widely available as 3DCRT or IMRT, but its use is growing in other diseases such as non-small-cell lung cancer.; - The institutional programmatic requirements for SBRT differ from those of IMRT.; - Comparative evidence for PBT is unavailable.
Comparators | - See above for Interventions.
Outcomes | - The major beneficial health outcomes in this CER are overall survival and late xerostomia.; - Overall survival is the primary outcome of interest for any cancer intervention study.; - Local control is of interest to patients because it measures the effectiveness of an intervention in disease control. On local failure, patients enter into a new category centered on systemic chemotherapy.
Timing | - The relevant periods occur from the time of treatment through followup over months (palliation) or years (overall survival).
Setting | - The evidence for Key Questions 1 and 2 is mostly international, primarily obtained in tertiary institutions. More sophisticated interventions such as IMRT and SBRT require an institutional commitment to quality assurance and ongoing training that may be difficult to achieve in smaller community-based centers.; - We did not collect or analyze information to examine these issues.

Abbreviations: CER = Comparative Effectiveness Review; CT = computed tomography; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; RCT = randomized controlled trial; RT = radiotherapy; SBRT = stereotactic body radiotherapy; 3DCRT = three-dimensional conformal radiotherapy.

### Key Questions 3 and 4

The current evidence base for Key Questions 3 and 4 is nonexistent based on our literature review. Therefore we cannot assess the applicability to clinical practice.

## Findings in Relationship to What Is Already Known

Our updated systematic literature search and review revealed no relevant evidence-based guidelines we could compare with our findings for any of the Key Questions.

## Limitations of Current Review and Evidence Base

The primary limitation for all Key Questions here is lack of well-designed and conducted comparative trials. Although the body of evidence we identified was more substantial for 3DCRT and IMRT than SBRT, and nonexistent for PBT, we have significant concerns about interstudy heterogeneity, with variability in RT dose, schedule of treatment, concurrent treatments, patient selection criteria, tumor size and location, and so forth.

We acknowledge that our inclusion of comparative studies alone may have limited collection of RT-associated adverse events that may be revealed in larger observational studies. However, we believe our decision to focus on key comparative outcomes xerostomia, dysphagia, and salivary gland toxicity was merited based on our understanding of the literature and the importance of those toxicities to cancer patients.

As stated previously in this report, we are not sure whether the inconsistency we observed in comparative RT-associated adverse events reflects a lack of systematic collection of this type of information by investigators, or failure to consistently report it in publications. In a systematic review in general, a heterogeneous evidence base makes it very difficult to assess the relative benefits and harms of any modality, particularly evidence drawn from nonrandomized trials, and to assess the SOE of a body of evidence. In this CER update, the sparse new evidence we identified limited additional comparative assessment among the modalities. We therefore believe further careful study of the RT methods compared in this CER is needed, particularly in the regimens of Key Question 1 or 2 to establish optimal technical protocols and patient selection criteria, perhaps standardizing and comparing them across institutions. These data and methods could, in theory, be applied to the design and conduct of comparative studies, as outlined in the Research Gaps section below.

We are aware that a body of dosimetry evidence is available to suggest potential differences in the benefits and harms of different conformal RT types. Our exclusion of such evidence may be viewed by some readers as a limitation of this CER update. However, we maintain that because dosimetry modeling studies do not provide a clear link to clinical outcomes, they do not add critical information to assess the comparative effectiveness of RT in the treatment of head and neck cancer.

## Research Gaps

The primary research gap we identified is a continuing lack of evidence from well-executed comparative studies (randomized or otherwise) to draw conclusions on the relative clinical benefits and harms of the RT methods used in patients with head and neck cancer. We also identified some feasibility issues associated with the RT methods that are potential impediments to the type of rigorous comparative studies we suggest are necessary to determine their comparative effectiveness. In this section, we first describe characteristics of ideal comparative studies we believe are needed to compare these technologies. Some potential impediments to such studies are discussed subsequently in this section.

### Lack of Clinical Trial Evidence on RT Interventions for Head and Neck Cancer

We suggest that further prospective studies are needed to properly evaluate the relative clinical benefits and harms of the technologies assessed in this CER, taking into account the potential impediments we discuss below. Ideally, comparative studies would incorporate the following:

- To assure comparability of patients and to minimize bias, standardized patient selection criteria would be used that involve consultation, including a head and neck surgeon, medical oncologist, and radiation oncology specialist. Key factors to consider include comorbidity status, age, performance status, tumor size, and tumor location.
- Standardized intervention protocols with training and quality assurance programs within and across participating institutions are necessary for the best study. For RT, key factors would include the imaging and planning method, immobilization method, dose, and fractionation schedule for comparisons of different modalities (e.g., 3DCRT, IMRT, SBRT, PBT).
- Prespecified followup criteria and methods—in particular, notation of systemic therapy—are key considerations in study design. Systemic therapy is a key concern because it is difficult to discern the effects of an intervention with systemic therapy from that achieved with the intervention alone. Is the effectiveness a function of the systemic therapy, the intervention, or the combination?
- Rigorous and standardized reporting is needed to account for all patients and treatments received. We urge that rigorous methods be used to conduct RCTs, particularly intention-to-treat analysis and adjustment of survival data to account for all patients based on their treatment plans.
- Primary outcomes would include overall survival, cancer-specific survival, and local control. Prespecified systematic collection of adverse events using validated criteria (e.g., Common Terminology Criteria for Adverse Events) is necessary to permit accurate assessment of relative benefits and risks of the interventions.
- As alluded to in the Introduction of this update, the potential impact of tumor tissue HPV positivity on oncologic outcomes and management of such patients has been increasing in importance. Studies are needed to identify reduced intensity therapies that still yield satisfactory oncologic outcomes in HPV-positive cases. This will require investigators to stratify patients by HPV status and analyze data accordingly.

### Potential Impediments to Comparative Studies of RT Interventions for Head and Neck Cancer

The general dissemination of conformal RT technologies into community clinical practice is a potential impediment to comparative study of those technologies. We acknowledge that randomized studies of 3DCRT versus IMRT or PBT may be very difficult to recruit and conduct, based on technical and potential ethical issues related to perceptions of unequal clinical benefit among the interventions. We also recognize that the cost of conducting rigorous RCTs may pose a significant impediment given the resource limitations that exist in the United States. This CER supports a conclusion that RT-associated adverse events—in particular late xerostomia—are lessened with IMRT compared with 3DCRT. However, we maintain that current evidence is insufficient to support a view that clinical oncologic outcomes achieved with any of the technologies are relatively superior or inferior. Clinical evidence from comparative studies is needed to establish the standard of care for head and neck cancer patients.

## Summary and Conclusions

Key Questions in CER No. 20 asked whether any of the RT modalities under consideration (2DRT, 3DCRT, IMRT, PBT) is more effective than the others:

- in reducing normal tissue toxicity and adverse events, and improving QOL
- in improving local tumor control, time to disease progression, and survival
- when used in certain anatomic locations or patient subpopulations
- whether there is more variation in patient outcomes with any modality secondary to user experience, treatment planning, or target volumes

The main finding of CER No. 20 was that late grade 2 or higher xerostomia was reduced and QOL domains related to xerostomia were improved in patients treated with IMRT compared with those who received either 3DCRT or 2DRT. Evidence was insufficient to draw relative conclusions on survival or tumor control; adverse events other than late xerostomia (e.g., mucositis, dysphagia, skin toxicities, osteoradionecrosis of the jaw); whether patient and tumor characteristics affected relative outcomes; or whether physician experience and treatment characteristics affected relative clinical outcomes such as survival or treatment-associated adverse events.

Moderate strength evidence from the update shows a reduction of the incidence of late grade 2 or higher xerostomia with IMRT compared with 3DCRT, which strengthens the conclusion on this toxicity from CER No. 20. Evidence in the update is insufficient to show a difference between IMRT and 3DCRT in overall survival or locoregional tumor control rates. We found no new evidence to alter any conclusions of CER No. 20 for any other toxicity, oncologic outcomes, or comparisons.