# Summary of Reasons for Study Exclusion at the Level of Full-Text Review

Citation | Reason for exclusion
A. Al-Mamgani, P. Van Rooij, L. Tans, D. N. Teguh and P. C. Levendag. Toxicity and outcome of intensity-modulated radiotherapy versus 3-dimensional conformal radiotherapy for oropharyngeal cancer: a matched-pair analysis. Technol Cancer Res Treat. 2013. 12:123–30 | Nonrelevant Study Design
A. Al-Mamgani, P. Van Rooij, R. Mehilal, L. Tans and P. C. Levendag. Combined-modality treatment improved outcome in sinonasal undifferentiated carcinoma: Single-institutional experience of 21 patients and review of the literature. European Archives of Oto-Rhino-Laryngology. 2013. 270:293–299 | Nonrelevant Study Design
A. B. Miah, S. L. Gulliford, C. H. Clark, S. A. Bhide, S. H. Zaidi, K. L. Newbold, K. J. Harrington and C. M. Nutting. Does-response of parotid gland function Dose-response analysis of parotid gland function: What is the best measure of xerostomia?. Radiotherapy and Oncology. 2013. 106:341–345 | Nonrelevant Study Design
A. Birnbaum, T. Dipetrillo, R. Rathore, E. Anderson, H. Wanebo, Y. Puthwala, D. Joyce, H. Safran, D. Henderson, T. Kennedy, N. Ready and T. T. W. Sio. Cetuximab, paclitaxel, carboplatin, and radiation for head and neck cancer: A toxicity analysis. American Journal of Clinical Oncology: Cancer Clinical Trials. 2010. 33:144–147 | Nonrelevant Study Design
A. C. Houweling, M. E. P. Philippens, T. Dijkema, J. M. Roesink, C. H. J. Terhaard, C. Schilstra, R. K. Ten Haken, A. Eisbruch and C. P. J. Raaijmakers. A Comparison of Dose-Response Models for the Parotid Gland in a Large Group of Head-and-Neck Cancer Patients. International Journal of Radiation Oncology Biology Physics. 2010. 76:1259–1265 | Nonrelevant Study Design
A. C. Tiong, S. Huang, B. O’Sullivan, W. Xu, J. Kim, L. A. Dawson, J. Cho, R. Gilbert, S. Breen and J. N. Waldron. Outcomes For T2N0M0 glottic squamous cell carcinoma treated with IMRT compared with conventional parallel opposed fields. International Journal of Radiation Oncology Biology Physics. 2011. 81:S106–S107 | Abstract Only
A. D. Jensen, J. Krauss, W. Weichert, Z. P. Bergmann, K. Freier, J. Debus and M. W. Munter. Disease control and functional outcome in three modern combined organ preserving regimens for locally advanced squamous cell carcinoma of the head and neck (SCCHN). Radiation Oncology. 2011. 6:#pages# | Nonrelevant Study Design
A. Eisbruch, H. M. Kim, F. Y. Feng, T. H. Lyden, M. J. Haxer, M. Feng, F. P. Worden, C. R. Bradford, M. E. Prince, J. S. Moyer, G. T. Wolf, D. B. Chepeha and R. K. Ten Haken. Chemo-IMRT of oropharyngeal cancer aiming to reduce dysphagia: Swallowing organs later complication probabilities and dosimetric correlates. Dysphagia. 2012. 27:439 | Abstract Only
A. Eisbruch, H. M. Kim, J. E. Terrell, L. H. Marsh, L. A. Dawson and J. A. Ship. Xerostomia and its predictors following parotid-sparing irradiation of head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2001. 50:695–704 | Included in Original CER
A. Eisbruch, J. A. Ship, L. A. Dawson, H. M. Kim, C. R. Bradford, J. E. Terrell, D. B. Chepeha, T. N. Teknos, N. D. Hogikyan, Y. Anzai, L. H. Marsh, R. K. Ten Haken and G. T. Wolf. Salivary gland sparing and improved target irradiation by conformal and intensity modulated irradiation of head and neck cancer. World J Surg. 2003. 27:832–7 | Nonrelevant Study Design
A. Eisbruch, L. A. Dawson, H. M. Kim, C. R. Bradford, J. E. Terrell, D. B. Chepeha, T. N. Teknos, Y. Anzai, L. H. Marsh, M. K. Martel, R. K. Ten Haken, G. T. Wolf and J. A. Ship. Conformal and intensity modulated irradiation of head and neck cancer: the potential for improved target irradiation, salivary gland function, and quality of life. Acta Otorhinolaryngol Belg. 1999. 53:271–5 | Nonrelevant Study Design
A. Eisbruch, L. H. Marsh, L. A. Dawson, C. R. Bradford, T. N. Teknos, D. B. Chepeha, F. P. Worden, S. Urba, A. Lin, M. J. Schipper and G. T. Wolf. Recurrences near base of skull after IMRT for head-and-neck cancer: implications for target delineation in high neck and for parotid gland sparing. Int J Radiat Oncol Biol Phys. 2004. 59:28–42 | Nonrelevant Disease
A. Eisbruch, P. C. Levendag, F. Y. Feng, D. Teguh, T. Lyden, P. I. Schmitz, M. Haxer, I. Noever, D. B. Chepeha and B. J. Heijmen. Can IMRT or brachytherapy reduce dysphagia associated with chemoradiotherapy of head and neck cancer? The Michigan and Rotterdam experiences. Int J Radiat Oncol Biol Phys. 2007. 69:S40–2 | Nonprimary Data
A. Eisbruch, R. K. Ten Haken, H. M. Kim, L. H. Marsh and J. A. Ship. Dose, volume, and function relationships in parotid salivary glands following conformal and intensity-modulated irradiation of head and neck cancer. Int J Radiat Oncol Biol Phys. 1999. 45:577–87 | Nonrelevant Study Design
A. Eisbruch. Intensity-modulated radiotherapy of head-and-neck cancer: encouraging early results. Int J Radiat Oncol Biol Phys. 2002. 53:1–3 | Nonprimary Data
A. I. Blanco, K. S. Chao, I. El Naqa, G. E. Franklin, K. Zakarian, M. Vicic and J. O. Deasy. Dose-volume modeling of salivary function in patients with head-and-neck cancer receiving radiotherapy. Int J Radiat Oncol Biol Phys. 2005. 62:1055–69 | Nonrelevant Study Design
A. Kovacs, G. Antal, C. S. Glavak, J. Hadjiev, G. Liposits, C. S. Vandulek, F. Lakosi, R. C. Colen and I. Repa. Treatment of head-neck cancer patients using conpas technique. 2 years follow up results. Radiotherapy and Oncology. 2012. 103:S455–S456 | Abstract Only
A. Kumar, E. Shih, N. Woody, S. A. Koyfman, J. P. Saxton, C. P. Rodriguez, D. J. Adelstein, P. Xia and J. F. Greskovich. A dosimetric correlation of radiation dose and early grade 3 dysphagia in oropharyngeal cancer patients: A comparison of conventional and IMRT plans. International Journal of Radiation Oncology Biology Physics. 2011. 81:S499 | Abstract Only
A. Kumar, T. Bledsoe, A. Noble, Q. Shang, J. P. Saxton, C. Rodriguez, D. J. Adelstein, S. A. Koyfman, P. Xia and J. F. Greskovich. A dosimetric analysis of imrt versus 3D planning and its impact on acute grade 3 dysphagia and xerostomia in oropharyngeal cancer patients treated with chemoradiation therapy. International Journal of Radiation Oncology Biology Physics. 2012. 84:S477 | Abstract Only
A. Lee. The battle against nasopharyngeal cancer. Radiotherapy and Oncology. 2012. 103:S198 | Abstract Only
A. Ligey, J. Gentil, G. Crehange, X. Montbarbon, P. Pommier, K. Peignaux, G. Truc and P. Maingon. Impact of target volumes and radiation technique on loco-regional control and survival for patients with unilateral cervical lymph node metastases from an unknown primary. Radiotherapy and Oncology. 2009. 93:483–487 | Nonrelevant Disease
A. M. Allen, T. Pawlicki, L. Dong, E. Fourkal, M. Buyyounouski, K. Cengel, J. Plastaras, M. K. Bucci, T. I. Yock, L. Bonilla, R. Price, E. E. Harris and A. A. Konski. An evidence based review of proton beam therapy: The report of ASTRO’s emerging technology committee. Radiotherapy and Oncology. 2012. 103:8–11 | Nonprimary Data
A. M. Chen, B. Q. Li, D. G. Farwell, J. Marsano, S. Vijayakumar and J. A. Purdy. Improved dosimetric and clinical outcomes with intensity-modulated radiotherapy for head-and-neck cancer of unknown primary origin. International Journal of Radiation Oncology Biology Physics. 2011. 79:756–762 | Nonrelevant Study Design
A. M. Chen, D. G. Farwell, D. H. Lau, B. Q. Li, Q. Luu and P. J. Donald. Radiation therapy in the management of head-and-neck cancer of unknown primary origin: How does the addition of concurrent chemotherapy affect the therapeutic ratio?. International Journal of Radiation Oncology Biology Physics. 2011. 81:346–352 | Nonrelevant Study Design
A. M. Chen, D. G. Farwell, Q. Luu, L. M. Chen, S. Vijayakumar and J. A. Purdy. Misses and near-misses after postoperative radiation therapy for head and neck cancer: Comparison of IMRT and non-IMRT techniques in the CT-simulation era. Head and Neck. 2010. 32:1452–1459 | Nonrelevant Study Design
A. M. Chen, W. H. Hall, J. Li, L. Beckett, D. G. Farwell, D. H. Lau and J. A. Purdy. Brachial plexus-associated neuropathy after high-dose radiation therapy for head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2012. 84:165–9 | Nonrelevant Study Design
A. Miah, S. Gulliford, S. Bhide, K. Newbold, K. Harrington and C. Nutting. Dose volume histogram atlases of xerostomia incidence: An alternative predictor of recovery of salivary function. Radiotherapy and Oncology. 2011. 98:S27–S28 | Abstract Only
A. Miah, S. Gulllford, K. Harrington, S. Bhlde, K. Newbold and C. Nutting. Recovery of salivary gland toxicity: Contralateral parotid gland (PG) versus bilateral superficial lobes parotid sparing IMRT (parsport versus parsport II). Radiotherapy and Oncology. 2011. 99:S211 | Abstract Only
A. Popovtzer, I. Gluck, D. B. Chepeha, T. N. Teknos, J. S. Moyer, M. E. Prince, C. R. Bradford and A. Eisbruch. The Pattern of Failure After Reirradiation of Recurrent Squamous Cell Head and Neck Cancer: Implications for Defining the Targets. International Journal of Radiation Oncology Biology Physics. 2009. 74:1342–1347 | Nonrelevant Study Design
A. Ruiz, R. D’Ambrosi, A. Castano, R. De Juan, P. Cotrina, P. Sarandeses, S. Guardado, J. Perez-Regadera, M. Colmenero and E. Lanzos. Prediction of early response to radiation therapy using FDG-PET standard uptake value. Radiotherapy and Oncology. 2012. 103:S462–S463 | Abstract Only
A. Turaka, L. Tianyu, A. D. Cohen, B. Pro, M. Millenson, V. Robu, T. I. Al-Saleem and M. R. Smith. Results of radiation therapy for primary extranodal lymphoma of the head and neck: A report of case series. Blood. 2011. 118:#pages# | Abstract Only
A. Turaka, T. Li, M. M. Millenson and M. R. Smith. Results of radiation therapy for primary extranodal lymphoma of the head and neck: A report of case series. International Journal of Radiation Oncology Biology Physics. 2012. 84:S621 | Abstract Only
A. Turaka, T. Li, N. Nicolaou, M. N. Lango, B. Burtness, E. M. Horwitz, J. A. Ridge and S. J. Feigenberg. Use of a conventional Low Neck Field (LNF) and intensity-modulated radiotherapy (IMRT): No clinical detriment of IMRT to an anterior LNF during the treatment of Head-and neck-cancer. International Journal of Radiation Oncology Biology Physics. 2011. 79:65–70 | Nonrelevant Study Design
A. W. Chan, S. M. McBride, M. Cianchetti, P. M. Busse, N. N. Ali and J. J. Wang. Tobacco smoking during radiation treatment predicts for decreased survival in patients with oropharyngeal Carcinoma. International Journal of Radiation Oncology Biology Physics. 2011. 81:S487 | Abstract Only
A. W. Lee, W. T. Ng, L. L. Chan, W. M. Hung, C. C. Chan, H. C. Sze, O. S. Chan, A. T. Chang and R. M. Yeung. Evolution of treatment for nasopharyngeal cancer - Success and setback in the intensity-modulated radiotherapy era. Radiother Oncol. 2014. 110:377–84 | Nonrelevant Study Design
A. W. M. Lee, W. T. Ng, L. K. Chan, O. S. H. Chan, W. M. Hung, C. C. Chan, P. T. C. Cheng, H. Sze, T. S. Lam and T. K. Yau. The strength/weakness of the AJCC/UICC staging system (7th edition) for nasopharyngeal cancer and suggestions for future improvement. Oral Oncology. 2012. 48:1007–1013 | Nonrelevant Study Design
B. A. Jereczek-Fossa, A. Kowalczyk, A. D’Onofrio, G. Catalano, C. Garibaldi, G. Boboc, V. Vitolo, M. C. Leonardi, R. Cambria and R. Orecchia. Three-dimensional conformal or stereotactic reirradiation of recurrent, metastatic or new primary tumors: Analysis of 108 patients. Strahlentherapie und Onkologie. 2008. 184:36–40 | Nonrelevant Study Design
B. A. Murphy, J. L. Beaumont, J. Isitt, A. S. Garden, C. K. Gwede, A. M. Trotti, R. F. Meredith, J. B. Epstein, Q. T. Le, D. M. Brizel, L. A. Bellm, N. Wells and D. Cella. Mucositis-Related Morbidity and Resource Utilization in Head and Neck Cancer Patients Receiving Radiation Therapy With or Without Chemotherapy. Journal of Pain and Symptom Management. 2009. 38:522–532 | Nonrelevant Study Design
B. Bussels, A. Maes, R. Hermans, S. Nuyts, C. Weltens and W. Van den Bogaert. Recurrences after conformal parotid-sparing radiotherapy for head and neck cancer. Radiother Oncol. 2004. 72:119–27 | Nonrelevant Study Design
B. L. T. Ramaekers, M. Pijls-Johannesma, M. A. Joore, P. van den Ende, J. A. Langendijk, P. Lambin, A. G. H. Kessels and J. P. C. Grutters. Systematic review and meta-analysis of radiotherapy in various head and neck cancers: Comparing photons, carbon-ions and protons. Cancer Treatment Reviews. 2011. 37:185–201 | Nonprimary Data
B. M. Beadle, K. P. Liao, L. S. Elting, T. A. Buchholz, K. K. Ang, A. S. Garden and B. A. Guadagnolo. Improved survival using intensity-modulated radiation therapy in head and neck cancers: A SEER-medicare analysis. Cancer. 2014. 120:702–710 | Nonrelevant Study Design
B. Pehlivan, F. Luthi, O. Matzinger, M. Betz, D. Dragusanu, S. Bulling, L. Bron, P. Pasche, W. Seelentag, R. O. Mirimanoff, A. Zouhair and M. Ozsahin. Feasibility and efficacy of accelerated weekly concomitant boost postoperative radiation therapy combined with concomitant chemotherapy in patients with locally advanced head and neck cancer. Annals of Surgical Oncology. 2009. 16:1337–1343 | Nonrelevant Study Design
B. S. Hoppe, C. J. Nelson, D. R. Gomez, L. D. Stegman, A. J. Wu, S. L. Wolden, D. G. Pfister, M. J. Zelefsky, J. P. Shah, D. H. Kraus and N. Y. Lee. Unresectable Carcinoma of the Paranasal Sinuses: Outcomes and Toxicities. International Journal of Radiation Oncology Biology Physics. 2008. 72:763–769 | Nonrelevant Study Design
B. S. Hoppe, L. D. Stegman, M. J. Zelefsky, K. E. Rosenzweig, S. L. Wolden, S. G. Patel, J. P. Shah, D. H. Kraus and N. Y. Lee. Treatment of nasal cavity and paranasal sinus cancer with modern radiotherapy techniques in the postoperative setting--the MSKCC experience. Int J Radiat Oncol Biol Phys. 2007. 67:691–702 | Nonrelevant Study Design
C. A. Kristensen, F. Kjaer-Kristoffersen, W. Sapru, A. K. Berthelsen, A. Loft and L. Specht. Nasopharyngeal carcinoma. Treatment planning with IMRT and 3D conformal radiotherapy. Acta Oncol. 2007. 46:214–20 | Nonrelevant Study Design
C. B. Hess and A. M. Chen. Global and health-related quality of life after intensity-modulated radiation therapy for head and neck cancer. Expert Review of Anticancer Therapy. 2012. 12:1469–1477 | Nonprimary Data
C. Chen, W. Yi, J. Gao, X. H. Li, L. J. Shen, B. F. Li, Z. W. Tu, Y. L. Tao, C. B. Jiang and Y. F. Xia. Alternative endpoints to the 5-year overall survival and locoregional control for nasopharyngeal carcinoma: A retrospective analysis of 2,450 patients. Mol Clin Oncol. 2014. 2:385–392 | Nonrelevant Study Design
C. Chin, N. Riaz, F. Ho, M. Hu, J. Hong, E. Sherman, R. Wong, S. Wolden, S. Rao and N. Lee. Can meaningful and durable locoregional control be achieved for oral cavity squamous cell carcinoma (OCSCC) treated with definitive radiation therapy (RT)?. International Journal of Radiation Oncology Biology Physics. 2012. 84:S464–S465 | Abstract Only
C. Chin, N. Riaz, F. Ho, M. Hu, J. Hong, E. Sherman, R. Wong, S. Wolden, S. Rao and N. Lee. Surgery improves outcome in recurrent squamous cell carcinoma of the oral cavity. International Journal of Radiation Oncology Biology Physics. 2012. 84:S466 | Abstract Only
C. H. Clark, E. A. Miles, M. T. Guerrero Urbano, S. A. Bhide, A. M. Bidmead, K. J. Harrington and C. M. Nutting. Pre-trial quality assurance processes for an intensity-modulated radiation therapy (IMRT) trial: PARSPORT, a UK multicentre Phase III trial comparing conventional radiotherapy and parotid-sparing IMRT for locally advanced head and neck cancer. British Journal of Radiology. 2009. 82:585–594 | Nonprimary Data
C. Huang, E. Huang, C. Wang, H. Chen, H. Hsu, Y. Huang, Y. Wang and F. Fang. Treatment outcome and prognostic factors for nasopharyngeal carcinoma with cranial nerve palsy treated by conventional or conformal radiotherapy. International Journal of Radiation Oncology Biology Physics. 2011. 81:S509 | Abstract Only
C. Lertbutsayanukul, K. Shotelersuk, C. Khorprasert, T. Sanghangthum, S. Oonsiri, Ayuthaya, II, C. Jumpangern, S. Suriyapee and P. Rojpornpradit. A two-year experience of implementing 3 dimensional radiation therapy and intensity-modulated radiation therapy for 925 patients in King Chulalongkorn Memorial Hospital. J Med Assoc Thai. 2008. 91:215–24 | Nonprimary Data
C. Liberatoscioli, J. A. Langendijk, C. Van Herpen, L. Collette, E. M. Ozsahin, R. Karra Gurunath, D. A. Lacombe, A. Gulyban, N. Gosselin and W. Budach. EORTC 22071–24071: Randomized, phase III trial of EGFR-antibody combined with adjuvant chemoradiation for patients with head and neck squamous cell carcinoma (HNSCC) at high risk of recurrence. Journal of Clinical Oncology. 2011. 29:#pages# | Abstract Only
C. M. Lim, D. A. Clump, D. E. Heron and R. L. Ferris. Stereotactic Body Radiotherapy (SBRT) for primary and recurrent head and neck tumors. Oral Oncology. 2013. #volume#:#pages# | Nonprimary Data
C. M. Nutting, J. P. Morden, K. J. Harrington, T. G. Urbano, S. A. Bhide, C. Clark, E. A. Miles, A. B. Miah, K. Newbold, M. Tanay, F. Adab, S. J. Jefferies, C. Scrase, B. K. Yap, R. P. A’Hern, M. A. Sydenham, M. Emson and E. Hall. Parotid-sparing intensity modulated versus conventional radiotherapy in head and neck cancer (PARSPORT): A phase 3 multicentre randomised controlled trial. The Lancet Oncology. 2011. 12:127–136 | Included in Original CER
C. M. Van Rij, W. D. Oughlane-Heemsbergen, A. H. Ackerstaff, E. A. Lamers, A. J. M. Balm and C. R. N. Rasch. Parotid gland sparing IMRT for head and neck cancer improves xerostomia related quality of life. Radiation Oncology. 2008. 3:#pages# | Nonrelevant Study Design
C. Makita, T. Nakamura, A. Takada, K. Takayama, T. Katou and N. Fuwa. Proton beam therapy for patients with Stage T4 and/or N3 nasopharyngeal carcinoma. Radiotherapy and Oncology. 2012. 103:S452–S453 | Abstract Only
C. S. Lin, Y. M. Jen, W. Y. Kao, C. L. Ho, M. S. Dai, C. L. Shih, J. C. Cheng, P. Y. Chang, W. Y. Huang and Y. F. Su. Improved outcomes in buccal squamous cell carcinoma. Head and Neck. 2013. 35:65–71 | Nonrelevant Study Design
C. W. Hodge, S. M. Bentzen, G. Wong, K. L. Palazzi-Churas, P. A. Wiederholt, V. Gondi, G. M. Richards, G. K. Hartig and P. M. Harari. Are we influencing outcome in oropharynx cancer with intensity-modulated radiotherapy? An inter-era comparison. Int J Radiat Oncol Biol Phys. 2007. 69:1032–41 | Included in Original CER
C. Y. Hsiung, H. M. Ting, H. Y. Huang, C. H. Lee, E. Y. Huang and H. C. Hsu. Parotid-sparing intensity-modulated radiotherapy (IMRT) for nasopharyngeal carcinoma: preserved parotid function after IMRT on quantitative salivary scintigraphy, and comparison with historical data after conventional radiotherapy. Int J Radiat Oncol Biol Phys. 2006. 66:454–61 | Included in Original CER
D. B. Shultz, J. D. Murphy, M. E. Daly, W. Hara, Q. T. Le and D. T. Chang. Radiotherapy for adenoid cystic carcinomas of the head and neck: Clinical outcomes and patterns of failure. International Journal of Radiation Oncology Biology Physics. 2011. 81:S528 | Abstract Only
D. Chua, P. Ho, V. Lee and J. Sham. A randomized phase II study of external beam reirradiation versus external beam reirradiation plus radiosurgery boost in recurrent nasopharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2011. 81:S506 | Abstract Only
D. E. Peterson, W. Doerr, A. Hovan, A. Pinto, D. Saunders, L. S. Elting, F. K. L. Spijkervet and M. T. Brennan. Osteoradionecrosis in cancer patients: The evidence base for treatment-dependent frequency, current management strategies, and future studies. Supportive Care in Cancer. 2010. 18:1089–1098 | Nonprimary Data
D. E. Soto, M. L. Kessler, M. Piert and A. Eisbruch. Correlation between pretreatment FDG-PET biological target volume and anatomical location of failure after radiation therapy for head and neck cancers. Radiotherapy and Oncology. 2008. 89:13–18 | Nonrelevant Study Design
D. F. Lee, M. Davis, M. Rajaraman, H. Hollenhorst and D. Wilke. Impact of intensity modulated radiotherapy on weight loss and percutaneous gastrostomy tube placement rates in advanced head and neck cancer patients. International Journal of Radiation Oncology Biology Physics. 2011. 81:S520 | Abstract Only
D. Fried, A. Khandani, C. Shores, M. Weissler, N. Hayes, T. Hackman, J. Rosenman and B. Chera. Matched cohort analysis of the effect of pre-treatment positron emission tomography on clinical outcomes of head and neck cancer patients treated with definitive chemoradiotherapy. International Journal of Radiation Oncology Biology Physics. 2011. 81:S537 | Abstract Only
D. Fried, J. Rosenman, M. Varia, D. Morris, C. Shores, M. Weissler, T. Hackman and B. Chera. A matched cohort comparison of head and neck squamous cell carcinoma patients treated with intensity modulated radiation therapy versus conventional radiotherapy. International Journal of Radiation Oncology Biology Physics. 2011. 81:S545 | Abstract Only
D. Fried, M. Lawrence, A. Khandani, J. Rosenman, T. Cullip and B. Chera. Is image registration of FDG-PET for head and neck treatment planning necessary?. International Journal of Radiation Oncology Biology Physics. 2011. 81:S539–S540 | Abstract Only
D. I. Rosenthal, G. B. Gunn, T. R. Mendoza, A. S. Garden, B. M. Beadle, W. H. Morrison, X. S. Wang, S. J. Frank, R. S. Weber, K. K. Ang and C. S. Cleeland. Long-term symptom burden after radiation treatment for oropharynx cancer: A comparison of 3D and IMRT techniques. Journal of Clinical Oncology. 2011. 29:#pages# | Abstract Only
D. I. Rosenthal, M. S. Chambers, C. D. Fuller, N. C. S. Rebueno, J. Garcia, M. S. Kies, W. H. Morrison, K. K. Ang and A. S. Garden. Beam Path Toxicities to Non-Target Structures During Intensity-Modulated Radiation Therapy for Head and Neck Cancer. International Journal of Radiation Oncology Biology Physics. 2008. 72:747–755 | Nonrelevant Study Design
D. J. Givens, L. H. Karnell, A. K. Gupta, G. H. Clamon, N. A. Pagedar, K. E. Chang, D. J. Van Daele and G. F. Funk. Adverse events associated with concurrent chemoradiation therapy in patients with head and neck cancer. Archives of Otolaryngology - Head and Neck Surgery. 2009. 135:1209–1217 | Nonrelevant Study Design
D. Rades, F. Fehlauer, J. Wroblesky, D. Albers, S. E. Schild and R. Schmidt. Prognostic factors in head-and-neck cancer patients treated with surgery followed by intensity-modulated radiotherapy (IMRT), 3D-conformal radiotherapy, or conventional radiotherapy. Oral Oncol. 2007. 43:535–43 | Included in Original CER
D. S. Lin, Y. M. Jen, J. C. Lee, S. C. Liu and Y. S. Lin. Recurrence of nasopharyngeal carcinoma in the parotid region after parotid-gland-sparing radiotherapy. J Formos Med Assoc. 2011. 110:655–60 | Nonrelevant Study Design
D. W. Golden, M. Witt, S. R. Rudra, T. I. Nwizu, E. E. Cohen, E. Blair, K. M. Stenson, E. E. Vokes and D. J. Haraf. Outcomes of induction chemotherapy and concurrent chemoradiation for nasopharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2012. 84:S485–S486 | Abstract Only
E. A. Klein, M. Guiou, D. G. Farwell, Q. Luu, D. H. Lau, K. Stuart, A. Vaughan, S. Vijayakumar and A. M. Chen. Primary radiation therapy for head-and-neck cancer in the setting of human immunodeficiency virus. International Journal of Radiation Oncology Biology Physics. 2011. 79:60–64 | Nonrelevant Study Design
E. Bragantini, S. Girlando, V. Vanoni, A. Bolner, F. Valduga, R. Carella, M. Barbareschi, M. Silvestrini, C. Grandi and P. Dalla Palma. Oropharynx cancer: Evaluation of clinical outcome according to HPV status and radiotherapy technique. Virchows Archiv. 2011. 459:S106–S107 | Abstract Only
E. H. Pow, D. L. Kwong, A. S. McMillan, M. C. Wong, J. S. Sham, L. H. Leung and W. K. Leung. Xerostomia and quality of life after intensity-modulated radiotherapy vs. conventional radiotherapy for early-stage nasopharyngeal carcinoma: initial report on a randomized controlled clinical trial. Int J Radiat Oncol Biol Phys. 2006. 66:981–91 | Included in Original CER
E. Katsoulakis, M. Hu, N. Riaz, S. Wolden, S. Rao and N. Lee. Outcomes of radiation therapy for hypopharyngeal squamous cell carcinoma: A single institution experience. International Journal of Radiation Oncology Biology Physics. 2012. 84:S494 | Abstract Only
F. Bekiroglu, N. Ghazali, R. Laycock, C. Katre, D. Lowe and S. N. Rogers. Adjuvant radiotherapy and health-related quality of life of patients at intermediate risk of recurrence following primary surgery for oral squamous cell carcinoma. Oral Oncology. 2011. 47:967–973 | Nonrelevant Study Design
F. Caparrotti, V. Vinh-Hung, N. Mach, P. Dulguerov, R. Miralbell and M. Betz. Concomitant radiotherapy and cetuximab for head and neck cancer: Late toxicity and outcomes. Strahlentherapie und Onkologie. 2011. 187:536 | Abstract Only
F. Dionisi, F. Bracco, D. Asnaghi, A. Cocchi, E. Iannacone and M. F. Palazzi. Quality of life of head neck cancer patients 1 year after radiotherapy with the use of EORTC QLQ-C30 and HN-35 modules. Radiotherapy and Oncology. 2012. 103:S454–S455 | Abstract Only
F. Ho, N. Riaz, C. Chin, M. Hu, J. Hong, E. Sherman, R. Wong, S. Wolden, S. Rao and N. Lee. IMRT versus conventional radiation therapy for postoperative treatment of oral cavity squamous cell carcinoma (OCSCC). International Journal of Radiation Oncology Biology Physics. 2012. 84:S465–S466 | Abstract Only
F. Liu and J. Xiao. Evaluation of fractionated stereotactic radiotherapy with vagina carotica protection for residual nasopharyngeal carcinoma. Radiotherapy and Oncology. 2011. 99:S324 | Abstract Only
F. Liu, J. P. Xiao, Y. J. Xu, Y. Zhang, G. Z. Xu, L. Gao, J. L. Yi, J. W. Luo, X. D. Huang, F. K. Huan, H. Fang, B. Wan and Y. X. Li. Fractionated stereotactic radiotherapy with vagina carotica protection technique for local residual nasopharyngeal carcinoma after primary radiotherapy. Chin Med J (Engl). 2012. 125:2525–9 | Nonrelevant Study Design
F. M. Fang, C. Y. Chien, W. L. Tsai, H. C. Chen, H. C. Hsu, C. C. Lui, T. L. Huang and H. Y. Huang. Quality of Life and Survival Outcome for Patients With Nasopharyngeal Carcinoma Receiving Three-Dimensional Conformal Radiotherapy vs. Intensity-Modulated Radiotherapy-A Longitudinal Study. International Journal of Radiation Oncology Biology Physics. 2008. 72:356–364 | Included in Original CER
F. M. Fang, W. L. Tsai, H. C. Chen, H. C. Hsu, C. Y. Hsiung, C. Y. Chien and S. F. Ko. Intensity-modulated or conformal radiotherapy improves the quality of life of patients with nasopharyngeal carcinoma: comparisons of four radiotherapy techniques. Cancer. 2007. 109:313–21 | Included in Original CER
F. M. Fang, W. L. Tsai, T. F. Lee, K. C. Liao, H. C. Chen and H. C. Hsu. Multivariate analysis of quality of life outcome for nasopharyngeal carcinoma patients after treatment. Radiotherapy and Oncology. 2010. 97:263–269 | Nonrelevant Study Design
F. Moretto, M. Rampino, F. Munoz, M. G. Ruo Redda, A. Reali, V. Balcet, S. Badellino, C. Piva, M. Schena, M. Airoldi, O. Ostellino, G. Pecorari, R. Ragona and U. Ricardi. Conventional 2D (2DRT) and 3D conformal radiotherapy (3DCRT) versus intensity-modulated radiotherapy (IMRT) for nasopharyngeal cancer treatment. Radiol Med. 2014. #volume#:#pages# | Nonrelevant Study Design
F. Roeder, F. Zwicker, L. Saleh-Ebrahimi, C. Timke, C. Thieke, M. Bischof, J. Debus and P. E. Huber. Intensity modulated or fractionated stereotactic reirradiation in patients with recurrent nasopharyngeal cancer. Radiation Oncology. 2011. 6:#pages# | Nonrelevant Study Design
F. Y. Feng, H. M. Kim, T. H. Lyden, M. J. Haxer, F. P. Worden, M. Feng, J. S. Moyer, M. E. Prince, T. E. Carey, G. T. Wolf, C. R. Bradford, D. B. Chepeha and A. Eisbruch. Intensity-modulated chemoradiotherapy aiming to reduce dysphagia in patients with oropharyngeal cancer: Clinical and functional results. Dysphagia. 2011. 26:206–207 | Nonrelevant Study Design
G. A. Hobeika, Y. Zia, G. Walker, M. Samuels, M. Abramowitz and N. Elsayyad. Definitive radiation therapy for locally advanced oropharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2012. 84:S474 | Abstract Only
G. B. Gunn, G. M. Chronowski, A. S. Garden, S. J. Frank, W. H. Morrison, B. M. Beadle, C. M. Lewis, T. R. Mendoza, C. S. Cleeland and D. I. Rosenthal. Symptom-free cure following unilateral radiation therapy for tonsil cancer: A patient-reported outcomes (PRO) benchmark. International Journal of Radiation Oncology Biology Physics. 2012. 84:S467 | Abstract Only
G. B. Gunn, T. R. Mendoza, A. S. Garden, X. S. Wang, W. H. Morrison, S. J. Frank, E. Y. Hanna, C. Lu, B. M. Beadle, K. K. Ang, C. S. Cleeland and D. I. Rosenthal. Patient-reported fatigue in head and neck cancer survivors. Journal of Clinical Oncology. 2011. 29:#pages# | Abstract Only
G. Dickie, K. Choma, P. Dwyer, C. Lin, B. Higgs and L. Kenny. Head and neck cancer treated with helical IMRT; Initial results and acute toxicity. Journal of Medical Imaging and Radiation Oncology. 2012. 56:252 | Abstract Only
G. F. Huber, C. Gengler, C. Walter, T. Roth, A. Huber and D. Holzmann. Adenocarcinoma of the nasal cavity and paranasal sinuses: Single-institution review of diagnosis, histology, and outcome. Journal of Otolaryngology - Head and Neck Surgery. 2011. 40:34–39 | Nonrelevant Study Design
G. Mok, I. Gauthier, H. Jiang, S. Huang, K. Chan, I. Witterick, J. J. Kim, J. N. Waldron, B. O’Sullivan and J. Ringash. Does IMRT for hypopharyngeal cancer improve locoregional control? A comparison to 3D conformal radiation therapy. International Journal of Radiation Oncology Biology Physics. 2012. 84:S492 | Abstract Only
G. Studer, K. Furrer, B. J. Davis, S. S. Stoeckli, R. A. Zwahlen, U. M. Luetolf and C. Glanzmann. Postoperative IMRT in head and neck cancer. Radiat Oncol. 2006. 1:40 | Nonrelevant Study Design
G. Studer, R. A. Zwahlen, K. W. Graetz, B. J. Davis and C. Glanzmann. IMRT in oral cavity cancer. Radiat Oncol. 2007. 2:16 | Nonrelevant Study Design
H. D. Pacholke, R. J. Amdur, C. G. Morris, J. G. Li, J. F. Dempsey, R. W. Hinerman and W. M. Mendenhall. Late xerostomia after intensity-modulated radiation therapy versus conventional radiotherapy. Am J Clin Oncol. 2005. 28:351–8 | Included in Original CER
H. Hojo, S. Zenda, M. Kawashima, S. Arahira, M. Tahara, R. Hayashi and K. Sasai. The response evaluation using CT/MRI for nasal cavity and paranasal sinuses malignancies treated with radiotherapy or proton beam therapy. European Journal of Cancer. 2011. 47:S567 | Abstract Only
H. Inokuchi, T. Nakamura, T. Tomoda, A. Takada, K. Takayama, C. Makita, M. Shiomi, T. Kato and N. Fuwa. Assessment of acute cervical skin toxicity due to fractionated proton beam therapy for head-and-neck cancer. International Journal of Radiation Oncology Biology Physics. 2012. 84:S836–S837 | Abstract Only
H. Langendijk, R. Steenbakkers, O. Hoegen-Choevalova and H. P. Bijl. Late functional outcome in chemo-radiation. European Journal of Cancer. 2011. 47:S12 | Abstract Only
H. Lee, Y. Ahn, H. Nam, D. Oh, B. Kim, H. Park, J. Park and S. Park. Tumor volume reduction rate during definitive radiation therapy: A potential prognosticator in oropharynx cancer. International Journal of Radiation Oncology Biology Physics. 2012. 84:S470–S471 | Abstract Only
H. P. Van Der Laan, T. Van De Water, H. Van Herpt, M. Christianen, H. P. Bijl, C. Schilstra and H. Langendijk. Dysphagia reduction with optimized photon and proton intensity-modulated radiotherapy for head and neck cancer. Radiotherapy and Oncology. 2011. 99:S72 | Abstract Only
I. Beetz, C. Schilstra, A. Visink, A. van der Schaaf, H. P. Bijl, B. F. van der Laan, R. J. Steenbakkers and J. A. Langendijk. Role of minor salivary glands in developing patient-rated xerostomia and sticky saliva during day and night. Radiother Oncol. 2013. 109:311–6 | Nonrelevant Study Design
I. Beetz, C. Schilstra, P. Luijk’van, M. E. M. C. Christianen, H. P. Bijl, O. Chouvalova, P. Doornaert, E. R. Van Den Heuvel, D. Van, R. J. H. M. Steenbakkers and J. A. Langendijk. 3D-CRT based predictive models for patient-rated xerostomia and sticky saliva are not valid among patients treated with IMRT. International Journal of Radiation Oncology Biology Physics. 2011. 81:S174–S175 | Abstract Only
I. Beetz, R. J. Steenbakkers, O. Chouvalova, C. R. Leemans, P. Doornaert, B. F. van der Laan, M. E. Christianen, A. Vissink, H. P. Bijl, P. van Luijk and J. A. Langendijk. The QUANTEC criteria for parotid gland dose and their efficacy to prevent moderate to severe patient-rated xerostomia. Acta Oncol. 2014. 53:597–604 | Nonrelevant Study Design
I. Mallick, S. K. Gupta, R. Ray, T. Sinha, S. Sinha, R. Achari and S. Chatterjee. Predictors of weight loss during conformal radiotherapy for head and neck cancers - how important are planning target volumes?. Clin Oncol (R Coll Radiol). 2013. 25:557–63 | Nonprimary Data
J. A. Dorth and D. M. Brizel. Incidence of asymptomatic carotid artery stenosis in survivors of head and neck radiation. International Journal of Radiation Oncology Biology Physics. 2011. 81:S76 | Abstract Only
J. Agarwal, S. Rathod, V. Murthy, S. Ghosh-laskar, A. Budrukkar, K. Dinshaw, P. Chaturvedi, K. Prabhash, A. D’Cruz and T. Gupta. Improved quality of life (QOL) outcomes in patients with head-and-neck squamous cell carcinoma (HNSCC) treated with intensity modulated radiation therapy (IMRT) compared to 3-dimensional conformal radiation therapy (3D-CRT): Evidence from a prospective randomized study. International Journal of Radiation Oncology Biology Physics. 2012. 84:S211 | Abstract Only
J. B. Yu, P. R. Soulos, R. Sharma, D. V. Makarov, R. H. Decker, B. D. Smith, R. A. Desai, L. D. Cramer and C. P. Gross. Patterns of care and outcomes associated with intensity-modulated radiation therapy versus conventional radiation therapy for older patients with head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2012. 83:e101–7 | Nonrelevant Study Design
J. Buntzel, M. Glatzel, R. Mucke, O. Micke and F. Bruns. Influence of amifostine on late radiation-toxicity in head and neck cancer--a follow-up study. Anticancer Res. 2007. 27:1953–6 | Nonrelevant Study Design
J. Caudell, W. Carroll, J. Locher and J. Bonner. Factors associated with long term dysphagia following treatment of locally advanced head and neck cancer with surgery and post-operative radiotherapy. Dysphagia. 2011. 26:450–451 | Abstract Only
J. Hey, J. Setz, R. Gerlach, M. Janich, G. Hildebrandt, D. Vordermark, C. R. Gernhardt and T. Kuhnt. Parotid gland-recovery after radiotherapy in the head and neck region--36 months follow-up of a prospective clinical study. Radiat Oncol. 2011. 6:125 | Nonrelevant Study Design
J. J. Beitler, Q. Zhang, K. K. Fu, A. Trotti, S. A. Spencer, C. U. Jones, A. S. Garden, G. Shenouda, J. Harris and K. K. Ang. Rtog 90–03: Final report. International Journal of Radiation Oncology Biology Physics. 2012. 84:S6 | Abstract Only
J. J. Wang, T. A. Goldsmith, A. S. Holman, M. Cianchetti and A. W. Chan. Pharyngoesophageal stricture after treatment for head and neck cancer. Head and Neck. 2012. 34:967–973 | Nonprimary Data
J. Kharofa, N. Choong, D. Wang, S. Firat, C. Schultz, C. Sadasiwan and S. Wong. Continuous-course reirradiation with concurrent carboplatin and paclitaxel for locally recurrent, nonmetastatic squamous cell carcinoma of the head-and-neck. Int J Radiat Oncol Biol Phys. 2012. 83:690–5 | Nonrelevant Study Design
J. Kubes, J. Cvek, V. Vondracek, M. Pala and D. Feltl. Accelerated radiotherapy with concomitant boost technique (69.5 Gy/5 weeks): An alternative in the treatment of locally advanced head and neck cancer. Strahlentherapie und Onkologie. 2011. 187:651–655 | Nonrelevant Study Design
J. L. Yi, L. Gao, X. D. Huang, S. Y. Li, J. W. Luo, W. M. Cai, J. P. Xiao and G. Z. Xu. Nasopharyngeal carcinoma treated by radical radiotherapy alone: Ten-year experience of a single institution. Int J Radiat Oncol Biol Phys. 2006. 65:161–8 | Nonrelevant Study Design
J. Mundi and M. St. John. Evaluation of trends in use of IMRT in head and neck cancer. Otolaryngology - Head and Neck Surgery. 2011. 145:166 | Abstract Only
J. Petsuksiri, A. Sermsree, K. Thephamongkhol, P. Keskool, K. Thongyai, Y. Chansilpa and P. Pattaranutaporn. Sensorineural hearing loss after concurrent chemoradiotherapy in nasopharyngeal cancer patients. Radiation Oncology. 2011. 6:#pages# | Nonrelevant Study Design
J. S. Kornerup, N. Brodin, C. Birk Christiansen, M. Aznar, T. Bjork-Eriksson, A. Kiil Berthelsen, E. Markova, A. Loft Jacobsen, L. Borgwardt and P. Munck af Rosenschold. Influence of pet data on the radiation therapy planning of pediatric cancer. International Journal of Radiation Oncology Biology Physics. 2012. 84:S639–S640 | Abstract Only
J. Staffurth. A review of the clinical evidence for intensity-modulated radiotherapy. Clinical Oncology. 2010. 22:643–657 | Nonprimary Data
J. T. Chang, C. Y. Lin, K. H. Fan, H. M. Wang, C. T. Liao, K. Kang and S. F. Hung. The treatment result of advanced stage oropharyngeal cancer by radiotherapy with or without chemotherapy - The impact of intensity modulation radiotherapy and FDG-PET. European Journal of Cancer. 2011. 47:S555 | Abstract Only
J. Vargo, D. E. Heron, R. L. Ferris, J. M. Rwigema, R. E. Wegner, R. Kalash, J. Ohr, G. J. Kubicek and S. Burton. Treatment duration>2 weeks negatively impacts disease control following SBRT for locally recurrent, previously irradiated headand-neck cancers. International Journal of Radiation Oncology Biology Physics. 2012. 84:S510 | Abstract Only
J. W. G. Roe, P. N. Carding, R. C. Dwivedi, R. A. Kazi, P. H. Rhys-Evans, K. J. Harrington and C. M. Nutting. Swallowing outcomes following Intensity Modulated Radiation Therapy (IMRT) for head & neck cancer - A systematic review. Oral Oncology. 2010. 46:727–733 | Nonprimary Data
J. W. Jang, R. J. Parambi, T. A. Goldsmith, A. S. Holman, L. J. Wirth, J. R. Clark, P. M. Busse and A. W. Chan. Factors associated with prolonged gastrostomy tube usage in patients with oropharyngeal cancer treated with chemoradiation. International Journal of Radiation Oncology Biology Physics. 2012. 84:S479 | Abstract Only
J. W. Roe, P. N. Carding, R. C. Dwivedi, R. A. Kazi, P. H. Rhys-Evans, K. J. Harrington and C. M. Nutting. Swallowing outcomes following intensity modulated radiation therapy (IMRT) for head and neck cancer - A systematic review. Dysphagia. 2011. 26:428 | Abstract Only
J. Waldron, S. Huang, W. Xu, H. Zhao, D. Chen, J. Kim, A. Bayley, K. Chan, R. Gilbert and B. O’Sullivan. Neck-specific outcome of N2–N3 head-and-neck cancer treated with radiation (plus or minus) chemotherapy. International Journal of Radiation Oncology Biology Physics. 2012. 84:S206 | Abstract Only
K. E. Rusthoven, D. Raben, A. Ballonoff, M. Kane, J. I. Song and C. Chen. Effect of radiation techniques in treatment of oropharynx cancer. Laryngoscope. 2008. 118:635–9 | Included in Original CER
K. Hu, L. B. Harrison, R. A. Shourbaji, B. Culliney, Z. Li and W. Fouad Mourad. Outcomes of occult primary (OP) of the head and neck squamous cell carcinoma (HNSCC) treated with oropharynx (OPX)-targeted radiotherapy (RT) and concurrent chemotherapy (CCRT). Journal of Clinical Oncology. 2012. 30:#pages# | Abstract Only
K. Hu, M. Kumar, S. Sura, B. Culliney, T. Tran, A. Jacobson, M. Perksy, M. Urken, P. Costantino and L. Harrison. Can stage III–IV head and neck cancer patients be treated with unilateral radiotherapy?. International Journal of Radiation Oncology Biology Physics. 2011. 81:S486–S487 | Abstract Only
K. Hu, W. F. Mourad, R. Shourbaji, W. Lin, B. Culliney, A. Jacobson, T. Tran, M. Urken, M. Persky and L. B. Harrison. Five-year outcomes of oropharynx (OPX) targeted radiation therapy (RT) for metastatic squamous cell carcinoma of unknown primary (MUP) in the head and neck. International Journal of Radiation Oncology Biology Physics. 2012. 84:S22 | Abstract Only
K. Jingu, K. Abe, M. Koto, K. Fujimoto, H. Matsushita, T. Sugawara, R. Umezawa, N. Kadoya, K. Takeda and S. Yamada. Does IMRT increase loco-regional failure in patients with nasopharyngeal cancer? A first report. Radiotherapy and Oncology. 2012. 103:S447–S448 | Abstract Only
K. S. Chao, J. O. Deasy, J. Markman, J. Haynie, C. A. Perez, J. A. Purdy and D. A. Low. A prospective study of salivary function sparing in patients with head-and-neck cancers receiving intensity-modulated or three-dimensional radiation therapy: initial results. Int J Radiat Oncol Biol Phys. 2001. 49:907–16 | Included in Original CER
K. S. Chao, N. Majhail, C. J. Huang, J. R. Simpson, C. A. Perez, B. Haughey and G. Spector. Intensity-modulated radiation therapy reduces late salivary toxicity without compromising tumor control in patients with oropharyngeal carcinoma: a comparison with conventional techniques. Radiother Oncol. 2001. 61:275–80 | Included in Original CER
K. Tsuchiya, K. Yasuda, Y. Nishikawa, R. Kinoshita, R. Onimaru and H. Shirato. Retrospective comparison between cisplatin plus fluorouracil and weekly cisplatin in concurrent chemoradiation therapy setting for stage II–IV nasopharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2012. 84:S484–S485 | Abstract Only
L. B. Harrison, K. Hu, R. A. Shourbaji, B. Culliney, Z. Li, M. Urken, M. Persky and W. F. Mourad. The role of postoperative radiotherapy (PORT) in the management of parotid gland malignancy (PGM). Journal of Clinical Oncology. 2012. 30:#pages# | Abstract Only
L. Costa, M. Buglione, N. Pasinetti, E. Castrezzati, R. Cavagnini, S. Tonoli and S. M. Magrini. Oropharynx cancer (OC): Acute/sub-acute toxicity in pts treated with 3D-conformal radiotherapy and IMRT. Radiotherapy and Oncology. 2012. 103:S448 | Abstract Only
L. Kong, Y. W. Zhang, C. S. Hu and Y. Guo. Neoadjuvant chemotherapy followed by concurrent chemoradiation for locally advanced nasopharyngeal carcinoma. Chinese Journal of Cancer. 2010. 29:551–555 | Nonrelevant Study Design
L. Ma, L. Du, L. Feng, X. Zhang, F. Li, G. Zhou, B. Qu, S. Xu and C. Xie. Treatment of nasopharyngeal carcinoma with helical tomotherapy: A retrospective study of 121 cases. International Journal of Radiation Oncology Biology Physics. 2012. 84:S485 | Abstract Only
L. Ma, Q. Guo, Y. Zhang, X. Kong, L. Yang, S. Lin, C. Huang, J. Pan and J. Lu. The effect of intensity-modulated radiotherapy versus conventional radiotherapy on quality of life in patients with nasopharyngeal cancer: a cross-sectional study. Head Neck Oncol. 2013. 5:8 | Nonrelevant Study Design
L. Veldeman, I. Madani, F. Hulstaert, G. De Meerleer, M. Mareel and W. De Neve. Evidence behind use of intensity-modulated radiotherapy: a systematic review of comparative clinical studies. The Lancet Oncology. 2008. 9:367–375 | Nonprimary Data
M. Abdel-Wahab, A. Abitbol, I. Elattar, O. Mahmoud, M. Troner and A. Lewin. Does radiation technique influence peg dependence? A comparison between intensity modulated radiation therapy and 3-dimensional conformal techniques. International Journal of Radiation Oncology Biology Physics. 2012. 84:S652 | Abstract Only
M. Boomsma-Van Holten, H. P. Bijl, M. Christianen, I. Beetz, O. Chouvalova, R. Steenbakkers, B. Van Der Laan, S. Oostinq, C. Schilstra and H. Langendijk. A NTCP model for radiation-induced hypothyroidism based on a prospective cohort study. Radiotherapy and Oncology. 2011. 98:S25–S26 | Abstract Only
M. E. Daly, Y. Lieskovsky, T. Pawlicki, J. Yau, H. Pinto, M. Kaplan, W. E. Fee, A. Koong, D. R. Goffinet, L. Xing and Q. T. Le. Evaluation of patterns of failure and subjective salivary function in patients treated with intensity modulated radiotherapy for head and neck squamous cell carcinoma. Head Neck. 2007. 29:211–20 | Included in Original CER
M. F. Roenjom, C. Brink, L. Hegedus, J. Overgaard and J. Johansen. Dose-response of hypothyroidism after primary radiotherapy in carcinoma of the head and neck (HNSCC). Radiotherapy and Oncology. 2012. 103:S202 | Abstract Only
M. Feng, S. Jabbari, A. Lin, C. R. Bradford, D. B. Chepeha, T. N. Teknos, F. P. Worden, C. Tsien, M. J. Schipper, G. T. Wolf, L. A. Dawson and A. Eisbruch. Predictive factors of local-regional recurrences following parotid sparing intensity modulated or 3D conformal radiotherapy for head and neck cancer. Radiother Oncol. 2005. 77:32–8 | Nonrelevant Study Design
M. Hu, E. Katsoulakis, N. Riaz, S. Jaffery, S. Rao and N. Lee. Excellent laryngeal preservation can be achieved with imrt for locoregionally advanced laryngeal cancer. International Journal of Radiation Oncology Biology Physics. 2012. 84:S495–S496 | Nonrelevant Study Design
M. K. Bhayani, K. A. Hutcheson, D. Barringer, A. Lisec, D. Roberts, S. Y. Lai and J. S. Lewin. Identification and management of oropharyngeal carcinoma patients with risk factors for gastrostomy tube placement and dependence. International Journal of Radiation Oncology Biology Physics. 2011. 81:S495 | Abstract Only
M. Lambrecht, D. Nevens and S. Nuyts. The effect of IMRT on outcome and toxicity compared to 3DCRT. A mono-centric, retrospective analysis. Radiotherapy and Oncology. 2012. 103:S456 | Abstract Only
M. Leclerc, E. Lartigau, T. Lacornerie, J. Daisne and V. Gregoire. Target volume delineation based on 18FDG PET for locally advanced head and neck cancer treated by chemo-radiotherapy. Radiotherapy and Oncology. 2012. 103:S175–S176 | Abstract Only
M. Lopez-Valcarcel, R. Moleron, E. Amaya, A. Sanz, P. Tavera, M. Hernandez, M. A. Cobo, J. Romero, C. Ispizua and A. De La Torre. Helical tomotherapy and 3D-conformal radiotherapy in nasopharyngeal cancer: Dosimetric and toxicity comparison. Radiotherapy and Oncology. 2012. 103:S445 | Abstract Only
M. Louise Kent, M. T. Brennan, J. L. Noll, P. C. Fox, S. H. Burri, J. C. Hunter and P. B. Lockhart. Radiation-induced trismus in head and neck cancer patients. Support Care Cancer. 2008. 16:305–9 | Nonrelevant Study Design
M. M. Qureshi, P. B. Romesser, L. T. Chatburn, R. M. Subramaniam and M. Truong. Determining the optimal prognostic volumetric threshold of gross tumor volume in head and neck cancer treated by radiotherapy. International Journal of Radiation Oncology Biology Physics. 2011. 81:S536 | Abstract Only
M. Palazzi, E. Orlandi, P. Bossi, E. Pignoli, P. Potepan, M. Guzzo, M. Franceschini, G. Scaramellini, G. Cantu, L. Licitra, P. Olmi and S. Tomatis. Further Improvement in Outcomes of Nasopharyngeal Carcinoma With Optimized Radiotherapy and Induction Plus Concomitant Chemotherapy: An Update of the Milan Experience. International Journal of Radiation Oncology Biology Physics. 2009. 74:774–780 | Nonrelevant Study Design
M. Qureshi, P. B. Romesser, A. Ajani, L. A. Kachnic and M. Truong. Gross tumor volume presentation in different race/ethnic groups as a determinant of treatment outcome in head-and-neck cancer patients treated with definitive radiation therapy. International Journal of Radiation Oncology Biology Physics. 2012. 84:S539 | Abstract Only
M. R. Vergeer, P. A. H. Doornaert, D. H. F. Rietveld, C. R. Leemans, B. J. Slotman and J. A. Langendijk. Intensity-Modulated Radiotherapy Reduces Radiation-Induced Morbidity and Improves Health-Related Quality of Life: Results of a Nonrandomized Prospective Study Using a Standardized Follow-Up Program. International Journal of Radiation Oncology Biology Physics. 2009. 74:1–8 | Included in Original CER
M. Roenjom, C. Brink, L. Hegedu s, J. Overgaard and J. Johansen. Hypothyroidism after primary radiation therapy in squamous cell carcinoma of the head and neck (HNSCC). International Journal of Radiation Oncology Biology Physics. 2012. 84:S61 | Abstract Only
M. Sujith Kumar, S. Chakraborty, M. Geetha, E. P. Greeshma, M. Kumar and B. Sateeshan. Geriatric radiation oncology practice in a tertiary care center in India: Cure sometimes, comfort always. Journal of Cancer Research and Therapeutics. 2012. 8:S176–S177 | Abstract Only
M. Suntharalingam, Y. Kwok, O. Goloubeva, A. Parekh, R. Taylor, J. Wolf, A. Zimrin, S. Strome, R. Ord and K. J. Cullen. Phase II study evaluating the addition of cetuximab to the concurrent delivery of weekly carboplatin, paclitaxel, and daily radiotherapy for patients with locally advanced squamous cell carcinomas of the head and neck. International Journal of Radiation Oncology Biology Physics. 2012. 82:1845–1850 | Nonrelevant Study Design
M. T. Milano, E. E. Vokes, J. Kao, W. Jackson, M. A. List, K. M. Stenson, M. E. Witt, A. Dekker, E. MacCracken, M. C. Garofalo, S. J. Chmura, R. R. Weichselbaum and D. J. Haraf. Intensity-modulated radiation therapy in advanced head and neck patients treated with intensive chemoradiotherapy: preliminary experience and future directions. Int J Oncol. 2006. 28:1141–51 | Nonrelevant Study Design
M. Vergeer, P. Doornaert, D. Rietveld, C. R. Leemans, J. A. Langendijk and B. Slotman. IMRT in head and neck cancer: Prognostic factors and patterns of recurrence. Radiotherapy and Oncology. 2012. 103:S279–S280 | Abstract Only
M. W. Munter, S. Hoffner, H. Hof, K. K. Herfarth, U. Haberkorn, V. Rudat, P. Huber, J. Debus and C. P. Karger. Changes in salivary gland function after radiotherapy of head and neck tumors measured by quantitative pertechnetate scintigraphy: comparison of intensity-modulated radiotherapy and conventional radiation therapy with and without Amifostine. Int J Radiat Oncol Biol Phys. 2007. 67:651–9 | Nonprimary Data
M. Y. Chen and R. Jiang. Endoscopic surgery and IMRT are effective in recurrent NPC. Otolaryngology - Head and Neck Surgery. 2011. 145:65 | Abstract Only
M. Yao, L. H. Karnell, G. F. Funk, H. Lu, K. Dornfeld and J. M. Buatti. Health-related quality-of-life outcomes following IMRT versus conventional radiotherapy for oropharyngeal squamous cell carcinoma. Int J Radiat Oncol Biol Phys. 2007. 69:1354–60 | Included in Original CER
N. C. Sheets, S. B. Wheeler, R. E. Kohler, D. V. Fried, P. M. Brown and B. S. Chera. Costs of care in a matched pair comparison of intensity-modulated radiation therapy (IMRT) versus conventional radiation therapy (CRT) for the treatment of head and neck cancer. American Journal of Clinical Oncology: Cancer Clin. 2013. #volume#:#pages# | Nonrelevant Study Design
N. Galanopoulos, M. Yao, P. Lavertu, A. Argiris, J. Greskovich, P. Fu, J. Wasman, R. Rezaee, M. Machtay and P. Savvides. Phase II study of concurrent chemoradiation with bevacizumab and docetaxel for treatment of locally advanced squamous cell carcinoma of the head and neck (SCCHN). International Journal of Radiation Oncology Biology Physics. 2011. 81:S77 | Abstract Only
N. Joshi, S. Mallick, A. Gandhi, S. Pandit, B. Mohanti, G. Rath, D. Sharma and P. Julka. Reirradiation in head-and-neck cancers: An indian tertiary cancer center experience. International Journal of Radiation Oncology Biology Physics. 2012. 84:S476 | Abstract Only
N. Lee, C. Akazawa, P. Akazawa, J. M. Quivey, C. Tang, L. J. Verhey and P. Xia. A forward-planned treatment technique using multisegments in the treatment of head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2004. 59:584–94 | Nonrelevant Study Design
N. Riaz, S. Jaffery, M. Hu, S. Wolden, S. Rao and N. Lee. Is IMRT associated with inferior outcomes for T1-2N0 squamous cell carcinoma of the larynx?. International Journal of Radiation Oncology Biology Physics. 2012. 84:S495 | Abstract Only
N. Wiedenmann, S. Bucher, M. Mix, M. Hentschel, M. I. Bittner, S. Adebahr, C. Offermann, U. Nestle, W. Weber and A. Grosu. Tumor hypoxia in head and neck cancer during radiochemotherapy evaluated with serial [18f]-fluoromisonidazole pet. Radiotherapy and Oncology. 2012. 102:S163–S164 | Abstract Only
N. Y. Lee, F. F. de Arruda, D. R. Puri, S. L. Wolden, A. Narayana, J. Mechalakos, E. S. Venkatraman, D. Kraus, A. Shaha, J. P. Shah, D. G. Pfister and M. J. Zelefsky. A comparison of intensity-modulated radiation therapy and concomitant boost radiotherapy in the setting of concurrent chemotherapy for locally advanced oropharyngeal carcinoma. Int J Radiat Oncol Biol Phys. 2006. 66:966–74 | Included in Original CER
O. Ardenfors, D. Josefsson and A. Dasu. Are IMRT treatments in the H&N region increasing the risk of secondary cancers?. Radiotherapy and Oncology. 2012. 103:S569–S570 | Abstract Only
O. K. Jilani, P. Singh, A. G. Wernicke, D. I. Kutler, W. Kuhel, P. Christos, D. Nori, A. Sabbas, K. S. C. Chao and B. Parashar. Radiation therapy is well tolerated and produces excellent control rates in elderly patients with locally advanced head and neck cancers. Journal of Geriatric Oncology. 2012. 3:337–343 | Nonrelevant Study Design
P. A. Paximadis, M. Christensen, D. Kamdar, G. Dyson, A. Sukari, H. Lin, H. Kim and G. Yoo. Up-front neck dissection followed by definitive chemoradiation in patients with regionally advanced head and neck cancer. International Journal of Radiation Oncology Biology Physics. 2011. 81:S546 | Abstract Only
P. B. Romesser, M. M. Qureshi, L. A. Kachnic and M. Truong. Non-english speaking language rather than non-white race predicts treatment outcomes in patients treated with radiotherapy (RT) for head and neck cancer (HNC). International Journal of Radiation Oncology Biology Physics. 2011. 81:S556–S557 | Abstract Only
P. B. Romesser, M. M. Qureshi, R. M. Subramaniam, O. Sakai, S. Jalisi and M. T. Truong. A prognostic volumetric threshold of gross tumor volume in head and neck cancer patients treated with radiotherapy. American Journal of Clinical Oncology: Cancer Clin. 2012. #volume#:#pages# | Nonrelevant Study Design
P. C. Levendag, D. N. Teguh, F. Keskin-Cambay, A. Al-Mamgani, P. Van Rooij, E. Astreinidou, S. L. S. Kwa, B. Heijmen, D. A. Monserez and S. O. S. Osman. Single vocal cord irradiation: A competitive treatment strategy in early glottic cancer. Radiotherapy and Oncology. 2011. 101:415–419 | Nonrelevant Study Design
P. C. Levendag, D. N. Teguh, P. Voet, H. van der Est, I. Noever, W. J. de Kruijf, I. K. Kolkman-Deurloo, J. B. Prevost, J. Poll, P. I. Schmitz and B. J. Heijmen. Dysphagia disorders in patients with cancer of the oropharynx are significantly affected by the radiation therapy dose to the superior and middle constrictor muscle: a dose-effect relationship. Radiother Oncol. 2007. 85:64–73 | Nonrelevant Study Design
P. C. Levendag, F. J. Lagerwaard, C. de Pan, I. Noever, A. van Nimwegen, O. Wijers and P. J. Nowak. High-dose, high-precision treatment options for boosting cancer of the nasopharynx. Radiother Oncol. 2002. 63:67–74 | Nonrelevant Study Design
P. Dirix and S. Nuyts. Value of intensity-modulated radiotherapy in stage IV head-and-neck squamous cell carcinoma. International Journal of Radiation Oncology Biology Physics. 2010. 78:1373–1380 | Overlapping Patient Population
P. Graff, M. Lapeyre, E. Desandes, C. Ortholan, R. J. Bensadoun, M. Alfonsi, P. Maingon, P. Giraud, J. Bourhis, V. Marchesi, A. Mege and D. Peiffert. Impact of intensity-modulated radiotherapy on health-related quality of life for head and neck cancer patients: matched-pair comparison with conventional radiotherapy. Int J Radiat Oncol Biol Phys. 2007. 67:1309–17 | Nonrelevant Study Design
P. Levendag, D. N. Teguh, F. Keskin-Cambay, S. L. S. Kwa, P. Rooij Van, A. Al-Mamgani, E. Astreinidou, B. Heijmen, M. Hoogeman and S. O. S. Osman. Single vocal cord irradiation - A competitive treatment strategy in early glottic cancer. European Journal of Cancer. 2011. 47:S561 | Abstract Only
P. M. Braam, C. H. Terhaard, J. M. Roesink and C. P. Raaijmakers. Intensity-modulated radiotherapy significantly reduces xerostomia compared with conventional radiotherapy. Int J Radiat Oncol Biol Phys. 2006. 66:975–80 | Nonrelevant Study Design
P. Mohindra, P. A. Wiederholt, H. M. Geye, D. Khuntia, T. Hoang, A. M. Traynor, T. Speer, T. M. McCulloch, G. K. Hartig and P. M. Harari. Squamous cell carcinoma of the oropharynx: 20-year outcome results. International Journal of Radiation Oncology Biology Physics. 2012. 84:S481 | Abstract Only
P. Paximadis, G. Yoo, H. S. Lin, J. Jacobs, A. Sukari, G. Dyson, M. Christensen and H. Kim. Concurrent chemoradiotherapy improves survival in patients with hypopharyngeal cancer. International Journal of Radiation Oncology Biology Physics. 2012. 82:1515–1521 | Nonrelevant Study Design
P. R. Patel, J. Lee, D. Kundu, K. Temple, R. May, W. Lee, D. Yoo and D. Brizel. Postoperative radiation therapy for salivary gland tumors: Factors associated with treatment failure and toxicity. International Journal of Radiation Oncology Biology Physics. 2012. 84:S502–S503 | Abstract Only
P. Y. Chen, H. H. Chen, J. R. Hsiao, M. W. Yang, W. T. Hsueh, S. T. Tasi, F. C. Lin and Y. H. Wu. Intensity-modulated radiotherapy improves outcomes in postoperative patients with squamous cell carcinoma of the oral cavity. Oral Oncol. 2012. 48:747–52 | Nonrelevant Study Design
Q. Guo, W. Jiang, S. Lin, L. Yang, C. Chen, L. Xu, J. Wu and J. Pan. Radiation therapy for locoregionally advanced nasopharyngeal carcinoma in elderly patients. Journal of Radiation Oncology. 2012. 1:323–332 | Nonrelevant Study Design
R. Banner, S. Gwynne, N. Palaniappan, J. Mathlin, S. Beachus, T. Rackley, L. Moss and M. Evans. Acute toxicity of chemo-IMRT for oropharyngeal cancer (OPC). A prospective audit compared with published data. Radiotherapy and Oncology. 2012. 103:S453–S454 | Abstract Only
R. Beesley, J. Rieger, S. Compton, M. Parliament, H. Seikaly and J. Wolfaardt. Comparison of tooth loss between intensity-modulated and conventional radiotherapy in head and neck cancer patients. Journal of Otolaryngology - Head and Neck Surgery. 2012. 41:389–395 | Nonrelevant Study Design
R. C. Miller, M. Lodge, M. H. Murad and B. Jones. Controversies in clinical trials in proton radiotherapy: The present and the future. Seminars in Radiation Oncology. 2013. 23:127–133 | Nonprimary Data
R. I. Smee, N. S. Meagher, K. Broadley, T. Ho, J. R. Williams and G. P. Bridger. Recurrent nasopharyngeal carcinoma: current management approaches. Am J Clin Oncol. 2010. 33:469–73 | Nonrelevant Study Design
R. J. Bensadoun, D. Riesenbeck, P. B. Lockhart, L. S. Elting, F. K. L. Spijkervet and M. T. Brennan. A systematic review of trismus induced by cancer therapies in head and neck cancer patients. Supportive Care in Cancer. 2010. 18:1033–1038 | Nonprimary Data
R. J. H. M. Steenbakkers, I. Beetz, O. Chouvalova, P. Doornaert, D. Rietveld, B. F. A. M. Van Der Laan, A. Vissink, H. P. Bijl, P. Van Luijk and J. A. Langendijk. Quantec dose volume constraints for parotid glands are feasible only in a minority of H&N patients treated with IMRT. Radiotherapy and Oncology. 2012. 103:S202–S203 | Abstract Only
R. Rahmati, N. Lee, G. Linkov, A. Mohebati and D. Kraus. Outcomes in recurrent head and neck cancer after salvage surgery and flap reconstruction with postoperative reirradiation (RE-RT). International Journal of Radiation Oncology Biology Physics. 2011. 81:S548 | Abstract Only
S. B. Jensen, A. M. L. Pedersen, A. Vissink, E. Andersen, C. G. Brown, A. N. Davies, J. Dutilh, J. S. Fulton, L. Jankovic, N. N. F. Lopes, A. L. S. Mello, L. V. Muniz, C. A. Murdoch-Kinch, R. G. Nair, J. J. Napenas, A. Nogueira-Rodrigues, D. Saunders, B. Stirling, I. Von Bultzingslowen, D. S. Weikel, L. S. Elting, F. K. L. Spijkervet and M. T. Brennan. A systematic review of salivary gland hypofunction and xerostomia induced by cancer therapies: Management strategies and economic impact. Supportive Care in Cancer. 2010. 18:1061–1079 | Nonprimary Data
S. B. Jensen, A. M. L. Pedersen, A. Vissink, E. Andersen, C. G. Brown, A. N. Davies, J. Dutilh, J. S. Fulton, L. Jankovic, N. N. F. Lopes, A. L. S. Mello, L. V. Muniz, C. A. Murdoch-Kinch, R. G. Nair, J. J. Napenas, A. Nogueira-Rodrigues, D. Saunders, B. Stirling, I. Von Bultzingslowen, D. S. Weikel, L. S. Elting, F. K. L. Spijkervet and M. T. Brennan. A systematic review of salivary gland hypofunction and xerostomia induced by cancer therapies: Prevalence, severity and impact on quality of life. Supportive Care in Cancer. 2010. 18:1039–1060 | Nonprimary Data
S. Chopra, D. Kamdar, O. E. Tulunay Ugur, G. Chen, B. Peshek, M. Marunick, H. Kim, H. S. Lin and J. Jacobs. Factors predictive of severity of osteoradionecrosis of the mandible. Head and Neck. 2011. 33:1600–1605 | Nonrelevant Study Design
S. Clavel, D. H. A. Nguyen, B. Fortin, P. Despres, N. Khaouam, D. Donath, D. Soulires, L. Guertin and P. F. Nguyen-Tan. Simultaneous integrated boost using intensity-modulated radiotherapy compared with conventional radiotherapy in patients treated with concurrent carboplatin and 5-fluorouracil for locally advanced oropharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2012. 82:582–589 | Nonrelevant Study Design
S. Colbert, M. Algholmy, M. Gray, S. Walji and J. Davies. Management of the cervical lymph node metastasis of unknown origin. British Journal of Oral and Maxillofacial Surgery. 2011. 49:S43 | Abstract Only
S. Das, S. G. Laskar, D. Gupta, T. Gupta, V. Murthy, A. Budrukkar and J. P. Agarwal. Hearing loss after conformal radiotherapy in non-nasopharyngeal head and neck cancer-A prospective study. Journal of Cancer Research and Therapeutics. 2012. 8:S186–S187 | Abstract Only
S. E. Mowry, C. Tang, A. Sadeghi and M. B. Wang. Standard chemoradiation versus intensity-modulated chemoradiation: A quality of life assessment in oropharyngeal cancer patients. European Archives of Oto-Rhino-Laryngology. 2010. 267:1111–1116 | Nonrelevant Study Design
S. F. Qiu, J. D. J. Lu, S. J. Lin, I. W. K. Tham, J. Lu and J. J. Pan. Three-dimensional conformal radiation therapy in the salvage of 212 locally recurrent nasopharyngeal carcinoma cases. International Journal of Radiation Oncology Biology Physics. 2011. 81:S508–S509 | Abstract Only
S. Ghosh-Laskar, D. A. Chaukar, J. P. Agarwal, T. Gupta, A. Budrukkar and V. Murthy. Comparison of early quality of life (QOL) in patients with squamous cell carcinoma of the head and neck (HNSCC) treated with 3-dimensional conformal radiotherapy (3D-CRT) versus intensity modulated radiotherapy (IMRT). Oral Oncology. 2011. 47:S56 | Abstract Only
S. Guha, C. G. Kelly, R. Guha, R. Achari, I. Mallick, V. Paleri, A. J. Munro and S. Chatterjee. Intensity modulated radiation therapy (IMRT) in the treatment of squamous carcinoma of the oropharynx: An overview. Journal of Cancer Science and Therapy. 2012. 4:77–83 | Nonprimary Data
S. Gulliford, A. Miah, S. Brennan, M. Partridge, K. Harrington and C. Nutting. The dose-volume response of posterior fossa and brainstem with respect to acute fatigue. Radiotherapy and Oncology. 2011. 99:S428 | Abstract Only
S. Gulliford, A. Miah, S. Brennan, M. Partridqe, K. Harrinqton and C. Nutting. Dose-volume atlases of complication incidence for acute fatigue: Data from the parsport trial. Radiotherapy and Oncology. 2011. 98:S28 | Abstract Only
S. H. Chan, W. T. Ng, K. L. Kam, M. C. H. Lee, C. W. Choi, T. K. Yau, A. W. M. Lee and S. K. Chow. Sensorineural Hearing Loss After Treatment of Nasopharyngeal Carcinoma: A Longitudinal Analysis. International Journal of Radiation Oncology Biology Physics. 2009. 73:1335–1342 | Nonrelevant Study Design
S. H. Kataoka, F. C. Setzer, E. R. Fregnani, O. F. Pessoa, E. Gondim, Jr. and C. L. Caldeira. Effects of 3-dimensional conformal or intensity-modulated radiotherapy on dental pulp sensitivity during and after the treatment of oral or oropharyngeal malignancies. J Endod. 2012. 38:148–52 | Nonrelevant Outcome
S. Iganej, G. L. Buchschacher and I. A. Abdalla. Triweekly carboplatin alone in the treatment of oropharyngeal carcinoma with definitive concurrent chemoradiation: Outcomes of 120 unselected patients and a comparison to the RTOG 0129 regimen results. Journal of Clinical Oncology. 2012. 30:#pages# | Abstract Only
S. Jabbari, H. M. Kim, M. Feng, A. Lin, C. Tsien, M. Elshaikh, J. E. Terrel, C. Murdoch-Kinch and A. Eisbruch. Matched case-control study of quality of life and xerostomia after intensity-modulated radiotherapy or standard radiotherapy for head-and-neck cancer: initial report. Int J Radiat Oncol Biol Phys. 2005. 63:725–31 | Included in Original CER
S. K. Gupta, R. Ray, S. Chatterjee, T. Sinha, S. Sinha, D. Gowardhanan, R. Achari and I. Mallick. Predictors of weight loss during conformal radiotherapy for head and neck cancers-How important are PTV volumes?. Journal of Cancer Research and Therapeutics. 2012. 8:S192–S193 | Abstract Only
S. K. Mullapally, B. K. Mohanti, M. A. Laviraj, S. Thulkar, V. Subramani, A. Sharma, S. Bhasker, R. M. Pandey, A. Thakkar and G. K. Rath. Image guided adaptive radiotherapy (IGART) of head and neck cancer: Volumetric and clinical evidence. Radiotherapy and Oncology. 2012. 103:S284 | Abstract Only
S. L. Gulliford, A. B. Miah, S. Brennan, D. McQuaid, C. H. Clark, M. Partridge, K. J. Harrington, J. P. Morden, E. Hall and C. M. Nutting. Dosimetric explanations of fatigue in head and neck radiotherapy: an analysis from the PARSPORT Phase III trial. #journal#. 2013. #volume#:205–12 | Nonprimary Data
S. L. Shiao, J. M. Quivey, V. K. Weinberg, D. W. Eisele, C. M. Glastonbury and S. S. Yom. Radiotherapy for carcinoma of the hypopharynx over four decades: Experience at the university of california san francisco. International Journal of Radiation Oncology Biology Physics. 2011. 81:S514–S515 | Abstract Only
S. L. Wolden, W. C. Chen, D. G. Pfister, D. H. Kraus, S. L. Berry and M. J. Zelefsky. Intensity-modulated radiation therapy (IMRT) for nasopharynx cancer: update of the Memorial Sloan-Kettering experience. Int J Radiat Oncol Biol Phys. 2006. 64:57–62 | Included in Original CER
S. Laskar, G. Bahl, M. Muckaden, S. K. Pai, T. Gupta, S. Banavali, B. Arora, D. Sharma, P. A. Kurkure, M. Ramadwar, S. Viswanathan, V. Rangarajan, S. Qureshi, D. D. Deshpande, S. K. Shrivastava and K. A. Dinshaw. Nasopharyngeal Carcinoma in Children: Comparison of Conventional and Intensity-Modulated Radiotherapy. International Journal of Radiation Oncology Biology Physics. 2008. 72:728–736 | Nonrelevant Study Design
S. M. Karandikar, K. Bokil, S. P. Deshmukh, S. Basu, B. Shinde, H. Patil and N. Gupta. Retrospective analysis of head and neck cancer patients successfully treated with chemoradiation plus nimotuzumab. Journal of Clinical Oncology. 2011. 29:#pages# | Abstract Only
S. M. Magrini, S. Tonoli, L. Costa, N. Pasinetti, F. Paiar, L. Livi, G. Simontacchi, I. Meattini, L. Pegurri, P. Borghetti, P. Frata, P. Ponticelli, M. Buglione and G. Biti. A benchmark study on 883 nasopharyngeal cancer patients treated in two Italian centres from 1977 to 2000. Part II: Evolving technical choices and toxicity patterns. Radiol Med. 2012. 117:715–24 | Nonrelevant Study Design
S. M. McBride, R. J. Parambi, J. W. Jang, T. Goldsmith, P. M. Busse and A. W. Chan. Intensity-modulated versus conventional radiation therapy for oropharyngeal carcinoma: long-term dysphagia and tumor control outcomes. Head Neck. 2014. 36:492–8 | Nonrelevant Study Design
S. McBride, J. J. Wang, P. M. Busse and A. W. Chan. Predictors of distant metastasis in locally advanced oropharyngeal squamous cell carcinoma. International Journal of Radiation Oncology Biology Physics. 2011. 81:S489–S490 | Abstract Only
S. Rathod, T. Gupta, S. Laskar, V. Murthy, A. Budrukkar, K. Prabhash, P. Chaturvedi and J. Agarwal. Change in health-related quality of life scores predict survival in head-and-neck squamous cell carcinoma treated with definitive high precision radiation therapy: Evidence from a prospective study. International Journal of Radiation Oncology Biology Physics. 2012. 84:S649 | Abstract Only
S. Tonoli, D. Alterio, O. Caspiani, A. Bacigalupo, F. Bunkheila, M. Cianciulli, A. Merlotti, A. Podhrdska, M. Rampino and D. Cante. Nasopharyngeal cancer: Treatment technique, dose homogeneity and acute toxicity in an Italian prospective study. Radiotherapy and Oncology. 2012. 103:S277–S278 | Abstract Only
S. Tonoli, S. M. Magrini, L. Costa, F. Paiar, G. Simontacchi, V. Scotti, N. Pasinetti, R. Barca, D. Barbieri, A. De Stefani, E. Cellai, M. Buglione and G. Biti. A benchmark study on 883 nasopharyngeal cancer patients treated in two Italian centres from 1977 to 2000. Part I: Evolving technical choices and survival. Radiol Med. 2012. 117:690–714 | Nonrelevant Study Design
S. Tribius and C. Bergelt. Intensity-modulated radiotherapy versus conventional and 3D conformal radiotherapy in patients with head and neck cancer: Is there a worthwhile quality of life gain?. Cancer Treatment Reviews. 2011. 37:511–519 | Nonprimary Data
S. W. Loo, K. Geropantas, C. Beadsmoore, P. Q. Montgomery, W. M. C. Martin and T. W. Roques. Neck dissection can be avoided after sequential chemoradiotherapy and negative post-treatment positron emission tomography-computed tomography in N2 Head and neck squamous cell carcinoma. Clinical Oncology. 2011. 23:512–517 | Nonrelevant Study Design
S. Wan Leung, T. F. Lee, C. Y. Chien, P. J. Chao, W. L. Tsai and F. M. Fang. Health-related Quality of life in 640 head and neck cancer survivors after radiotherapy using EORTC QLQ-C30 and QLQ-H&N35 questionnaires. BMC Cancer. 2011. 11:#pages# | Nonrelevant Study Design
T. Bledsoe, A. Noble, G. Hunter, L. Rybicki, A. Hoschar, D. Chute, J. P. Saxton, J. F. Greskovich, D. J. Adelstein and S. A. Koyfman. Oropharyngeal squamous cell carcinoma (OPSCC) with known human papillomavirus (HPV) status treated with definitive chemoradiation therapy: Patterns of failure and toxicity outcomes. International Journal of Radiation Oncology Biology Physics. 2012. 84:S478 | Abstract Only
T. Dijkema, C. P. J. Raaijmakers, R. K. Ten Haken, J. M. Roesink, P. M. Braam, A. C. Houweling, M. A. Moerland, A. Eisbruch and C. H. J. Terhaard. Parotid gland function after radiotherapy: The combined Michigan and Utrecht experience. International Journal of Radiation Oncology Biology Physics. 2010. 78:449–453 | Nonrelevant Study Design
T. Goldsmith, J. Wang, A. Holman and A. W. Chan. Risk of Cervical Esophageal Stricture with Intensity Modulated vs. Conventional Radiation Therapy for Head and Neck Cancer: A Systemic Review. International Journal of Radiation Oncology Biology Physics. 2010. 78:S453–S454 | Abstract Only
T. Gupta, S. Jain, J. P. Agarwal, S. Ghosh-Laskar, R. Phurailatpam, R. Pai-Shetty and K. A. Dinshaw. Prospective assessment of patterns of failure after high-precision definitive (chemo)radiation in head-and-neck squamous cell carcinoma. International Journal of Radiation Oncology Biology Physics. 2011. 80:522–531 | Nonrelevant Study Design
T. Hoang, C. Zhang, H. M. Geye, T. Speer, M. Yu, P. A. Wiederholt, J. C. Kakuske, A. M. Traynor, J. F. Cleary, S. H. Dailey, C. N. Ford, T. M. McCulloch, G. K. Hartig and P. M. Harari. Gender associations in head and neck squamous cell carcinoma (HNSCC). Journal of Clinical Oncology. 2012. 30:#pages# | Abstract Only
T. Kodaira, H. Tachibana, N. Tomita, Y. Oshima, K. Hirata, J. Ito, Y. Goto and N. Fuwa. Clinical efficacy of helical tomotherapy for nasopharyngeal cancer treated with definite concurrent chemoradiation therapy. International Journal of Radiation Oncology Biology Physics. 2012. 84:S483 | Abstract Only
T. R. Koo, H. G. Wu, K. H. Kim, M. W. Sung and C. I. Park. Treatment outcomes of radiotherapy for tonsillar carcinoma in the era of intensity-modulated radiotherapy. European Journal of Cancer. 2011. 47:S565–S566 | Abstract Only
T. Shahid, M. S. Chowdhury, G. S. Bhattacharya, S. Murshed, S. Poddar and K. Bhattacharya. Quality of life in head and neck cancer patients after treatment with radical radiotherapy alone or in combination with concurrent chemoradiation. Journal of Cancer Research and Therapeutics. 2012. 8:S169 | Abstract Only
T. Terasawa, T. Dvorak, S. Ip, G. Raman, J. Lau and T. A. Trikalinos. Systematic review: Charged-particle radiation therapy for cancer. Annals of Internal Medicine. 2009. 151:556–565 | Nonprimary Data
T. W. Leung, S. Y. Tung, W. K. Sze, F. C. Wong, K. K. Yuen, C. M. Lui, S. H. Lo, T. Y. Ng and S. K. O. Treatment results of 1070 patients with nasopharyngeal carcinoma: an analysis of survival and failure patterns. Head Neck. 2005. 27:555–65 | Nonrelevant Study Design
T. W. Roques, S. W. Loo, K. Geropantas, C. Beadsmoore, I. Worthington, J. Harrowven and C. Martin. Response assessment with FDG-PET/CT following definitive radiochemotherapy in head and neck cancer. Radiotherapy and Oncology. 2012. 103:S279 | Abstract Only
U. Schick, M. Betz, P. Ghadjar, J. H. A. M. Kaanders and M. Ozsahin. Outcome and prognostic factors in adenosquamous carcinoma of the head and neck: A multi center rare cancer network study. International Journal of Radiation Oncology Biology Physics. 2011. 81:S541–S542 | Abstract Only
U. Schick, M. Betz, P. Ghadjar, J. H. A. M. Kaanders, C. Demiroz and M. Ozsahin. Outcome and prognostic factors in adenosquamous carcinoma of the head and neck - A multicenter rare cancer network study. European Journal of Cancer. 2011. 47:S555 | Abstract Only
V. Budach, C. H. Cho, B. Sedlmaier, M. Wittlinger, H. Iro, E. C. Rita, M. Hautmann, J. Strutz, M. Flentje, B. Hueltenschmidt, L. Moser, M. Bleif, W. Budach, S. Staar, G. Becker, S. Tribius, P. C. Feyer, K. D. Wernecke and J. Werner. Five years’ results of the German ARO 04–01 trial of concurrent 72 Gy hyperfractionated accelerated radiation therapy (HART) plus once weekly cisplatinum/5-FU versus mitomycin C/5-FU in stage IV head and neck cancer. Journal of Clinical Oncology. 2012. 30:#pages# | Abstract Only
V. Gregoire, P. Mamgon, S. Nuyts, G. Calais, N. Grosso, U. Thalin, P. Sorensen, T. Nielsen and E. Brun. An open-label, phase I/II dose-escalation trial investigating zalutumumab, a human monoclonal EGF receptor (EGFR) antibody. In combination with chemoradiation as first line treatment of patients with locoregionally advanced squamous cell carcinoma of the head and neck (SCCHN). Radiotherapy and Oncology. 2010. 96:S309–S310 | Abstract Only
V. Lau, L. M. Chen, D. G. Farwell, Q. Luu, P. Donald and A. M. Chen. Postoperative radiation therapy for head and neck cancer in the setting of orocutaneous and pharyngocutaneous fistula. American Journal of Clinical Oncology: Cancer Clinical Trials. 2011. 34:276–280 | Nonrelevant Study Design
V. M. Duarte, Y. F. Liu, S. Rafizadeh, T. Tajima, V. Nabili and M. B. Wang. Comparison of dental health of patients with head and neck cancer receiving IMRT vs conventional radiation. Otolaryngol Head Neck Surg. 2014. 150:81–6 | Nonrelevant Study Design
V. Murthy, K. Narang, J. P. Agarwal, S. Ghosh-Laskar, T. Gupta and A. Budrukkar. Hypothyroidism after head and neck 3DCRT and IMRT: Prospective data from two randomized trials. Radiotherapy and Oncology. 2012. 103:S176 | Abstract Only
V. Murthy, K. Narang, S. Ghosh-Laskar, T. Gupta, A. Budrukkar and J. P. Agrawal. Hypothyroidism after 3-dimensional conformal radiotherapy and intensity-modulated radiotherapy for head and neck cancers: Prospective data from 2 randomized controlled trials. Head Neck. 2013. #volume#:#pages# | Nonprimary Data
W. C. Chen, T. Z. Hwang, W. H. Wang, C. H. Lu, C. C. Chen, C. M. Chen, H. H. Weng, C. H. Lai and M. F. Chen. Comparison between conventional and intensity-modulated post-operative radiotherapy for stage III and IV oral cavity cancer in terms of treatment results and toxicity. Oral Oncology. 2009. 45:505–510 | Nonrelevant Study Design
W. Duthoy, T. Boterberg, F. Claus, P. Ost, L. Vakaet, S. Bral, F. Duprez, M. Van Landuyt, H. Vermeersch and W. De Neve. Postoperative intensity-modulated radiotherapy in sinonasal carcinoma: clinical results in 39 patients. Cancer. 2005. 104:71–82 | Included in Original CER
W. F. Mourad, K. S. Hu, R. A. Shourbaji, D. Berlach, W. Lin, E. Kaplan-Marans, M. Urken, B. Culliney, M. Persky and L. B. Harrison. Outcomes of parotid gland tumors treated with surgery and postoperative radiation therapy. International Journal of Radiation Oncology Biology Physics. 2012. 84:S499 | Abstract Only
W. F. Mourad, K. S. Hu, R. A. Shourbaji, W. Lin, E. Kaplan-Marans, S. Manolidis, B. Culliney, M. Urken, M. Persky and L. B. Harrison. Pattern of failure of head and neck malignancy (HNM) with perineural invasion (PNI). International Journal of Radiation Oncology Biology Physics. 2012. 84:S506–S507 | Abstract Only
W. L. Kuang, Q. Zhou and L. F. Shen. Outcomes and prognostic factors of conformal radiotherapy versus intensity-modulated radiotherapy for nasopharyngeal carcinoma. Clin Transl Oncol. 2012. 14:783–90 | Nonrelevant Study Design
W. Nijdam, P. Levendag, I. Noever, C. U. Groot and M. Agthoven. Cancer in the oropharynx: cost calculation of different treatment modalities for controlled primaries, relapses and grade III/IV complications. Radiother Oncol. 2005. 77:65–72 | Nonrelevant Study Design
W. S. Liu, H. C. Kuo, J. C. Lin, M. C. Su, J. K. Lee, M. J. Chou, M. C. Chou and H. Lee. Assessment of salivary function change in nasopharyngeal carcinoma treated by parotid-sparing radiotherapy. Cancer J. 2006. 12:494–500 | Nonrelevant Study Design
W. S. Liu, S. P. Lee, J. K. Lee, M. C. Su, G. D. Chen, H. S. Lee and H. Lee. Factors influencing the parotid function in nasopharyngeal carcinoma treated with parotid-sparing radiotherapy. Jpn J Clin Oncol. 2006. 36:626–31 | Nonrelevant Study Design
X. Ou, C. Shen, L. Kong, X. Wang, J. Ding, Y. Gao, T. Xu and C. Hu. Treatment outcome of nasopharyngeal carcinoma with retropharyngeal lymph nodes metastasis only and the feasibility of elective neck irradiation. Oral Oncol. 2012. 48:1045–50 | Nonrelevant Study Design
Y. C. Ahn, K. C. Lee, D. Y. Kim, S. J. Huh, I. H. Yeo, D. H. Lim, M. K. Kim, K. H. Shin, S. Park and S. H. Chang. Fractionated stereotactic radiation therapy for extracranial head and neck tumors. Int J Radiat Oncol Biol Phys. 2000. 48:501–5 | Nonrelevant Study Design
Y. Doi, M. Kenjyo, I. Takahashi, Y. Takeuti, S. Takahashi, I. Nishibuti, Y. Kaneyasu, Y. Murakami, T. Kimura and Y. Nagata. The frequency of adverse events by radiation therapy for atomic bomb survivors with cancer. International Journal of Radiation Oncology Biology Physics. 2012. 84:S538 | Abstract Only
Y. H. Wu, H. M. Wang, H. H. W. Chen, C. Y. Lin, E. Y. C. Chen, K. H. Fan, S. F. Huang, I. H. Chen, C. T. Liao, A. J. Cheng and J. T. C. Chang. Hypothyroidism After Radiotherapy for Nasopharyngeal Cancer Patients. International Journal of Radiation Oncology Biology Physics. 2010. 76:1133–1139 | Nonrelevant Study Design
Y. Li, J. M. Taylor, R. K. Ten Haken and A. Eisbruch. The impact of dose on parotid salivary recovery in head and neck cancer patients treated with radiation therapy. Int J Radiat Oncol Biol Phys. 2007. 67:660–9 | Nonprimary Data
Y. Shibamoto, M. Okamoto, M. Kobayashi, S. Ayakawa, H. Iwata, C. Sugie, Y. Mitsuishi and H. Takahashi. Imax (immunity-maximized) cancer therapy: Combination of dendritic cell-based vaccine and intensity modulated radiation. International Journal of Radiation Oncology Biology Physics. 2012. 84:S74–S75 | Abstract Only
Y. Shibamoto, M. Okamoto, M. Kobayashi, S. Ayakawa, H. Iwata, C. Sugie, Y. Mitsuishi and H. Takahashi. Immune-maximizing (IMAX) therapy for cancer: Combination of dendritic cell vaccine and intensity-modulated radiation. Mol Clin Oncol. 2013. 1:649–654 | Nonrelevant Study Design
Y. Sun and B. Zheng. The clinical outcomes of radiation therapy with VMAT in locoregionally advanced nasopharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2012. 84:S489 | Abstract Only
Y. Wu. Postoperative IMRT improved outcome in patients with oral cavity squamous cell carcinoma. Radiotherapy and Oncology. 2012. 103:S447 | Abstract Only
Y. Zeidan, J. D. Murphy, C. Chan, Y. An, M. Kaplan, A. Colevas, C. Kong and Q. Le. Postoperative radiation therapy for minor salivary gland carcinomas of the head and neck: Long-term outcomes. International Journal of Radiation Oncology Biology Physics. 2012. 84:S500 | Abstract Only
Y. Zhang, Z. A. Lin, J. J. Pan, Z. Zheng, L. Yang, S. J. Lin and F. Zheng. Concurrent control study of different radiotherapy for primary nasopharyngeal carcinoma: Intensity-modulated radiotherapy versus conventional radiotherapy. Chinese Journal of Cancer. 2009. 28:21–26 | Nonrelevant Study Design
Z. H. Wang, C. Yan, Z. Y. Zhang, C. P. Zhang, H. S. Hu, W. Y. Tu, J. Kirwan and W. M. Mendenhall. Outcomes and xerostomia after postoperative radiotherapy for oral and oropharyngeal carcinoma. Head Neck. 2013. #volume#:#pages# | Nonrelevant Study Design
Z. Y. Shao, Z. S. Tang, C. Yan, Y. T. Jiang, R. Ma, Z. Liu and Z. W. Huang. Effects of intensity-modulated radiotherapy on human oral microflora. J Radiat Res. 2011. 52:834–9 | Nonrelevant Outcome