# UPSTF Study Quality Ratings

- The quality of studies was assessed on the basis of the following criteria:
  ○ Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups.
  ○ Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination).
  ○ Important differential loss to followup or overall high loss to followup.
  ○ Measurements: equal, reliable, and valid (includes masking of outcome assessment).
  ○ Clear definition of interventions.
  ○ All important outcomes considered.
  ○ Analysis: adjustment for potential confounders and intention-to-treat analysis.
- The rating of intervention studies were rated according to one of three quality categories:

Good. Meets all criteria; comparable groups were assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments were used and applied equally to the groups; interventions were spelled out clearly; all important outcomes were considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair. Studies were graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: In general, comparable groups were assembled initially, but some questions remain about whether some (although not major) differences occurred with followup; measurement instruments were acceptable (although not the best) and were generally applied equally; some but not all important outcomes were considered; and some but not all potential confounders were accounted for. Intention-to-treat analysis has been done for RCTs.

Poor. Studies were graded “poor” if any of the following fatal flaws exists: Groups assembled initially were not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments were used or not applied at all equally among groups; and key confounders were given little or no attention; lack of masked outcome assessment; and for RCTs, intention-to-treat analysis is lacking.

Table B-1 USPSTF study limitations ratings

Table B-2 Comparative study design and patient characteristics

Table B-3 Summary of radiotherapy techniques

Table B-4 Key acute (< 90 days posttreatment) toxicities

Table B-5 Key late toxicities

Table B-6 Key oncologic outcomes

## References Cited in Appendix B

1 Gupta T, et al. Three-dimensional conformal radiotherapy (3D-CRT) versus intensity modulated radiation therapy (IMRT) in squamous cell carcinoma of the head and neck: a randomized controlled trial. Radiother Oncol. 2012;104(3):343-8. [pmid: 22853852].
2 Rathod S, et al. Quality-of-life (QOL) outcomes in patients with head and neck squamous cell carcinoma (HNSCC) treated with intensity-modulated radiation therapy (IMRT) compared to three-dimensional conformal radiotherapy (3D-CRT): evidence from a prospective randomized study. Oral Oncol. 2013;49(6):634-42. [pmid: 23562564].
3 Al-Mamgani A, et al. The impact of treatment modality and radiation technique on outcomes and toxicity of patients with locally advanced oropharyngeal cancer. Laryngoscope. 2013;123(2):386-93. [pmid: 23404489].
4 Lambrecht M, Nevens D, Nuyts S. Intensity-modulated radiotherapy vs. parotid-sparing 3D conformal radiotherapy. Effect on outcome and toxicity in locally advanced head and neck cancer. Strahlenther Onkol. 2013;189(3):223-9. [pmid: 23319256].
5 Al-Mamgani A, et al. Toxicity, quality of life, and functional outcomes of 176 hypopharyngeal cancer patients treated by (chemo)radiation: the impact of treatment modality and radiation technique. Laryngoscope. 2012;122(8):1789-95. [pmid: 22833307].
6 Chen AM, et al. Intensity-modulated radiotherapy is associated with improved global quality of life among long-term survivors of head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2012;84(1):170-5. [pmid: 22300572].
7 Al-Mamgani A, et al. Highly-conformal intensity-modulated radiotherapy reduced toxicity without jeopardizing outcome in patients with paranasal sinus cancer treated by surgery and radiotherapy or (chemo)radiation. Oral Oncol. 2012;48(9):905-11. [pmid: 22584070].
8 Kruser TJ, et al. Acute hematologic and mucosal toxicities in head and neck cancer patients undergoing chemoradiotherapy: A comparison of 3D-CRT, IMRT, and helical tomotherapy. Technology in Cancer Research and Treatment. 2013;12(5):383-389. [pmid: 23547974].
9 Dirix P, et al. Intensity-modulated radiotherapy for sinonasal cancer: Improved outcome compared to conventional radiotherapy. International Journal of Radiation Oncology Biology Physics. 2010;78(4):998-1004.
10 Guan X, et al. Lymph node metastasis in sinonasal squamous cell carcinoma treated with IMRT/3D-CRT. Oral Oncology. 2013;49(1):60-65. [pmid: 22884302].
11 Kong M, et al. Comparison of survival rates between patients treated with conventional radiotherapy and helical tomotherapy for head and neck cancer. Radiation Oncology Journal. 2013;31(1):1-11. [pmid: 23620863].
12 Huang HI, et al. T4-locally advanced nasopharyngeal carcinoma: prognostic influence of cranial nerve involvement in different radiotherapy techniques. ScientificWorldJournal. 2013;2013:439073. [pmid: 24385882].
13 Lohia S, et al. A comparison of outcomes using intensity-modulated radiation therapy and 3-dimensional conformal radiation therapy in treatment of oropharyngeal cancer. JAMA Otolaryngol Head Neck Surg. 2014;140(4):331-7. [pmid: 24557509].
14 Mok G, et al. Outcomes of intensity-modulated radiotherapy versus conventional radiotherapy for hypopharyngeal cancer. Head Neck. 2014.
15 Ozyigit G, et al. A retrospective comparison of robotic stereotactic body radiotherapy and three-dimensional conformal radiotherapy for the reirradiation of locally recurrent nasopharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2011;81(4):e263-e268.