# Search Strategy

## PubMed Search Strategy

(“Head and Neck Neoplasms”[Mesh]

OR

((“Neoplasms”[Mesh] OR neoplasms [TIAB] OR tumor [TIAB] OR tumors [TIAB] OR tumour [TIAB] OR tumours [TIAB] OR cancer [TIAB] OR cancers [TIAB] OR adenocarcinoma [TIAB] OR carcinoma [TIAB])

AND

(larynx [TIAB] OR laryngeal [TIAB] OR supraglottic [TIAB] OR glottic [TIAB] OR subglottic [TIAB] OR pharynx [TIAB] OR pharyngeal [TIAB] OR hypopharynx [TIAB] OR hypopharyngeal [TIAB] OR hypo-pharynx [TIAB] OR hypo-pharyngeal [TIAB] OR oropharynx [TIAB] OR oropharyngeal [TIAB] OR oro-pharynx [TIAB] OR oro-pharyngeal [TIAB] OR nasopharynx [TIAB] OR nasopharyngeal [TIAB] OR naso-pharynx [TIAB] OR naso-pharyngeal [TIAB] OR lip [TIAB] OR lips [TIAB] OR oral [TIAB] OR paranasal [TIAB] OR para-nasal [TIAB] OR nasal [TIAB] OR sinus [TIAB] OR salivary [TIAB] OR parotid [TIAB]))

OR

“Neoplasms, Unknown Primary”[Mesh] OR “occult primary” [TIAB] OR “unknown primary” [TIAB])

AND

((“Radiotherapy, Conformal”[Mesh] OR “Radiotherapy, Intensity-Modulated”[Mesh] OR “Protons”[Mesh] OR IMRT [TIAB] OR 3dcrt [TIAB] OR “3D-CRT” [TIAB] OR “3-D CRT” [TIAB] OR “3D CRT” [TIAB] OR (intensity [TIAB] AND modulated [TIAB]) OR conformal [TIAB] OR proton [TIAB] OR protons [TIAB]) OR ((“Radiotherapy”[Mesh] OR “radiotherapy” [Subheading]) AND (3dcrt [TIAB] OR “3D-CRT” [TIAB] OR “3-D CRT” [TIAB] OR “3D CRT” [TIAB] OR (intensity [TIAB] AND modulated [TIAB]) OR conformal [TIAB] OR proton [TIAB] OR protons [TIAB])))

AND

Publication date from 2008/09/28 to 2013/04/04; Humans; English

(“Head and Neck Neoplasms”[Mesh]

OR

((“Neoplasms”[Mesh] OR neoplasms [TIAB] OR tumor [TIAB] OR tumors [TIAB] OR tumour [TIAB] OR tumours [TIAB] OR cancer [TIAB] OR cancers [TIAB] OR adenocarcinoma [TIAB] OR carcinoma [TIAB])

AND

(larynx [TIAB] OR laryngeal [TIAB] OR supraglottic [TIAB] OR glottic [TIAB] OR subglottic [TIAB] OR pharynx [TIAB] OR pharyngeal [TIAB] OR hypopharynx [TIAB] OR hypopharyngeal [TIAB] OR hypo-pharynx [TIAB] OR hypo-pharyngeal [TIAB] OR oropharynx [TIAB] OR oropharyngeal [TIAB] OR oro-pharynx [TIAB] OR oro-pharyngeal [TIAB] OR nasopharynx [TIAB] OR nasopharyngeal [TIAB] OR naso-pharynx [TIAB] OR naso-pharyngeal [TIAB] OR lip [TIAB] OR lips [TIAB] OR oral [TIAB] OR paranasal [TIAB] OR para-nasal [TIAB] OR nasal [TIAB] OR sinus [TIAB] OR salivary [TIAB] OR parotid [TIAB]))

OR

“Neoplasms, Unknown Primary”[Mesh] OR “occult primary” [TIAB] OR “unknown primary” [TIAB])

AND

“Brachytherapy”[Mesh] OR brachytherapy OR ((interstitial OR intracavitary OR implant OR surface) AND radiotherapy)

AND

Publication date from 1990/01/01 to 2013/04/04; Humans; English

(“Head and Neck Neoplasms”[Mesh]

OR

((“Neoplasms”[Mesh] OR neoplasms [TIAB] OR tumor [TIAB] OR tumors [TIAB] OR tumour [TIAB] OR tumours [TIAB] OR cancer [TIAB] OR cancers [TIAB] OR adenocarcinoma [TIAB] OR carcinoma [TIAB])

AND

(larynx [TIAB] OR laryngeal [TIAB] OR supraglottic [TIAB] OR glottic [TIAB] OR subglottic [TIAB] OR pharynx [TIAB] OR pharyngeal [TIAB] OR hypopharynx [TIAB] OR hypopharyngeal [TIAB] OR hypo-pharynx [TIAB] OR hypo-pharyngeal [TIAB] OR oropharynx [TIAB] OR oropharyngeal [TIAB] OR oro-pharynx [TIAB] OR oro-pharyngeal [TIAB] OR nasopharynx [TIAB] OR nasopharyngeal [TIAB] OR naso-pharynx [TIAB] OR naso-pharyngeal [TIAB] OR lip [TIAB] OR lips [TIAB] OR oral [TIAB] OR paranasal [TIAB] OR para-nasal [TIAB] OR nasal [TIAB] OR sinus [TIAB] OR salivary [TIAB] OR parotid [TIAB]))

OR

“Neoplasms, Unknown Primary”[Mesh] OR “occult primary” [TIAB] OR “unknown primary” [TIAB])

AND

(((“Radiosurgery”[Mesh]) OR “Stereotaxic Techniques”[Mesh] OR (stereotactic AND (radiosurgery OR radiotherapy)) OR SBRT OR tomotherapy OR tomotherapies))

AND

Publication date from 1990/01/01 to 2013/04/04; Humans; English

## EMBASE Search Strategy

(neoplasms:ti,ab OR tumor:ti,ab OR tumors:ti,ab OR tumour:ti,ab OR tumours:ti,ab OR cancer:ti,ab OR cancers:ti,ab OR adenocarcinoma:ti,ab OR carcinoma*:ti,ab)

AND

(larynx:ab,ti OR laryngeal:ab,ti OR supraglottic:ab,ti OR glottic:ab,ti OR subglottic:ab,ti OR pharynx:ab,ti OR pharyngeal:ab,ti OR hypopharynx:ab,ti OR hypopharyngeal:ab,ti OR ‘hypo pharynx’:ab,ti OR ‘hypo pharyngeal’:ab,ti OR oropharynx:ab,ti OR oropharyngeal:ab,ti OR ‘oro pharynx’:ab,ti OR ‘oro pharyngeal’:ab,ti OR nasopharynx:ab,ti OR nasopharyngeal:ab,ti OR ‘naso pharynx’:ab,ti OR ‘naso pharyngeal’:ab,ti OR lip:ab,ti OR lips:ab,ti OR oral:ab,ti OR paranasal:ab,ti OR ‘para nasal’:ab,ti OR nasal:ab,ti OR sinus:ab,ti OR ‘naso sinus’:ab,ti OR salivary:ab,ti OR parotid:ab,ti OR ‘occult primary’:ab,ti OR ‘unknown primary’:ab,ti) OR (‘head and neck’ AND (neoplasms:ab,ti OR tumor:ab,ti OR tumors:ab,ti OR tumour:ab,ti OR tumours:ab,ti OR cancer:ab,ti OR cancers:ab,ti OR adenocarcinoma:ab,ti OR carcinoma:ab,ti)

AND

(‘radiotherapy’/exp AND (3dcrt:ab,ti OR ‘3d-crt’:ab,ti OR ‘3-d crt’:ab,ti OR ‘3d crt’:ab,ti OR (intensity:ab,ti AND modulated:ab,ti) OR conformal:ab,ti OR proton:ab,ti OR protons:ab,ti) OR imrt:ab,ti OR 3dcrt:ab,ti OR ‘3d-crt’:ab,ti OR ‘3-d crt’:ab,ti OR ‘3d crt’:ab,ti OR (intensity:ab,ti AND modulated:ab,ti) OR conformal:ab,ti OR proton:ab,ti OR protons:ab,ti)

AND

[humans]/lim AND [english]/lim AND [embase]/lim AND [2008–2013]/py

(neoplasms:ti,ab OR tumor:ti,ab OR tumors:ti,ab OR tumour:ti,ab OR tumours:ti,ab OR cancer:ti,ab OR cancers:ti,ab OR adenocarcinoma:ti,ab OR carcinoma*:ti,ab)

AND

(larynx:ab,ti OR laryngeal:ab,ti OR supraglottic:ab,ti OR glottic:ab,ti OR subglottic:ab,ti OR pharynx:ab,ti OR pharyngeal:ab,ti OR hypopharynx:ab,ti OR hypopharyngeal:ab,ti OR ‘hypo pharynx’:ab,ti OR ‘hypo pharyngeal’:ab,ti OR oropharynx:ab,ti OR oropharyngeal:ab,ti OR ‘oro pharynx’:ab,ti OR ‘oro pharyngeal’:ab,ti OR nasopharynx:ab,ti OR nasopharyngeal:ab,ti OR ‘naso pharynx’:ab,ti OR ‘naso pharyngeal’:ab,ti OR lip:ab,ti OR lips:ab,ti OR oral:ab,ti OR paranasal:ab,ti OR ‘para nasal’:ab,ti OR nasal:ab,ti OR sinus:ab,ti OR ‘naso sinus’:ab,ti OR salivary:ab,ti OR parotid:ab,ti OR ‘occult primary’:ab,ti OR ‘unknown primary’:ab,ti) OR (‘head and neck’ AND (neoplasms:ab,ti OR tumor:ab,ti OR tumors:ab,ti OR tumour:ab,ti OR tumours:ab,ti OR cancer:ab,ti OR cancers:ab,ti OR adenocarcinoma:ab,ti OR carcinoma:ab,ti)

AND

‘brachytherapy’/exp OR ((interstitial OR intracavitary OR ‘implant’/exp OR ‘surface’/exp) AND ‘radiotherapy’/exp)

AND

[humans]/lim AND [english]/lim AND [embase]/lim AND [1990–2013]/py

(neoplasms:ti,ab OR tumor:ti,ab OR tumors:ti,ab OR tumour:ti,ab OR tumours:ti,ab OR cancer:ti,ab OR cancers:ti,ab OR adenocarcinoma:ti,ab OR carcinoma*:ti,ab)

AND

(larynx:ab,ti OR laryngeal:ab,ti OR supraglottic:ab,ti OR glottic:ab,ti OR subglottic:ab,ti OR pharynx:ab,ti OR pharyngeal:ab,ti OR hypopharynx:ab,ti OR hypopharyngeal:ab,ti OR ‘hypo pharynx’:ab,ti OR ‘hypo pharyngeal’:ab,ti OR oropharynx:ab,ti OR oropharyngeal:ab,ti OR ‘oro pharynx’:ab,ti OR ‘oro pharyngeal’:ab,ti OR nasopharynx:ab,ti OR nasopharyngeal:ab,ti OR ‘naso pharynx’:ab,ti OR ‘naso pharyngeal’:ab,ti OR lip:ab,ti OR lips:ab,ti OR oral:ab,ti OR paranasal:ab,ti OR ‘para nasal’:ab,ti OR nasal:ab,ti OR sinus:ab,ti OR ‘naso sinus’:ab,ti OR salivary:ab,ti OR parotid:ab,ti OR ‘occult primary’:ab,ti OR ‘unknown primary’:ab,ti) OR (‘head and neck’ AND (neoplasms:ab,ti OR tumor:ab,ti OR tumors:ab,ti OR tumour:ab,ti OR tumours:ab,ti OR cancer:ab,ti OR cancers:ab,ti OR adenocarcinoma:ab,ti OR carcinoma:ab,ti)

AND

‘stereotaxic techniques’/exp OR (stereotactic AND (‘radiosurgery’/exp OR ‘radiotherapy’/exp)) OR ‘sbrt’/exp OR ‘tomotherapy’/exp

AND

[humans]/lim AND [english]/lim AND [embase]/lim AND [1990–2013]/py