# Results

## Introduction

The bulk of the available evidence addresses diagnostic accuracy of imaging techniques for hepatocellular carcinoma (HCC)—ultrasound (US), computed tomography (CT), magnetic resonance imaging (MRI), and positron emission tomography (PET). Few studies compared effects of different imaging modalities or strategies on clinical decisionmaking, clinical outcomes, and almost no studies reported harms.

## Results of Literature Searches

The search and selection of articles are summarized in the study flow diagram (Figure 4). Of the 4846 citations identified at the title and abstract level, 851 articles appeared to meet inclusion criteria and were selected for further full-text review. Following review at the full-text level, a total of 281 studies met inclusion criteria (Appendix A); primary reasons for exclusion of the articles reviewed at the full-text level were (Appendix B). We rated three studies low risk of bias,42–44 189 moderate risk of bias, and 89 high risk of bias (Appendix C).

Figure 4 Study flow diagram

This figure is a flow chart that outlines study retrieval and selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria of the report. This figure is described further in the Section entitled “Results of Literature Searches” as follows: “Of the 4846 citations identified at the title and abstract level, 851 articles appeared to meet inclusion criteria and were selected for further full-text review. Following review at the full-text level, a total of 281 studies met inclusion criteria.” 281 studies were included in the quantitative analysis. The primary reasons for exclusion of studies were as follows: Wrong Population (n=160), Wrong Outcome (n=183), and Wrong Intervention (n=68). The additional 159 studies were excluded as Background (n=86), Systematic Review (n=11), Wrong Comparator (n=3), Wrong Setting (n=2), Wrong Study Design (n=6), Wrong Publication Type (n=6), Not English Language (n=7), Imaging Before 1995 (n=6), and Inadequate Reference Standard (n=32), for a total of 570 excluded studies.

Three cohort studies45–47 and three randomized trials reported patient outcomes of imaging for staging.48–50 We identified 274 studies that evaluated diagnostic accuracy of imaging tests.

Of the diagnostic accuracy studies, 70 evaluated US (Appendix D),43,51–119 134 evaluated CT (Appendix E),42–44,51,53–56,58,60–62,66,69,74,75,81,82,87,89,91,92,96,99,101–103,110–112,117–220 129 evaluated MRI (Appendix F),43,44,51,56,59,61,65,69,74,75,82,99,100,103,105,106,108,110,118,121,123,126,129,131,134–136,138,140,141,144,145,150,158,163,164,166,168,176,179,184,190,191,193,195,198,200,203,206,207,209,211,212,218,221–295 and 32 evaluated PET (Appendix G).110,111,127,152,154,171,189,296–320 Twenty-eight studies evaluated use of more than one imaging technique in combination or sequentially.43,44,51,55,59,61,69,75,79,96,127,134,152,171,189,296,297,300,302,305,309,310,312–314,317,320,321 Almost all studies reported sensitivity, but only 130 reported specificity or provided data to calculate specificity. We found 119 studies avoided use of a case-control design, 151 used blinded ascertainment, and 75 used a prospective design. More studies were conducted in Asia (182 studies) than in Australia, Canada, the United States or Europe combined (92 studies). In 155 studies, imaging was conducted starting in or after 2003.

Twenty-seven studies evaluated CT using methods that met minimum technical specifications (≥8-row multidetector CT; contrast rate ≥3 ml/s; at least arterial, portal venous, and delayed phase imaging; delayed phase imaging performed >120 s following administration of contrast; and enhanced imaging section thickness ≤5 mm)42,43,56,69,75,87,92,96,131,135,141,147,158,162–164,168,177,178,183,184,195,200,206,210,212,215 and 59 studies evaluated MRI using methods that met minimum technical specifications (1.5 or 3.0 T MRI; at least arterial, portal venous, and delayed phase imaging; delayed phase imaging performed >120 s following administration of contrast; and enhanced imaging section thickness ≤5 mm).43,56,59,69,74,105,106,121,123,131,134,135,141,145,150,158,162,163,168,184,191,195,198,203,206,207,212,221,223–225,227,231,232,238,241,243–256,262–265,271,272,274,278,282 Sixty-three MRI studies evaluated use of hepatic-specific contrast (e.g., gadoxetic acid or gadobenate).43,51,56,65,69,74,75,79,105,106,108,121,123,131,135,136,141,144,145,150,158,163,168,184,191,195,203,206,207,212,221–225,227,230–232,241,242,244,246–251,253–255,264,265,269–272,274,278,282,287,295,321 Forty-six US studies evaluated use of microbubble contrast agents.43,51,53,55,57–60,63,65–69,71,73–75,78,79,81,85–89,91–93,95–98,100,101,104–109,113–117 30 studies evaluated PET using FDG,110,111,127,152,154,171,189,296–298,300–305,307–320 eight studies using ^11^C-acetate,127,297,300–302,306,309,319 and three studies evaluated use of other tracers (^18^F-fluorothymidine or ^18^F-fluorocholine).299,313,314

Data for outcomes other than measures of test performance were sparse. Eight studies reported comparative effects on clinical decisionmaking,82,102,122,127,179,202,208,322 four studies reported comparative clinical and patient-centered outcomes,48–50,322 and three studies reported harms associated with imaging for HCC.91,144,204

## Key Question 1 What is the comparative effectiveness of available imaging-based strategies, used singly or in sequence, for detection of HCC among individuals in surveillance and nonsurveillance settings?

### Description of Included Studies

Six studies54,62,90,94,103,112 evaluated diagnostic accuracy of imaging techniques for surveillance and 182 studies42,51,52,56,61,64,67,69–71,74,76–79,82–84,92,99,106,110,111,118–121,123–127,129–133,135–141,143–146,148–151,153–155,157–170,172–180,182–188,190–205,207–212,215–227,234–238,241,244,246,248–252,254–264,267,268,270,271,273–277,280,281,283–286,288,290,292,294,295,297,299,301–303,306–310,313–319,321 reported diagnostic accuracy in nonsurveillance settings (e.g., imaging performed to assess detection rates in a series of patients undergoing treatment for HCC or patients with otherwise known prevalence of HCC prior to imaging). Four studies of PET evaluated accuracy specifically for identification of recurrent HCC.296,305,312,318

One randomized trial (rated high risk of bias)50 evaluated clinical outcomes associated with imaging-based surveillance versus no screening, and two trials48,49 evaluated clinical outcomes associated with different US surveillance intervals. One study compared effects of different imaging surveillance strategies on diagnostic thinking or clinical decisionmaking.322 Two studies reported harms associated with imaging for HCC.144,204

### Key Points

#### Test Performance

- In surveillance settings, using patients with HCC as the unit of analysis:
  ○ US without contrast: Sensitivity was 0.78 (95% CI 0.60 to 0.89, 4 studies) and specificity was 0.89 (95% CI 0.80 to 0.94, 3 studies), for a LR+ of 6.8 (95% CI 4.2 to 11) and LR− of 0.25 (0.13 to 0.46). (Strength of Evidence: low for sensitivity and specificity)
  ○ CT: Sensitivity was 0.84 (95% CI 0.59 to 0.95, 2 studies) and specificity 0.99 (95% CI 0.86 to 0.999, 2 studies), for a LR+ of 60 (95% CI 5.9 to 622) and LR− of 0.16 (0.06 to 0.47). (Strength of Evidence: low for sensitivity and specificity).
  ○ MRI and PET were not evaluated in surveillance settings. (Strength of Evidence: insufficient)
- In surveillance settings, using HCC lesions as the unit of analysis:
  ○ US without contrast: Sensitivity was 0.60 (95% CI 0.24 to 0.87, 1 study); specificity was not reported. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ CT: Sensitivity was 0.62 (95% CI 0.46 to 0.76, 1 study). (Strength of Evidence: low for sensitivity, insufficient for specificity).
- In nonsurveillance settings (e.g., imaging performed in patients who underwent liver transplantation or resection, or in patients in whom the prevalence of HCC is already known), using patients with HCC as the unit of analysis:
  ○ US without contrast: Sensitivity was 0.73 (95% CI 0.46 to 0.90, 8 studies) and specificity was 0.93 (95% CI 0.85 to 0.97, 6 studies), for a LR+ of 11 (95% CI 5.4 to 21) and LR− of 0.29 (95% CI 0.13 to 0.65). (Strength of Evidence: low for sensitivity and specificity)
  ○ CT: Sensitivity was 0.83 (95% CI 0.75 to 0.89, 16 studies) and specificity was 0.92 (95% CI 0.86 to 0.96, 11 studies), for a LR+ of 11 (95% CI 5.6 to 20) and LR− of 0.19 (95% CI 0.12 to 0.28). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ MRI: Sensitivity was 0.85 (95% CI 0.76 to 0.91, 10 studies) and specificity was 0.90 (95% CI 0.81 to 0.94, 8 studies), for a LR+ of 8.1 (95% CI 4.3 to 15) and LR− of 0.17 (95% CI 0.10 to 0.28). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ PET: For FDG PET, sensitivity was 0.52 (95% CI 0.39 to 0.66, 15 studies) and specificity was 0.95 (95% CI 0.82 to 0.99, 5 studies), for a LR+ of 11 (95% CI 2.6 to 49) and LR− of 0.50 (95% CI 0.37 to 0.68). For ^11^C-acetate PET or PET/CT, sensitivity was 0.85 (95% CI 0.67 to 0.94, 4 studies); specificity was not reported. (Strength of Evidence: moderate for sensitivity, low for specificity)
- In nonsurveillance settings, using HCC lesions as the unit of analysis:
  ○ US without contrast: Sensitivity was 0.59 (95% CI 0.42 to 0.74, 11 studies). Only two studies reported specificity, with inconsistent results (0.63, 95% CI 0.53 to 0.73, and 0.95, 95% CI 0.85 to 0.99). (Strength of Evidence: moderate for sensitivity and low for specificity)
  ○ US with contrast: Sensitivity was 0.73 (95% CI 0.52 to 0.87, 8 studies). No study evaluated specificity. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ CT: Sensitivity was 0.77 (95% CI 0.72 to 0.80, 79 studies) and specificity was 0.89 (95% CI 0.84 to 0.93, 21 studies), for a LR+ of 7.1 (95% CI 4.7 to 11) and LR− of 0.26 (95% CI 0.22 to 0.31). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ MRI: Sensitivity was 0.82 (95% CI 0.79 to 0.85, 75 studies) and specificity was 0.87 (95% CI 0.77 to −0.93, 16 studies), for a LR+ of 6.4 (95% CI 3.5 to 12) and LR− of 0.20 (95% CI 0.16 to 0.25). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ PET: For FDG PET, sensitivity was 0.53 (95% CI 0.41 to 0.65, 5 studies) and specificity was 0.91 (95% CI 0.76 to 0.98, 1 study). For ^11^C-acetate PET, sensitivity was 0.78 (95% CI 0.61 to 0.89, 4 studies); specificity was not reported. (Strength of Evidence: moderate for sensitivity, low for specificity)
- Direct (within-study) comparisons of imaging modalities, using patients with HCC as the unit of analysis:
  ○ US without contrast versus CT: Sensitivity was 0.68 (95% CI 0.54 to 0.80) versus 0.80 (95% CI 0.68 to 0.88), for a difference of −0.12 (95% CI −0.20 to −0.03), based on six studies. Two studies were performed in surveillance settings and rated as low strength of evidence for sensitivity and specificity. (Strength of Evidence: moderate for sensitivity and specificity for the 6 studies)
  ○ US without contrast versus MRI: Sensitivity was 0.61 (95% CI 0.48 to 0.74) versus 0.81 (95% CI 0.69 to 0.89), for a difference of −0.19 (95% CI −0.30 to −0.08), based on three studies, none of which were performed in surveillance settings. (Strength of Evidence: moderate for sensitivity and specificity)
  ○ MRI versus CT: Sensitivity was 0.88 (95% CI 0.53 to 0.98) versus 0.82 (95% CI 0.41 to 0.97), for a difference of 0.06 (95% CI −0.05 to 0.17), based on four studies, none of which were performed in surveillance settings. (Strength of Evidence: moderate for sensitivity and specificity)
- Direct (within-study) comparisons of imaging modalities, using HCC lesions as the unit of analysis (no study performed in a surveillance setting):
  ○ US without contrast versus CT: Sensitivity was 0.55 (95% CI 0.43 to 0.66) versus 0.66 (95% CI 0.54 to 0.76) for a difference of −0.11 (95% CI −0.18 to −0.04), based on three studies. (Strength of Evidence: moderate for sensitivity and specificity)
  ○ US without contrast versus MRI: Sensitivity was 0.57 (95% CI 0.42 to 0.71) versus 0.79 (95% CI 0.67 to 0.88), for a difference of −0.22 (95% −0.31 to −0.14), based on three studies. (Strength of Evidence: moderate for sensitivity and specificity)
  ○ US with contrast versus CT: Sensitivity was 0.51 (95% CI 0.29 to 0.74) versus 0.61 (95% CI 0.38 to 0.81), for a difference of −0.10 (95% CI −0.20 to 0.00), based on four studies. (Strength of Evidence: moderate for sensitivity, insufficient for specificity)
  ○ US with contrast versus MRI: Sensitivity was 0.65 (95% CI 0.41 to 0.84) versus 0.73 (95% CI 0.50 to 0.88), for a difference of −0.08 (95% CI −0.19 to 0.02), based on 3 studies. (Strength of Evidence: moderate for sensitivity, insufficient for specificity)
  ○ MRI versus CT: Sensitivity was 0.81 (95% CI 0.76 to 0.84) versus 0.71 (95% CI 0.66 to 0.76), for a difference of 0.09 (95% CI 0.07 to 0.12), based on 31 studies. Findings were similar when studies were stratified according to use of nonhepatic-specific or hepatic-specific contrast, and when the analysis was restricted to HCC lesions <2–3 cm. For HCC lesions <2–3 cm, the difference in sensitivity was greater for studies of hepatic-specific MRI contrast (0.23, 95% CI 0.17 to 0.29, 12 studies) than for studies of non-hepatic specific MRI contrast (0.06, 95% CI −0.01 to 0.13, 6 studies). (Strength of Evidence: moderate for sensitivity and specificity)
- Multiple imaging modalities
  ○ One study found sensitivity of imaging with various combinations of two imaging modalities was similar or lower than single modality imaging, based on concordant positive findings on two imaging modalities. The other study reported higher sensitivity with multiple imaging modalities than with single modality imaging, but criteria for positive results based on multiple imaging modalities were unclear. (Strength of Evidence: low for sensitivity and insufficient for specificity)
- Sensitivity of US, CT, and MRI was lower in studies that used explanted liver as the reference standard than in studies that used other histopathological reference standards, clinical or imaging criteria, or a mixed reference standard.
  ○ US without contrast: Using HCC lesions as the unit of analysis, sensitivity was 0.34 (95% CI 0.22 to 0.47) in 5 studies that used explanted liver as the reference standard and ranged from 0.72 to 0.75 in studies that used other reference standards. (Strength of Evidence: moderate for sensitivity, insufficient for specificity)
  ○ US with contrast: No study using HCC lesions as the unit of analysis used an explanted liver reference standard. Sensitivity was 0.58 (95% CI 0.39 to 0.75) using a nonexplant histopathological reference standard and 0.98 (95% CI 0.88 to 0.997) using a mixed reference standard. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ CT: Using HCC lesions as the unit of analysis, sensitivity was 0.67 (95% CI 0.59 to 0.75) in 23 studies that used explanted liver as the reference standard and ranged 0.65 to 0.86 in studies that used other reference standards. (Strength of Evidence: moderate for sensitivity and specificity).
  ○ MRI: Using HCC lesions as the unit of analysis, sensitivity was 0.69 (95% CI 0.60 to 0.76) in 18 studies that used explanted liver as the reference standard and ranged from 0.86 to 0.88 in studies that used a nonexplant histopathological reference standard or mixed reference standard; only three studies evaluated an imaging/clinical reference standard (sensitivity 0.65, 95% CI 0.43 to 0.83). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ PET: No study of FDG PET used an explanted liver reference standard. Four of the five studies that used HCC lesions as the unit of analysis used a nonexplant histological reference standard (sensitivity 0.49, 95% CI 0.37 to 0.61). Specificity was reported in too few studies to draw strong conclusions. (Strength of Evidence: low for sensitivity, insufficient for specificity)
- Across imaging modalities, based on within-study comparisons, sensitivity increased as HCC lesion size increased.
  ○ US without contrast: Sensitivity was 0.82 (95% CI 0.68 to 0.91) for lesions ≥2 cm and 0.34 (95% CI 0.19 to 0.53) for lesions <2 cm, for a difference o 0.48 (95% CI 0.39 to 0.57). Sensitivity was 0.09 (95% CI 0.02 to 0.29, 4 studies) for lesions <10 mm, 0.50 (95% CI 0.23 to 0.78, 4 studies) for lesions 10–20 mm and 0.88 (95% CI 0.66 to 0.96, 4 studies) for lesions >20 mm, for a difference of 0.37 (95% CI 0.18 to 0.57) for lesions >20 mm versus 10–20 mm, and 0.41 (95% CI 0.19 to 0.63) for lesions 10–20 mm versus <10 mm. (Strength of Evidence: moderate for sensitivity, low for specificity)
  ○ US with contrast: Sensitivity was 0.94 (95% CI 0.83 to 0.98) for lesions ≥2 cm and 0.77 (95% CI 0.53 to 0.91) for lesions <2 cm for a difference of 0.17 (95% CI 0.03 to 0.32), based on 5 studies. Three studies found sensitivity of 0.64 (95% CI 0.33 to 0.87) for lesions 10–20 mm and 0.91 (95% CI 0.71 to 0.98) for lesions >20 mm, for a difference of 0.26 (95% CI 0.04 to 0.48). (Strength of Evidence: low for sensitivity and specificity)
  ○ CT: Sensitivity was 0.94 (95% CI 0.92 to 0.95) for lesions ≥2 cm and 0.63 (95% CI 0.57 to 0.69) for lesions <2 cm, for an absolute difference in sensitivity of 0.31 (95% CI 0.26 to 0.36), based on 34 studies. Sensitivity was 0.32 (95% CI 0.25 to 0.41, 21 studies) for lesions <10 mm, 0.74 (95% CI 0.67 to 0.80, 23 studies) for lesions 10–20 mm, and 0.95 (95% CI 0.92 to 0.97, 20 studies), for a difference of 0.21 (95% CI 0.15 to 0.26) for lesions >20 versus 10–20 mm and 0.42 (95% CI 0.36 to 0.48) for lesions 10–20 versus <10 mm. (Strength of Evidence: moderate for sensitivity, low for specificity)
  ○ MRI: Sensitivity was 0.96 (95% CI 0.93 to 0.97) for lesions ≥2 cm and 0.66 (95% CI 0.58 to 0.74) for lesions <2 cm, for an absolute difference in sensitivity of 0.29 (95% CI 0.23 to 0.36), based on 29 studies. Sensitivity was 0.45 (95% CI 0.34 to 0.56, 20 studies) for lesions <10 mm, 0.78 (95% CI 0.69 to 0.85, 21 studies) for lesions 10–20 mm, and 0.97 (95% CI 0.94 to 0.98, 14 studies) for lesions >20 mm (0.97, 95% CI 0.94 to 0.98, 18 studies), for a difference of 0.19 (95% CI 0.12 to 0.26) for >20 versus 10–20 mm and 0.33 (95% CI 0.26 to 0.40) for 10–20 versus <10 mm. (Strength of Evidence: moderate for sensitivity and specificity)
  ○ PET: For FDG PET, sensitivity was consistently higher for larger lesions, based on five studies. Data were not pooled due to differences in the tumor size categories evaluated. Two studies of ^11^C-acetatate PET found inconsistent effects of lesion size on sensitivity. (Strength of Evidence: low for sensitivity, insufficient for specificity)
- Across imaging modalities, based on within-study comparisons, sensitivity was higher for moderately or poorly differentiated HCC lesions than for well-differentiated HCC lesions.
  ○ US with contrast: Sensitivity was 0.83 (95% CI 0.55 to 0.95) for moderately- or poorly-differentiated HCC lesions and 0.43 (95% CI 0.15 to 0.76) for well-differentiated lesions, for an absolute difference in sensitivity of 0.40 (95% CI 0.17 to 0.64), based on three studies. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ CT: Sensitivity was 0.82 (95% CI 0.66 to 0.91) for moderately- or poorly-differentiated HCC lesions and 0.50 (95% CI 0.29 to 0.70) for well-differentiated lesions, for an absolute difference in sensitivity of 0.32 (95% CI 0.19 to 0.45), based on five studies. (Strength of Evidence: low for sensitivity, insufficient for specificity).
  ○ MRI: Sensitivity was 0.68 (95% CI 0.44 to 0.86) for moderately- or poorly-differentiated HCC lesions and 0.37 (95% CI 0.17 to 0.62) for well-differentiated lesions, for an absolute difference in sensitivity of 0.31 (95% CI 0.13 to 0.49), based on three studies. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ PET: For FDG PET, sensitivity was 0.72 (95% CI 0.59 to 0.83) for moderately- or poorly-differentiated HCC lesions and 0.39 (95% CI 0.26 to 0.55) for well differentiated lesions, for an absolute difference in sensitivity of 0.33 (95% CI 0.20 to 0.46), based on six studies. In three studies of ^11^C-acetate PET and one study of ^18^F-fluorochlorine, sensitivity for more well-differentiated lesions was not lower than for more poorly-differentiated lesions. (Strength of Evidence: low for sensitivity, insufficient for specificity)
- Effects of other factors on estimates of test performance
  ○ US: In two studies that directly compared US with contrast versus without contrast, there was no clear difference in sensitivity (−0.04, 95% CI −0.11 to 0.04). One study that directly compared use of Doppler versus no Doppler showed no clear effect on estimates of sensitivity. Lesion depth and body mass index had no effect on estimates of sensitivity. (Strength of Evidence: low)
  ○ CT: Using patients with HCC as the unit of analysis, studies with a contrast rate ≥3 ml/s reported a higher sensitivity (0.87, 95% CI 0.77 to 0.93, 8 studies) than studies with a contrast rate <3 ml/s (0.71, 95% CI 0.50 to 0.85, 4 studies). Studies with delayed phase imaging reported somewhat higher sensitivity (0.89, 95% CI 0.81 to 0.94, 7 studies) than studies without delayed phase imaging (0.74, 95% CI 0.66 to 0.87, 7 studies). However, both of these technical parameters had no clear effects in studies that used HCC lesions as the unit of analysis. (Strength of Evidence: low)
  ○ MRI: There were no clear differences in estimates of diagnostic accuracy when studies were stratified according to MRI scanner type (1.5 vs. 3.0 T), imaging phases evaluated (with or without delayed phase imaging), timing of delayed phase imaging (>120 seconds vs. <120 seconds), section thickness (≤5 mm for enhanced images vs. >5 mm), or use of diffusion-weighted imaging. In studies that directly compared diagnostic accuracy with different types of contrast, hepatic-specific contrast agents (gadoxetic acid or gadobenate) were associated with slightly higher sensitivity than nonhepatic-specific contrast agents (gadopentetate or gadodiamide) (0.83, 95% CI 0.75 to 0.90 vs. 0.74, 95% CI 0.62 to 0.83, difference 0.10, 95% CI 0.04 to 0.15, 6 studies). (Strength of Evidence: low)
  ○ PET: FDG PET was associated with lower sensitivity that ^11^C-acetate PET when either patients (0.58 vs. 0.81, for a difference of −0.23, 95% CI −0.34 to −0.13, 3 studies) or HCC lesions (0.52 vs. 0.79, for a difference of −0.27, 95% CI −0.36 to −0.17, 3 studies) were the unit of analysis. FDG PET was also associated with lower sensitivity than dual tracer PET with FDG and ^11^C-acetate or ^18^F-choline PET, but evidence was limited to 1 or 2 studies for each of these comparisons. Using patients as the unit of analysis, sensitivity of FDG PET (0.39, 95% CI 0.24 to 0.56, 8 studies) was lower than sensitivity of FDG PET/CT (0.65, 95% CI 0.50 to 0.78, 7 studies). (Strength of Evidence: low)

#### Clinical Decisionmaking

- One randomized controlled trial (n=163) found no clear differences between surveillance with US without contrast versus CT in HCC detection rates, subsequent imaging, or cost per HCC detected. (Strength of Evidence: low)

#### Clinical and Patient-Centered Outcomes

- One cluster randomized controlled trial (n=18,816) conducted in China found screening every 6 months with noncontrast US plus serum AFP versus no screening in persons 35 to 79 years of age (mean 42 years) with HBV infection or chronic hepatitis without HBV infection associated with lower risk of HCC-related mortality (32 vs. 54 deaths, rate ratio 0.63, 95% CI 0.41 to 0.98) at 5-year followup, but was rated high risk of bias due to multiple methodological shortcomings. (Strength of Evidence: low)
- Two trials found no clear differences in mortality with US screening at 4-month versus 12-month intervals, or at 3-month versus 6-month intervals. One trial found no difference in HCC mortality between surveillance with US without contrast versus CT, but was underpowered to detect differences. (Strength of Evidence: moderate)

#### Harms

- One study reported no serious adverse events associated with administration of gadoxetic acid for MRI and one study reported no clear differences in adverse events between CT with contrast at 3 ml/s versus 5 ml/s. No study reported rates of adverse events associated with use of microbubble contrast agents in US, and harms were not reported in randomized trials of screening with imaging. (Strength of Evidence: insufficient)

### Detailed Synthesis

#### KQ1.a What is the comparative test performance of imaging-based strategies for detecting HCC?

##### Ultrasound

In surveillance settings, using patients with HCC as the unit of analysis, sensitivity of US without contrast was 0.78 (95% CI 0.60 to 0.89, 4 studies) and specificity was 0.89 (95% CI 0.80 to 0.94, 3 studies), for a LR+ of 6.8 (95% CI 4.2 to 11) and LR− of 0.25 (0.13 to 0.46) (Figure 5; Appendix D).54,90,94,112 Using HCC lesions as the unit of analysis, sensitivity was 0.60 (95% CI 0.24 to 0.87) in one study; specificity was not reported.62

Figure 5 Test performance of ultrasound without contrast for detection of patients with hepatocellular carcinoma in surveillance settings

This figure is a forest plot that displays the test performance of ultrasound without contrast for detection of patients with hepatocellular carcinoma in surveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 4 studies, with a combined sensitivity of 0.78 (95% confidence interval: 0.60 to 0.89) and the tau-squared value is 0.52, p = 0.108. Specificity was reported or calculated for 3 studies, with a combined specificity of 0.89 (95% confidence interval: 0.80 to 0.94) and the tau-squared value is 0.26, p = 0.164.

In nonsurveillance settings, using patients with HCC as the unit of analysis, the sensitivity of US without contrast was 0.73 (95% CI 0.46 to 0.90, 8 studies) and specificity was 0.93 (95% CI 0.85 to 0.97, 6 studies), for a LR+ of 11 (95% CI 5.4 to 21) and LR− of 0.29 (95% CI 0.13 to 0.65) (Figure 6).52,64,76,82,83,110,111,118 Restricting the analysis to studies that avoided a case-control design resulted in lower sensitivity (0.54, 95% CI 0.38 to 0.70, 6 studies). Other sensitivity analyses had little effect on estimates (e.g., restricted to studies conducted in United States and Europe, excluded high risk of bias studies, or restricted to studies with blinded interpretation of imaging) or resulted in imprecise estimates due to small numbers of studies (analysis restricted to prospective studies).

Figure 6 Test performance of ultrasound without contrast for detection of patients with hepatocellular carcinoma in nonsurveillance settings

This figure is a forest plot that displays the test performance for studies of ultrasound without contrast for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 6 studies, with a combined sensitivity of 0.73 (95% confidence interval: 0.46 to 0.024) and the tau-squared value is 2.35, p = 0.24. Specificity was reported or calculated for 6 studies, with a combined specificity of 0.93 (95% confidence interval: 0.85 to 0.97) and the tau-squared value is 0.78, p = 0.123.

Using HCC lesions as the unit of analysis, the sensitivity of US without contrast was 0.59 (95% CI 0.42 to 0.74, 11 studies) and specificity 0.83 (95% CI 0.53 to 0.95, 2 studies), for a LR+ of 3.4 (95% C I 1.2 to 9.4) and LR− of 0.50 (95% CI 0.37 to 0.66) (Figure 7).52,56,70,76,77,79,83,84,99,111,118 Only two studies reported specificity, with inconsistent results (0.63, 95% CI 0.52 to 0.73^56^ and 0.95, 95% CI 0.85 to 0.99^99^). Excluding two studies77,79 restricted to HCC lesions <2–3 cm resulted in similar estimates (Table 6). Sensitivity was higher in studies that used a prospective design (0.78, 95% CI 0.55 to 0.91, 3 studies), but confidence intervals were wide. Other sensitivity analyses had little effect on estimates (Table 6).

Figure 7 Sensitivity of ultrasound without contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings

This figure is a forest plot that displays the sensitivity for studies of ultrasound without contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings. A solid vertical line on the graph corresponds to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. An overall mixed-effects model was based on 8 studies, with a value of 0.73 (95% confidence interval: 0.52 to 0.87).

Table 6 Test performance of ultrasound imaging for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of HCC (KQ 1)
Surveillance settings
Ultrasound without contrast | Patient | 0.78 (0.60 to 0.89); 0.52 (p=0.11) | 4 | 0.89 (0.80 to 0.94); 0.26 (p=0.16) | 3 | 6.8 (4.2 to 11) | 0.25 (0.13 to 0.46)
| Lesion | 0.60 (0.24 to 0.87) | 1 | No data | -- | -- | --
Nonsurveillance settings
Ultrasound without contrast | Patient | 0.73 (0.46 to 0.90); 2.3 (p=0.02) | 8 | 0.93 (0.85 to 0.97); 0.78 (p=0.12) | 6 | 11 (5.4 to 21) | 0.29 (0.13 to 0.65)
- Excluding Doppler | | 0.77 (0.48 to 0.93); 2.5 (p=0.04) | 7 | 0.92 (0.82 to 0.97); 0.70 (p=0.14) | 5 | 9.8 (4.7 to 21) | 0.25 (0.09 to 0.64)
- Prospective design | | 0.97 (0.68 to 0.998); 1.3 (p=0.02) | 2 | 0.73 (0.45 to 0.90) | 1 | 3.6 (1.5 to 8.5) | 0.04 (0.003 to 0.59)
- Reference standard: Explanted liver | | 0.48 (0.35 to 0.61); 0.17 (p=0.08) | 5 | 0.96 (0.94 to 0.97); <0.0001 (p=0.97) | 5 | 12 (7.4 to 19) | 0.54 (0.42 to 0.70)
- Reference standard: Histopathological, non-explant | | 0.95 (0.87 to 0.98) | 3 | 0.73 (0.47 to 0.90) | 1 | 3.6 (1.5 to 8.2) | 0.07 (0.03 to 0.19)
- United States or Europe | | 0.70 (0.37 to 0.91); 1.9 (p=0.02) | 5 | 0.93 (0.84 to 0.97); 0.51 (p=0.13) | 4 | 10 (4.9 to 21) | 0.32 (0.12 to 0.83)
- Excluding poor quality studies | | 0.77 (0.48 to 0.93); 2.5 (p=0.04) | 7 | 0.92 (0.82 to 0.97); 0.70 (p=0.14) | 5 | 9.8 (4.7 to 21) | 0.25 (0.09 to 0.64)
- Avoided case-control design | | 0.54 (0.38 to 0.70); 0.44 (p=0.09) | 6 | 0.95 (0.91 to 0.97); 0.41 (p=0.16) | 6 | 11 (6.1 to 19) | 0.48 (0.34 to 0.68
- Blinded interpretation of imaging | | 0.75 (0.33 to 0.95); 2.0 (p=0.02) | 3 | 0.94 (0.81 to 0.98); 0.51 (p=0.13) | 2 | 12 (4.4 to 33) | 0.27 (0.07 to 0.97)
| Lesion | 0.59 (0.42 to 0.74); 1.2 (p=0.005) | 11 | 0.83 (0.53 to 0.95); 3.4 (p=0.07) | 2 | 3.4 (1.2 to 9.4) | 0.50 (0.37 to 0.66)
- HCC lesions <2–3 cm | | 0.75 (0.72 to 0.78); <0.0001 (p=1.0) | 2 | No data | -- | -- | --
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.54 (0.35 to 0.73); 1.3 (p=0.01) | 9 | 0.86 (0.55 to 0.97); 3.5 (p=0.09) | 2 | 4.0 (1.2 to 13) | 0.53 (0.38 to 0.73)
- Excluding Doppler | | 0.50 (0.30 to 0.71); 1.2 (p=0.02) | 7 | 0.95 (95% CI 0.85 to 0.99) | 1 | Not calculated | Not calculated
- Reference standard: Explanted liver | | 0.34 (0.22 to 0.47); 0.28 (p=0.06) | 5 | Insufficient data | -- | -- | --
- Reference standard: Histopathological, non-explant | | 0.75 (0.58 to 0.86) | 3 | Insufficient data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical criteria | | 0.72 (0.46 to 0.88) | 1 | Insufficient data | -- | -- | --
- Prospective | | 0.78 (0.55 to 0.91); 0.61 (p=0.02) | 3 | Insufficient data | -- | -- | --
- U.S. or Europe | | 0.66 (0.35 to 0.87); 1.3 (p=0.01) | 4 | Insufficient data | -- | -- | --
- Avoided case-control design | | 0.43 (0.22 to 0.68); 1.2 (p=0.01) | 5 | Insufficient data | -- | -- | --
- Blinded interpretation of imaging | | 0.67 (0.44 to 0.84); 1.0 (p=0.02) | 5 | Insufficient data | -- | -- | --
Ultrasound with contrast | Lesion | 0.73 (0.52 to 0.87); 1.6 (p=0.01) | 8 | No data | -- | -- | --
- All HCC lesions <2–3 cm | | 0.63 (0.35 to 0.84); 0.89 (p=0.16) | 3 | No data | -- | -- | --
- No Doppler | | 0.78 (0.50 to 0.92); 1.9 (p=0.05) | 5 | No data | -- | -- | --
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.78 (0.50 to 0.92); 1.9 (p=0.05) | 5 | No data | -- | -- | --
- Contrast: Perflubutane | | 0.85 (0.65 to 0.94); 1.1 (p=0.11) | 4 | No data | -- | -- | --
- Reference standard: Histopathological, non-explant | | 066 (0.47 to 0.81); 0.58 (p=0.06) | 4 | No data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.98 (0.86 to 0.998) | 1 | No data | -- | -- | --
- Prospective | | 0.34 (95% CI 0.11 to 0.68); 0.48 (p=0.10) | 1 | No data | -- | -- | --
- United States or Europe | | 0.34 (95% CI 0.08 to 0.75); 0.76 (p=0.08) | 1 | No data | -- | -- | --
- Excluding high risk of bias studies | | 0.66 (0.33 to 0.88); 1.4 (p=0.05) | 3 | No data | -- | -- | --
- Avoided case-control design | | No data | 0 | No data | -- | -- | --
- Blinded interpretation of imaging | | 0.80 (0.50 to 0.94); 1.8 (p=0.05) | 4 | No data | -- | -- | --
| Liver segment | 0.79 (0.62 to 0.89); 1.6 (p=0.0006) | 2 | 0.95 (0.84 to 0.99); 0.74 (p=0.04) | 2 | 17 (4.7 to 60) | 0.22 (0.12 to 0.42)
Evaluation of focal liver lesions (KQ 2)
Ultrasound without contrast | Patient | 0.78 (0.69 to 0.86) | 1 | No data | -- | -- | --
Ultrasound with contrast | Patient | 0.87 (0.79 to 0.92); 0.59 (p=0.005) | 12 | 0.91 (0.83 to 0.95); 0.62 (p=0.04) | 8 | 9.6 (5.1 to 18) | 0.14 (0.09 to 0.23)
- HCC lesions <2–3 cm | | 0.79 (0.56 to 0.92); 0.90 (p=0.18) | 4 | 0.91 (0.74 to 0.97); 0.88 (p=0.26) | 4 | 8.6 (2.9 to 26) | 0.23 (0.10 to 0.53)
- Excluding Doppler | | 0.90 (0.85 to 0.93); 0.02 (p=0.60) | 6 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 10 (5.0 to 21) | 0.11 (0.07 to 0.16)
- Excluding studies restricted to hypervascular HCC | | 0.87 (0.78 to 0.92); 0.65 (p=0.007) | 11 | 0.91 (0.83 to 0.95); 0.62 (p=0.04) | 8 | 9.6 (5.1 to 18) | 0.15 (0.09 to 0.25)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.90 (0.86 to 0.93); 0.02 (p=0.76) | 8 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 10 (5.0 to 21) | 0.11 (0.08 to 0.16)
- Contrast: sulfur hexafluoride | | 0.87 (0.82 to 0.91); 0.02 (p=0.59) | 6 | 0.92 (0.78 to 0.97); 0.42 (p=0.10) | 2 | 11 (3.7 to 31) | 0.14 (0.10 to 0.20)
- Contrast: perflubutane | | 0.95 (0.89 to 0.97) | 2 | 0.92 (0.78 to 0.97) | 2 | 12 (3.9 to 35) | 0.06 (0.03 to 0.13)
- Reference standard: Histopathological, non-explant | | 0.91 (0.84 to 0.95); 0.06 (p=0.39) | 4 | 0.87 (0.61 to 0.97); 0.41 (p=0.09) | 1 | 7.0 (1.9 to 25) | 0.11 (0.06 to 0.20)
- Reference standard: Mixed histological and imaging/clinical criteria | | 0.89 (0.83 to 0.93) | 4 | 0.93 (0.83 to 0.97) | 3 | 12 (5.0 to 29) | 0.12 (0.07 to 0.19)
- Prospective Design | | 0.87 (0.82 to 0.91); 0.02 (p=0.59) | 6 | 0.92 (0.78 to 0.97); 0.42 (p=0.10) | 2 | 11 (3.7 to 31) | 0.14 (0.10 to 0.20)
- United States or Europe | | 0.87 (0.82 to 0.91); 0.02 (p=0.59) | 6 | 0.92 (0.78 to 0.97); 0.42 (p=0.10)) | 2 | 11 (3.7 to 31) | 0.14 (0.10 to 0.20)
- Excluding high risk of bias studies | | 0.89 (0.84 to 0.93); 0.03 (p=0.73) | 6 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 10 (4.9 to 21) | 0.12 (0.07 to 0.18)
- Avoided case-control design | | 0.90 (0.86 to 0.93); 0.02 (p=0.61) | 6 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 11 (5.1 to 22) | 0.11 (0.07 to 0.16)
- Blinded interpretation of imaging | | 0.92 (0.87 to 0.95); 0.03 (p=0.54) | 5 | 0.94 (0.89 to 0.96); 0.05 (p=0.51) | 3 | 14 (8.1 to 26) | 0.09 (0.06 to 0.14)
- Used confidence rating scale | | 0.93 (0.83 to 0.97) | 1 | 0.89 (0.65 to 0.97) | 1 | 8.5 (2.2 to 33) | 0.08 (0.03 to 0.21)
Ultrasound without contrast | Lesion | 0.62 (0.18 to 0.93); 3.7 (p=0.19) | 4 | 0.92 (0.84 to 0.96); 0.16 (p=0.34) | 3 | 8.1 (3.6 to 18) | 0.41 (0.12 to 1.4)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.76 (0.14 to 0.98); 5.4 (p=0.36) | 3 | 0.91 (0.78 to 0.97); 0.14 (p=0.54) | 2 | 8.5 (3.2 to 22) | 0.26 (0.03 to 2.4)
Ultrasound with contrast | | 0.87 (0.80 to 0.92); 1.2 (p<0.0001) | 21 | 0.91 (0.85 to 0.95); 0.51 (p=0.01) | 10 | 9.8 (5.7 to 17) | 0.14 (0.09 to 0.23)
- HCC lesions <2–3 cm | | 0.73 (0.55 to 0.85); 0.997 (p=0.02) | 7 | 0.92 (0.81–0.97); 0.95 (p=0.07) | 6 | 8.7 (4.1 to 18) | 0.30 (0.18 to 0.51)
- Excluding studies restricted to hypervascular HCC | | 0.87 (0.79 to 0.92); 1.3 (p<0.0001) | 20 | 0.91 (0.85 to 0.95); 0.52 (p=0.01) | 10 | 9.8 (5.7 to 17) | 0.15 (0.09 to 0.24)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.91 (0.86 to 0.95); 0.59 (p=0.002) | 14 | 0.93 (0.88 to 0.96); 0.05 (p=0.38) | 4 | 14 (7.7 to 24) | 0.09 (0.06 to 0.15)
- Contrast: sulfur hexafluoride | | 0.91 (0.84 to 0.96); 0.53 (p=0.003) | 7 | No data; 0.03 (p=0.34) | -- | -- | --
- Contrast: perflubutane | | 0.86 (0.67 to 0.95) | 2 | 0.92 (0.87 to 0.96) | 2 | 11 (5.8 to 22) | 0.15 (0.06 to 0.40)
- Contrast: galactose | | 0.94 (0.85 to 0.97) | 4 | 0.95 (0.86 to 0.98) | 2 | 19 (6.2 to 61) | 0.07 (0.03 to 0.17)
- Reference standard: Histological specimen | | 0.94 (0.88 to 0.97); 0.54 (p=0.002) | 6 | 0.95 (0.86 to 0.98); 0.03 (p=0.34) | 2 | 20 (6.3 to 61) | 0.06 (0.03 to 0.13)
- Reference standard: Mixed histological and imaging/clinical criteria | | 0.89 (0.81 to 0.94) | 8 | 0.93 (0.87 to 0.96) | 2 | 12 (6.5 to 23) | 0.12 (0.07 to 0.22)
- Prospective design | | 0.91 (0.85 to 0.95); 0.58 (p=0.002) | 8 | 0.93 (0.88 to 0.96); 0.05 (p=0.36) | 2 | 14 (7.7 to 24) | 0.09 (0.05 to 0.17)
- United States or Europe | | 0.94 (0.87 to 0.97); 0.53 (p=0.002) | 5 | No data | -- | -- | --
- Excluding Doppler | | 0.90 (0.85 to 0.94); 0.57 (p=0.002) | 12 | 0.93 (0.88 to 0.96); 0.05 (p=0.38) | 4 | 13 (7.6 to 24) | 0.10 (0.06 to 0.17)
- Excluding high risk of bias studies | | 0.91 (0.85 to 0.95); 0.59 (p=0.002) | 10 | 0.93 (0.88 to 0.96); 0.05 (p=0.38) | 4 | 14 (7.7 to 24) | 0.09 (0.05 to 0.17)
- Avoided case-control design | | 0.90 (0.83 to 0.94); 0.55 (p=0.002) | 10 | 0.92 (0.87 to 0.96); 0.03 (p=0.49) | 3 | 12 (6.6 to 21) | 0.11 (0.06 to 0.19)
- Blinded interpretation of imaging | | 0.92 (0.84 to 0.96); 0.60 (p=0.002) | 7 | 0.93 (0.86 to 0.96); 0.03 (p=0.48) | 2 | 12 (6.5 to 23) | 0.09 (0.05 to 0.18)
- Used confidence rating scale | | No studies | 0 | No studies | 0 | -- | --
Lesion depth <53, <60, or <85 mm | | 0.87 (0.80–0.92); <0.0001 (p=1.0) | 3 | Insufficient data | -- | -- | --
- >53, >60, or >85 mm | | 0.83 (0.74 to 0.90) | 3 | Insufficient data | -- | -- | --
Body mass index <23 or <25 | | 0.80 (0.70–0.88); 0.11 (p=0.37) | 2 | Insufficient data | -- | -- | --
- >23 or >25 | | 0.80 (0.70–0.87) | 2 | Insufficient data | -- | -- | --

HCC = hepatocellular carcinoma; KQ = Key Question

Using HCC lesions as the unit of analysis, the sensitivity of US with contrast was 0.73 (95% CI 0.52 to 0.87, 8 studies); no study reported specificity (Figure 8).51,69,71,74,79,92,106,119 Excluing three studies restricted to HCC lesions 2–3 cm74,79,92 resulted in slightly higher sensitivity (0.78, 95% CI 0.5 to 0.92, 5 studies). Seven of the eight contrast-enhanced studies used perflubutane.51,71,74,79,92,106,119 The usefulness of sensitivity analyses was limited by the small number of studies (Table 6).

Figure 8 Sensitivity of ultrasound with contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings

This figure is a forest plot that displays the specificity for studies of ultrasound with contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. An overall mixed-effects model was based on 8 studies, with a value of 0.73 (95% confidence interval: 0.52 to 0.87) and the tau-squared value is 1.57, p = 0.009.

##### Computed Tomography

Few studies evaluated CT in surveillance settings. Using patients with HCC as the unit of analysis, sensitivity was 0.84 (95% CI 0.59 to 0.95) and specificity 0.99 (95% CI 0.86 to 0.999), based on two studies (Table 7.).54,112 In one study that used HCC lesions as the unit of analysis, sensitivity was 0.62 (95% CI 0.46 to 0.76).62

Table 7 Test performance of computed tomography imaging for identification of intrahepatic and extrahepatic hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of HCC (KQ 1)
Surveillance settings | Patient | 0.84 (0.59 to 0.95); 0.50 (p=0.74) | 2 | 0.99 (0.86 to 0.999); 1.1 (p=0.97) | 2 | 60 (5.9 to 622) | 0.16 (0.06 to 0.47)
| Lesion | 0.62 (0.46 to 0.76) | 1 | Insufficient data | -- | -- | --
Nonsurveillance settings | Patient | 0.83 (0.75 to 0.89); 0.60 (p=0.008) | 16 | 0.92 (0.86 to 0.96); 0.63 (p=0.02) | 11 | 11 (5.6 to 20) | 0.19 (0.12 to 0.28)
- Excluding studies restricted to hypervascular HCC | | 0.84 (0.77 to 0.90); 0.46 (p=0.03) | 15 | 0.92 (0.85 to 0.96); 0.62 (p=0.02) | 11 | 11 (5.6 to 21) | 0.17 (0.11 to 0.26)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.83 (0.75 to 0.89); 0.60 (p=0.008) | 16 | 0.92 (0.86 to 0.96); 0.63 (p=0.02) | 11 | 11 (5.6 to 20) | 0.19 (0.12 to 0.28)
- CT type: Multidetector, ≥8 rows | | 0.88 (0.69 to 0.96); 0.55 (p=0.01) | 2 | Insufficient data; 0.48 (p=0.07) | -- | -- | --
- CT type: Multidetector, <8 rows | | 0.89 (0.69 to 0.97) | 2 | 0.98 (0.87 to 0.996) | 1 | 37 (6.1 to 222) | 0.11 (0.03 to 0.37)
- CT type: Non-multidetector | | 0.82 (0.71 to 0.89) | 11 | 0.90 (0.83 to 0.95) | 9 | 8.3 (4.5 to 15) | 0.20 (0.12 to 0.34)
- Contrast rate: ≥3 ml/s | | 0.87 (0.77 to 0.93); 0.48 (p=0.04) | 8 | 0.90 (0.81 to 0.94); 0.38 (p=0.08) | 7 | 8.4 (4.5 to 16) | 0.15 (0.08 to 0.27)
- Contrast rate: <3 ml/s | | 0.71 (0.50–0.85) | 4 | 0.95 (0.87 to 0.98) | 3 | 13 (4.8 to 37) | 0.31 (0.17 to 0.58)
- Imaging phases: Arterial, portal venous, and delayed | | 0.89 (0.81 to 0.94); 0.33 (p=0.06) | 7 | 0.88 (0.74 to 0.95); 0.41 (p=0.09) | 4 | 7.3 (3.2 to 17) | 0.13 (0.07 to 0.22)
- Imaging phases: Missing delayed phase imaging | | 0.78 (0.66 to 0.87) | 7 | 0.94 (0.87 to 0.97) | 5 | 13 (5.8 to 27) | 0.23 (0.14 to 0.38)
- Delayed phase ≥120 s | | 0.87 (0.79 to 0.92); 0.17 (p=0.12) | 6 | 0.87 (0.74 to 0.94); 0.40 (p=0.10) | 4 | 6.8 (3.1 to 15) | 0.15 (0.09 to 0.25)
- Section thickness: ≤5 mm | | 0.84 (0.73 to 0.91); 0.57 (p=0.02) | 9 | 0.87 (0.76 to 0.93); 0.19 (p=0.19) | 6 | 6.3 (3.4 to 12) | 0.19 (0.11 to 0.33)
- Section thickness: >5 mm | | 0.83 (0.67 to 0.92) | 5 | 0.95 (0.90–0.98) | 4 | 17 (8.3 to 34) | 0.18 (0.09 to 0.37)
- Reference standard: Explanted liver | | 0.81 (0.71 to 0.88); 0.47 (p=0.02) | 11 | 0.93 (0.87 to 0.96); 0.36 (p=0.05) | 9 | 11 (6.0–20) | 0.21 (0.13 to 0.32)
- Reference standard: Histopathological, non-explant | | 0.85 (0.64 to 0.95) | 3 | 0.73 (0.31 to 0.94) | 1 | 3.1 (0.83 to 12) | 0.20 (0.07 to 0.62)
- Reference standard: Histological and clinical/imaging reference standard | | 0.88 (0.70–0.96) | 2 | 0.93 (0.75 to 0.98) | 1 | 13 (3.2 to 52) | 0.13 (0.05 to 0.35)
- Prospective | | 0.72 (0.57 to 0.84); 0.30 (p=0.03) | 5 | 0.85 (0.67 to 0.94); 0.43 (p=0.03) | 3 | 4.9 (2.0–12) | 0.33 (0.20–0.54)
- United States or Europe | | 0.83 (0.73 to 0.90); 0.60 (p=0.008) | 12 | 0.89 (0.80–0.94); 0.32 (p=0.11) | 8 | 7.3 (3.9 to 14) | 0.19 (0.12 to 0.32)
- Used confidence rating scale | | 0.85 (0.70–0.93); 0.53 (p=0.01) | 4 | 0.73 (0.31 to 0.94); 0.36 (p=0.05) | 1 | 3.1 (0.84 to 12) | 0.20 (0.08 to 0.51)
- Excluding high risk of bias studies | | 0.85 (0.75 to 0.91); 0.55 (p=0.01) | 9 | 0.92 (0.83 to 0.97); 0.63 (p=0.02) | 6 | 11 (4.6 to 26) | 0.16 (0.10–0.28)
- Avoided case-control design | | 0.75 (0.63 to 0.84); 0.44 (p=0.007) | 9 | 0.91 (0.83 to 0.95); 0.59 (p=0.03) | 9 | 8.1 (4.1 to 16) | 0.28 (0.18 to 0.43)
- Blinded interpretation of imaging | | 0.83 (0.74 to 0.0.89); 0.55 (p=0.01) | 13 | 0.94 (0.88 to 0.97); 0.49 (p=0.02) | 8 | 13 (6.5 to 27) | 0.19 (0.12 to 0.29)
| Lesion | 0.77 (0.72 to 0.80); 0.92 (p<0.0001) | 79 | 0.89 (0.84 to 0.93); 0.92 (p<0.0001) | 21 | 7.1 (4.7 to 11) | 0.26 (0.22 to 0.31)
- HCC lesions <2–3 cm | | 0.70 (0.45 to 0.87); 1.8 (p=0.02) | 7 | 0.97 (0.88 to 0.99); 2.2 (p=0.08) | 2 | 24 (6.6 to 85) | 0.31 (0.15 to 0.62)
- Excluding studies restricted to hypervascular HCC | | 0.75 (0.71 to 0.80); 0.79 (p<0.0001) | 55 | 0.87 (0.80 to 0.91); 0.64 (p<0.0001) | 16 | 5.6 (4.0 to 8.5) | 0.28 (0.23 to 0.35)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.77 (0.73 to 0.81); 0.81 (p<0.0001) | 72 | 0.89 (0.83 to 0.93); 0.83 (p<0.0001) | 19 | 7.0 (4.5 to 11) | 0.26 (0.21 to 0.31)
- CT type: Multidetector, ≥8 rows | | 0.77 (0.71 to 0.82); 0.81 (p<0.0001) | 36 | 0.91 (0.84 to 0.95); 0.79 (p<0.0001) | 10 | 8.5 (4.6 to 16) | 0.26 (0.20 to 0.33)
- CT type: Multidetector, <8 rows | | 0.79 (0.59 to 0.91) | 4 | Insufficient data | -- | -- | --
- CT type: Non-multidetector | | 0.75 (0.67 to 0.82) | 22 | 0.86 (0.73 to 0.93) | 7 | 5.3 (2.7 to 10) | 0.29 (0.21 to 0.40)
- Contrast rate: ≥3 ml/s | | 0.78 (0.74 to 0.82); 0.79 (p<0.0001) | 58 | 0.90 (0.84 to 0.94); 0.82 (p<0.0001) | 18 | 7.7 (4.8 to 12) | 0.24 (0.20 to 0.30)
- Contrast rate: <3 ml/s | | 0.74 (0.59 to 0.85) | 7 | 0.71 (0.22 to 0.95) | 1 | 2.5 (0.54 to 12) | 0.37 (0.16 to 0.85)
- Imaging phases: Arterial, portal venous, and delayed | | 0.74 (0.69 to 0.80); 0.78 (p<0.0001) | 42 | 0.90 (0.85 to 0.94); 0.51 (p<0.0001) | 13 | 7.8 (4.9 to 12) | 0.28 (0.23 to 0.35)
- Imaging phases: Missing delayed phase imaging | | 0.81 (0.75 to 0.86) | 26 | 0.88 (0.75 to 0.95) | 5 | 6.7 (3.0 to 15) | 0.22 (0.16 to 0.30)
- Delayed phase ≥120 s | | 0.75 (0.69 to 0.80); 0.78 (p<0.0001) | 38 | 0.92 (0.88 to 0.95) ; 0.39(p=0.002) | 10 | 9.6 (5.9 to 16) | 0.27 (0.22 to 0.35)
- Section thickness: ≤5 mm | | 0.75 (0.70 to 0.79); 0.78 (p<0.0001) | 53 | 0.90 (0.85 to 0.94); 0.76 (p<0.0001) | 16 | 7.5 (4.7 to 12) | 0.28 (0.23 to 0.34)
- Section thickness: >5 mm | | 0.83 (0.75 to 0.89) | 14 | 0.83 (0.53 to 0.96) | 2 | 4.9 (1.4 to 17) | 0.21 (0.13 to 0.34)
- Reference standard: Explanted liver | | 0.67 (0.59 to 0.75); 0.63 (p<0.0001) | 23 | 0.82 (0.74 to 0.88); 0.46 (p=0.0001) | 12 | 3.8 (2.6 to 5.6) | 0.40 (0.31 to 0.50)
- Reference standard: Histopathological, non-explant | | 0.86 (0.78 to 0.91) | 12 | 0.95 (0.88 to 0.98) | 3 | 19 (7.1 to 49) | 0.15 (0.10 to 0.23)
- Reference standard: Imaging/clinical | | 0.65 (0.43 to 0.83) | 3 | Insufficient data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.80 (0.75 to 0.84) | 34 | 0.92 (0.83 to 0.96) | 4 | 11 (5.3 to 21) | 0.22 (0.17 to 0.27)
- Prospective | | 0.73 (0.63 to 0.81); 0.71 (p<0.0001) | 16 | 0.84 (0.74 to 0.91); 0.58 (p<0.0001) | 8 | 4.5 (2.6 to 7.8) | 0.32 (0.23 to 0.46)
- United States or Europe | | 0.76 (0.69 to 0.83); 0.81 (p<0.0001) | 23 | 0.81 (0.70 to 0.88); 0.46 (p=0.0002) | 10 | 3.9 (2.5 to 6.3) | 0.29 (0.21 to 0.40)
- Used confidence rating scale | | 0.74 (0.67 to 0.80); 0.80 (p<0.0001) | 31 | 0.92 (0.86 to 0.96); 0.63 (p<0.0001) | 9 | 9.3 (5.2 to 17) | 0.28 (0.22 to 0.36)
- Excluding high risk of bias studies | | 0.75 (0.70 to 0.80); 0.79 (p<0.0001) | 47 | 0.91 (0.87 to 0.94); 0.51 (p<0.0001) | 15 | 8.5 (5.6 to 13) | 0.27 (0.22 to 0.34)
- Avoided case-control design | | 0.74 (0.66 to 0.81); 0.80 (p<0.0001) | 21 | 0.87 (0.78 to 0.93); 0.78 (p<0.0001) | 10 | 5.7 (3.2 to 10) | 0.30 (0.21 to 0.41)
- Blinded interpretation of imaging | | 0.78 (0.72 to 0.82); 0.81 (p<0.0001) | 42 | 0.86 (0.77 to 0.92); 0.79 (p<0.0001) | 10 | 5.7 (3.3 to 9.7) | 0.26 (0.20 to 0.33)
| Liver segment | 0.88 (0.78 to 0.94); 0.81 (p=0.02) | 8 | 0.97 (0.94 to 0.98); 0.29 (p=0.06) | 8 | 26 (15 to 42) | 0.10 (0.94 to 0.98)
- Excluding studies restricted to hypervascular HCC | | 0.87 (0.75 to 0.93); 0.86 (p=0.03) | 7 | 0.97 (0.95 to 0.98); 0.31 (p=0.08) | 7 | 29 (16 to 51) | 0.14 (0.07 to 0.27)
- Excluding studies restricted to HCC lesions <2 cm | | 0.87 (0.76 to 0.94); 0.87 (p=0.02) | 7 | 0.97 (0.94 to 0.98); 0.39 (p=0.06) | 7 | 28 (15 to 51) | 0.13 (0.07 to 0.25)
Evaluation of focal liver lesions (KQ 2)
| Patient | 0.86 (0.75 to 0.92); 0.65 (p=0.04) | 8 | 0.88 (0.76 to 0.95); 0.64 (p=0.08) | 5 | 7.4 (3.3 to 17) | 0.16 (0.09 to 0.30)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.87 (0.78 to 0.93); 0.42 (p=0.11) | 6 | 0.93 (0.85 to 0.96); 0.11 (p=0.57) | 3 | 12 (5.7 to 24) | 0.14 (0.08 to 0.25)
| HCC lesion | 0.79 (0.67 to 0.87); 0.97 (p=0.001) | 13 | 0.90 (0.37 to 0.99); 4.4 (p=0.11) | 6 | 7.7 (0.71 to 84) | 0.24 (0.15 to 0.38)
- HCC lesions <2–3 cm | | 0.61 (0.49 to 0.71); 0.19 (p=0.14) | 5 | 0.98 (0.87 to 0.996); 2.5 (p=0.11) | 5 | 25 (4.5 to 138) | 0.40 (0.30 to 0.53)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.87 (0.78 to 0.92); 0.67 (p=0.01) | 8 | 0.71 (0.57 to 0.83) | 1 | Not calculated | Note calculated
- CT type: Multidetector, ≥8 rows | | 0.79 )0.56 to 0.91); 0.49 (p=0.02) | 2 | Insufficient data | -- | -- | --
- CT type: Non-multidetector | | 0.87 (0.77 to 0.93) | 5 | Insufficient data | -- | -- | --
- Contrast rate: ≥3 ml/s | | 0.87 (0.78 to 0.92); 0.67 (p=0.01) | 8 | Insufficient data | -- | -- | --
- Imaging phases: Arterial, portal venous, and delayed | | 0.83 (0.73 to 0.90); 0.48 (p=0.15) | 6 | Insufficient data | -- | -- | --
- Imaging phases: Missing delayed phase imaging | | 0.94 (0.82 to 0.98) | 2 | Insufficient data | -- | -- | --
- Delayed phase imaging >120 s | | 0.88 (0.81 to 0.92); 0.17 (p=0.03) | 4 | Insufficient data | -- | -- | --
- Section thickness: ≤5 mm | | 0.78 (0.61 to 0.89); 0.45 (p=0.01) | 3 | Insufficient data | -- | -- | --
- Section thickness: >5 mm | | 0.91 (0.78 to 0.97); 0.45 | 2 | Insufficient data | -- | -- | --
- Reference standard: Histopathological, non-explant | | 0.83 (0.73 to 0.90); 0.48 (p=0.02) | 6 | Insufficient data | -- | -- | --
- Reference standard: Histological and clinical/imaging | | 0.93 (0.82 to 0.98) | 2 | Insufficient data | -- | -- | --
- Prospective | | 0.90 (0.80 to 0.95); 0.48 (p=0.02) | 4 | Insufficient data | -- | -- | --
- United States or Europe | | 0.89 (0.80 to 0.94); 0.53 (p=0.02) | 5 | Insufficient data | -- | -- | --
- Used confidence rating scale | | 0.86 (0.64 to 0.95); 0.66 (p=0.01) | 2 | Insufficient data | -- | -- | --
- Excluding high risk of bias studies | | 00.83 (0.71 to 0.90); 0.51 (p=0.01) | 5 | Insufficient data | -- | -- | --
- Avoided case-control design | | 0.88 (0.74 to 0.95); 0.66 (p=0.01) | 4 | Insufficient data | -- | -- | --
- Blinded interpretation of imaging | | 0.86 (0.75 to 0.93); 0.65 (p=0.01) | 6 | Insufficient data | -- | -- | --

CT = computed tomography; HCC = hepatocellular carcinoma

In nonsurveillance settings, using patients with HCC as the unit of analysis, sensitivity of CT was 0.83 (95% CI 0.75 to 0.89, 16 studies) and specificity 0.92 (95% CI 0.86 to 0.96, 11 studies), for a LR+ of 11 (95% CI 5.6 to 20) and LR− of 0.19 (95% CI 0.12 to 0.28) (Figure 9).82,110,111,118,126,129,130,133,154,155,164,175,186,197,201,202 Using HCC lesions as the unit of analysis, sensitivity was 0.77 (95% CI 0.72 to 0.80, 79 studies) and specificity 0.89 (95% CI 0.84 to 0.93, 21 studies), for a LR+ of 7.1 (95% CI 4.7 to 11) and LR− of 0.26 (95% CI 0.22 to 0.31) (Figure 10).42,56,69,92,99,118–121,123–127,129–131,133,135–141,143–146,148,149,153,155,157,158,161–169,172,175–180,182–185,188,190–195,198,200,202–204,207–212,215–220. Using liver segments with HCC as the unit of analysis, sensitivity was 0.88 (95% CI 0.78 to 0.94, 8 studies) and specificity was 0.97 (95% CI 0.94 to 0.98, 8 studies), for a LR+ of 26 (95% CI 15 to 42) and LR− of 0.13 (95% CI 0.07 to 0.23).132,150,151,159,160,174,205,216

Figure 9 Test performance of CT for detection of patients with hepatocellular carcinoma in nonsurveillance settings

CT = computed tomography

This figure is a forest plot that displays the test performance for studies CT for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 17 studies, with a combined sensitivity of 0.83 (95% confidence interval: 0.75 to 0.89) and the tau-squared value is 0.60, p = 0.008. Specificity was reported or calculated for 11 studies, with a combined specificity of 0.92 (95% confidence interval: 0.86 to 0.96) and the tau-squared value is 0.63, p = 0.024.

Figure 10 Test performance of CT for detection of hepatocellular carcinoma lesions in nonsurveillance settings

CT = computed tomography

This figure is a forest plot that displays the test performance for studies of CT for detection of hepatocellular carcinoma lesions in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 79 studies, with a combined sensitivity of 0.77 (95% confidence interval: 0.72 to 0.82). Specificity was reported or calculated for 21 studies, with a combined specificity of 0.90 (95% confidence interval: 0.84 to 0.93).

Excluding high risk of bias studies, studies limited to hypervascular HCC, or HCC lesions <2–3 cm, and restricting analyses to studies that were performed in the United States and Europe, used a prospective design, avoided a case-control design, or used blinded imaging interpretation had little impact on estimates of sensitivity and specificity or measures of heterogeneity.

##### Magnetic Resonance Imaging

No study evaluated MRI in surveillance settings.

In nonsurveillance settings, using patients with HCC as the unit of analysis, sensitivity was 0.85 (95% CI 0.76 to 0.91, 10 studies) and specificity was 0.90 (95% CI 0.81 to 0.94, 8 studies), for a LR+ of 8.1 (95% CI 4.3 to 15) and LR− of 0.17 (95% CI 0.10 to 0.28) (Table 8; Figure 11).82,110,118,126,129,259,260,263,273,280

Table 8 Test performance of magnetic resonance imaging for identification of intrahepatic and extrahepatic hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of HCC (KQ 1)
Nonsurveillance settings
| Patient | 0.85 (0.76 to 0.91); 0.47 (p=0.07) | 10 | 0.90 (0.81 to 0.94); 0.51 (p=0.05) | 8 | 8.1 (4.3 to 15) | 0.17 (0.10 to 0.28)
- Excluding studies restricted to hypervascular HCC | | 0.85 (0.75 to 0.91); 0.58 (p=0.06) | 9 | 0.90 (0.81 to 0.95); 0.62 (p=0.06) | 7 | 8.7 (4.2 to 18) | 0.17 (0.10 to 0.30)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.85 (0.76 to 0.91); 0.47 (p=0.07) | 10 | 0.90 (0.81 to 0.94); 0.51 (p=0.05) | 8 | 8.1 (4.3 to 15) | 0.17 (0.10 to 0.28)
- MRI type: 1.5 T | | 0.85 (0.76 to 0.91); 0.45 (p=0.10) | 10 | 0.90 (0.82 to 0.95); 0.48 (p=0.08) | 8 | 8.3 (4.5 to 15) | 0.17 (0.10 to 0.27)
- Contrast: Gadopentetate or gadodiamide | | 0.85 (0.76 to 0.91); 0.45 (p=0.10) | 10 | 0.90 (0.82 to 0.95); 0.48 (p=0.08) | 8 | 8.3 (4.5 to 15) | 0.17 (0.10 to 0.27)
- Imaging phases: Arterial, portal venous, and delayed | | 0.85 (0.75 to 0.91); 0.45 (p=0.10) | 8 | 0.89 (0.80 to 0.95); 0.49 (p=0.08) | 6 | 8.0 (4.1 to 15) | 0.17 (0.10 to 0.29)
- Imaging phases: Missing delayed phase imaging | | 0.84 (0.57 to 0.95) | 2 | 0.92 (0.69 to 0.98) | 2 | 10 (2.2 to 47) | 0.18 (0.06 to 0.56)
- Delayed phase ≥120 s | | 0.79 (0.58 to 0.91); 0.11 (p=0.45) | 2 | 0.92 (0.77 to 0.97); 0.41 (p=0.13) | 2 | 9.7 (3.1 to 30) | 0.23 (0.10 to 0.51)
- Section thickness: ≤5 mm | | 0.88 (0.76 to 0.94); 0.31 (p=0.18) | 4 | 0.95 (0.89 to 0.98); <0.0001 (p=1.0) | 3 | 17 (8.1 to 37) | 0.13 (0.06 to 0.27)
- Section thickness: >5 mm | | 0.76 (0.54 to 0.90) | 3 | 0.84 (0.70 to 0.92) | 3 | 4.7 (2.3 to 9.4) | 029 (0.13 to 0.62)
- Reference standard: Explanted liver | | 0.87 (0.78 to 0.92); 0.32 (p=0.24) | 8 | 0.92 (0.84 to 0.96); 0.46 (p=0.14) | 6 | 11 (5.3 to 23) | 0.15 (0.09 to 0.24)
- Prospective | | 0.78 (0.59 to 0.89); 0.42 (p=0.12) | 4 | 0.94 (0.84 to 0.98); 0.29 (p=0.23) | 3 | 12 (4.5 to 34) | 0.24 (0.12 to 0.48)
- United States or Europe | | 0.87 (0.77 to 0.93); 0.70 (p=0.05) | 11 | 0.88 (0.79 to 0.93); 0.58 (p=0.04) | 9 | 7.2 (3.9 to 13) | 0.15 (0.08 to 0.27)
- Used confidence rating scale | | 0.53 (0.23 to 0.81); <0.0001 (p=1.0) | 1 | 0.72 (0.37 to 0.92); 0.27 (p=0.14) | 1 | 1.9 (0.55 to 6.8) | 0.72 (0.37 to 0.92)
- Excluding high risk of bias studies | | 0.83 (0.74 to 0.90); 0.35 (p=0.18) | 8 | 0.90 (0.80 to 0.95); 0.48 (p=0.08) | 6 | 8.0 (4.1 to 16) | 0.19 (0.12 to 0.30)
- Avoided case-control design | | 0.82 (0.73 to 0.88); 0.19 (p=0.34) | 8 | 0.89 (0.80 to 0.94); 0.43 (p=0.08) | 7 | 7.4 (4.0 to 13) | 0.20 (0.13 to 0.32)
- Blinded interpretation of imaging | | 0.90 (0.82 to 0.95); 0.18 (p=0.19) | 5 | 0.94 (0.87 to 0.97)); 0.18 (p=0.15) | 4 | 15 (6.9 to 32) | 0.11 (0.06 to 0.20)
| Lesion | 0.82 (0.79 to 0.85); 0.80 (p<0.0001) | 75 | 0.87 (0.77 to 0.93); 1.6 (p<0.0001) | 16 | 6.4 (3.5 to 12) | 0.20 (0.16 to 0.25)
- HCC lesions <2–3 cm | | 0.83 (0.73 to 0.90); 0.85 (p=0.001) | 12 | Insufficient data | -- | -- | --
- Excluding studies that used diffusion-weighted imaging | | 0.82 (0.78 to 0.85); 0.81 (p<0.0001) | 69 | 0.86 (0.75 to 0.92); 1.6 (p<0.0001) | 15 | 5.8 (3.2 to 11) | 0.21 (0.17 to 0.26)
- Excluding studies restricted to hypervascular HCC | | 0.84 (0.80 to 0.87); 0.72 (p<0.0001) | 64 | 0.87 (0.77 to 0.93); 1.6 (p<0.0001) | 16 | 6.6 (3.6 to 12) | 0.18 (0.15 to 0.23)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.82 (0.79 to 0.86); 0.78 (p<0.0001) | 63 | 0.86 (0.75 to 0.93); 1.7 (p<0.0001) | 15 | 6.0 (3.2 to 11) | 0.20 (0.16 to 0.25)
- MRI type: 3.0 T | | 0.87 (0.78 to 0.93); 0.76 (p<0.0001) | 8 | 0.94 (0.66 to 0.99); 1.5 (p<0.0001) | 2 | 14 (2.1 to 100) | 0.14 (0.07 to 0.25)
- MRI type: 1.5 T | | 0.82 (0.77 to 0.85) | 50 | 0.83 (0.69 to 0.91) | 11 | 4.8 (2.5 to 9.1) | 0.22 (0.17 to 0.28)
- Contrast: Gadopentetate or gadodiamide | | 0.81 (0.75 to 0.85); 0.75 (p<0.0001) | 32 | 0.62 (0.48 to 0.74); 0.44 (p=0.005) | 6 | 2.1 (1.5 to 3.0) | 0.31 (0.23 to 0.42)
- Contrast: Gadobenate disodium or gadobenate | | 0.84 (0.78 to 0.88) | 29 | 0.95 (0.91 to 0.97) | 8 | 18 (9.5 to 32) | 0.17 (0.13 to 0.23)
- Imaging phases: Arterial, portal venous, and delayed | | 0.82 (0.78 to 0.86); 0.76 (p<0.0001) | 59 | 0.86 (0.74 to 0.93); 1.7 (p<0.0001) | 14 | 6.0 (3.1 to 12) | 0.20 (0.16 to 0.26)
- Imaging phases: Missing delayed phase imaging | | 0.77 (0.52 to 0.91) | 3 | 0.88 (0.30 to 0.99) | 1 | 6.6 (0.52 to 83) | 0.26 (0.10 to 0.66)
- Delayed phase ≥120 s | | 0.83 (0.79 to 0.87); 0.74 (p<0.0001) | 49 | 0.90 (0.84 to 0.94); 0.66 (p=0.0002) | 10 | 8.6 (5.1 to 14) | 0.19 (0.15 to 0.24)
- Section thickness: ≤5 mm | | 0.85 (0.81 to 0.88); 0.68 (p<0.0001) | 39 | 0.87 (0.72 to 0.94); 1.7 (p<0.0001) | 10 | 6.3 (2.9 to 14) | 0.17 (0.13 to 0.23)
- Section thickness: >5 mm | | 0.81 (0.73 to 0.87) | 15 | 0.88 (0.61 to 0.97) | 3 | 6.6 (1.7 to 25) | 0.21 (0.14 to 0.32)
- Reference standard: Explanted liver | | 0.69 (0.60 to 0.76); 0.54 (p<0.0001) | 18 | 0.85 (0.70 to 0.93); 1.5 (p=0.002) | 9 | 4.6 (2.3 to 9.3) | 0.37 (0.29 to 0.47)
- Reference standard: Histopathological, non-explant | | 0.88 (0.82 to 0.93) | 11 | 0.97 (0.89 to 0.99) | 3 | 31 (7.7 to 123) | 0.12 (0.08 to 0.19)
- Reference standard: Imaging/clinical reference standard | | 0.86 (0.67 to 0.95) | 2 | Insufficient data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.86 (0.82 to 0.89) | 32 | 0.84 (0.56 to 0.96) | 3 | 5.4 (1.6 to 18) | 0.17 (0.13 to 0.23)
- Prospective | | 0.82 (0.74 to 0.89); 0.78 (p<0.0001) | 15 | 0.89 (0.71 to 0.97); 1.7 (p<0.0001) | 5 | 7.6 (2.6 to 23) | 0.20 (0.13 to 0.31)
- United States or Europe | | 0.78 (0.70 to 0.85); 0.71 (p<0.0001) | 19 | 0.73 (0.58 to 0.84); 0.73 (p=0.0004) | 8 | 2.9 (1.8 to 4.8) | 0.30 (0.21 to 0.43)
- Used confidence rating scale | | 0.86 (0.82 to 0.89)); 0.68 (p<0.0001) | 36 | 0.90 (0.78 to 0.96); 1.8 (p=0.0005) | 9 | 8.6 (3.7 to 20) | 0.16 (0.12 to 0.20)
- Excluding high risk of bias studies | | 0.81 (0.76 to 0.85); 0.74 (p<0.0001) | 47 | 0.88 (0.76 to 0.94); 1.7 (p<0.0001) | 12 | 6.6 (3.2 to 13) | 0.22 (0.17 to 0.28)
- Avoided case-control design | | 0.80 (0.73 to 0.86); 0.77 (p<0.0001) | 22 | 0.83 (0.69 to 0.92); 1.4 (p=0.0001) | 11 | 4.7 (2.4 to 9.1) | 0.24 (0.17 to 0.34)
- Blinded interpretation of imaging | | 0.84 (0.79 to 0.87); 0.77 (p<0.0001) | 38 | 0.88 (0.73 to 0.95); 1.7 (p<0.0001) | 8 | 7.1 (2.9 to 17) | 0.19 (0.14 to 0.25)
| Liver segment | 0.77 (0.56 to 0.90); 0.56 (p=0.31) | 3 | 0.97 (0.87 to 0.99); 1.6 (p=0.29) | 3 | 28 (5.6 to 0.90) | 0.97 (0.87 to 0.99)
Evaluation of focal liver lesions (KQ 2)
| Patient | 0.77 (0.66 to 0.84); 0.14 (p=0.22) | 4 | 0.81 (0.52 to 0.94); 1.6 (p=0.19) | 4 | 4.0 (1.4 to 12) | 0.29 (0.21 to 0.39)
- HCC lesions <2–3 cm | | 0.82 (0.71 to 0.89); <0.0001 (p=1.0) | 2 | 0.79 (0.68 to 0.86); <0.0001 (p=1.0) | 2 | 3.8 (2.5 to 5.9) | 0.23 (0.14 to 0.38)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.72 (0.55 to 0.85); 0.22 (p=0.14) | 2 | 0.79 (0.16 to 0.99); 3.9 (p=0.09) | 2 | 3.5 (0.38 to 31) | 0.35 (0.23 to 0.53)
| HCC lesion | 0.81 (0.72 to 0.87); 0.64 (p=0.001) | 14 | 0.93 (0.80 to 0.98); 3.7 (p=0.006) | 11 | 12 (3.8 to 39) | 0.21 (0.15 to 0.30)
- HCC lesions <2–3 cm | | 0.73 (0.62 to 0.82); 0.44 (p=0.01) | 9 | 0.95 (0.73 to 0.99); 5.8 (p=0.03) | 8 | 14 (2.5 to 76) | 0.29 (0.21 to 0.39)
- Excluding studies that used diffusion-weighted imaging | | 0.79 (0.70 to 0.85); 0.53 (p=0.002) | 13 | 0.94 (0.78 to 0.98); 4.3 (p=0.01) | 10 | 13 (3.3 to 47) | 0.23 (0.16 to 0.32)
- Excluding studies restricted to hypervascular HCC lesions | | 0.75 (0.64 to 0.84); 0.56 (p=0.01) | 9 | 0.92 (0.62 to 0.99); 6.3 (p=0.03) | 7 | 9.2 (1.7 to 49) | 0.27 (0.20 to 0.37)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.90 (0.86 to 0.93); 0.0006 (p=0.95) | 5 | 0.88 (0.76 to 0.94); 0.10 (p=0.64) | 3 | 7.5 (3.6 to 16) | 0.11 (0.08 to 0.16)
- MRI type: 1.5 T | | 0.90 (0.86 to 0.93); 0.0006 (p=0.95) | 5 | 0.88 (0.76 to 0.94); 0.10 (p=0.64) | 3 | 7.5 (3.6 to 16) | 0.11 (0.08 to 0.16)
- Contrast: Gadopentetate or gadodiamide | | 0.91 (0.86 to 0.94); <0.0001 (p=1.0) | 3 | 0.92 (0.80 to 0.97); <0.0001 (p=1.0) | 2 | 11 (4.3 to 28) | 0.10 (0.07 to 0.15)
- Contrast: Gadoxetic acid or gadobenate | | 0.88 (0.73 to 0.95) | 2 | 0.81 (0.64 to 0.91) | 1 | 4.7 (2.3 to 9.7) | 0.15 (0.06 to 0.36)
- Imaging phases: Arterial, portal venous, and delayed | | 0.90 (0.86 to 0.93); 0.0006 (p=0.95) | 5 | 0.88 (0.76 to 0.94); 0.10 (p=0.64) | 3 | 7.5 (3.6 to 16) | 0.11 (0.08 to 0.16)
- Delayed phase imaging >120 s | | 0.91 (0.86 to 0.94); <0.0001 (p=0.99) | 4 | 0.88 (0.77 to 0.94); 0.10 (p=0.64) | 3 | 7.5 (3.7 to 15) | 0.11 (0.07 to 0.16)
- Section thickness: ≤5 mm | | 0.90 (0.86 to 0.93); 0.0006 (p=0.95) | 5 | 0.88 (0.76 to 0.94); 0.10 (p=0.64) | 3 | 7.5 (3.6 to 16) | 0.11 (0.08 to 0.16)
- Reference standard: Histopathological, non-explant | | 0.91 (0.81 to 0.96); <0.0001 (p=1.0) | 1 | 0.97 (0.79 to 0.995); <0.0001 (p=1.0) | 1 | 26 (3.8 to 181) | 0.10 (0.04 to 0.21)
- Reference standard: Histological and clinical/imaging | | 0.90 (0.86 to 0.94) | 4 | 0.82 (0.69 to 0.91) | 2 | 5.1 (2.8 to 9.3) | 0.12 (0.08 to 0.18)
- Excluding high risk of bias studies | | 0.90 (0.86 to 0.93); 0.0006 (p=0.95) | 5 | 0.88 (0.76 to 0.94); 0.10 (p=0.64) | 3 | 7.5 (3.6 to 16) | 0.11 (0.08 to 0.16)

HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging

Figure 11 Test performance of MRI for detection of patients with hepatocellular carcinoma in nonsurveillance settings

MRI = magnetic resonance imaging

This figure is a forest plot that displays the test performance for studies of MRI for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 10 studies, with a combined sensitivity of 0.85 (95% confidence interval: 0.76 to 0.91) and the tau-squared value is 0.48, p = 0.067. Specificity was reported or calculated for 8 studies, with a combined specificity of 0.90 (95% confidence interval: 0.81 to 0.94) and the tau-squared value is 0.51, p = 0.05.

Using HCC lesions as the unit of analysis, sensitivity was 0.82 (95% CI 0.79 to 0.85, 75 studies) and specificity was 0.87 (95% CI 0.77 to 0.93, 16 studies), for a LR+ of 6.4 (95% CI 3.5 to 12) and LR− of 0.20 (95% CI 0.16 to 0.25) (Figure 12).56,69,99,106,118,121,123,126,129,131,135,136,138,140,141,144,145,158,163,164,166,168,179,184,190,191,193,195,198,200,203,207,209,211,212,218,221,224,227,234,236,238,244,246,248–252,254–257,259,260,262–264,267,268,270,271,274–277,281,283–286,288,290,292,295

Figure 12 Test performance of MRI for detection of hepatocellular carcinoma lesions in nonsurveillance settings

MRI = magnetic resonance imaging

This figure is a forest plot that displays the test performance for studies of MRI for detection of hepatocellular carcinoma lesions in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 75 studies, with a combined sensitivity of 0.83 (95% confidence interval: 0.79 to 0.86). Specificity was reported or calculated for 16 studies, with a combined specificity of 0.88 (95% confidence interval: 0.78 to 0.94).

Excluding high risk of bias studies, studies limited to hypervascular HCC, or HCC lesions <2–3 cm, and restricting analyses to studies that were performed in the United States and Europe, used a prospective design, avoided a case-control design, or used blinded imaging interpretation had little impact on estimates of sensitivity and specificity or measures of heterogeneity.

##### Positron Emission Tomography

No study evaluated PET in surveillance settings.

In nonsurveillance settings, using patients with HCC as the unit of analysis, sensitivity of FDG PET was 0.52 (95% CI 0.39 to 0.66, 15 studies) and specificity was 0.95 (95% CI 0.82 to 0.99, 5 studies) (Table 9; Figure 13; Appendix G).110,111,154,297,302,307–310,313–318 Using HCC lesions as the unit of analysis, sensitivity was 0.53 (95% CI 0.41 to 0.65, 5 studies) and specificity 0.91 (95% CI 0.76 to 0.98, 1 study) (Figure 14).297,303,309,313,319 Results were similar when analyses excluded high risk of bias studies, or when analyses were restricted to studies that used a prospective design or were conducted in the United States or Europe.

Table 9 Test performance of positron emission tomography for identification of intrahepatic and extrahepatic hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of intrahepatic HCC (KQ 1)
FDG PET for intrahepatic HCC | Patient | 0.52 (0.39 to 0.66); 0.87 (p=0.01) | 15 | 0.95 (0.82 to 0.99); 0.17 (p=0.40) | 5 | 11 (2.6 to 49) | 0.50 (0.37 to 0.68)
- Excluding high risk of bias studies | | 0.42 (0.26 to 0.60); 0.65 (p=0.01) | 7 | 0.92 (0.76 to 0.98); 0.04 (p=0.73) | 3 | 5.3 (1.5 to 18) | 0.63 (0.45 to 0.87)
- PET type: PET | | 0.39 (0.24 to 0.56); 0.54 (p=0.01) | 8 | 0.94 (0.68 to 0.99); 0.11 (p=0.68) | 3 | 6.6 (0.92 to 47) | 0.65 (0.48 to 0.88)
- PET type: PET/CT | | 0.65 (0.50–0.78) | 7 | 0.96 (0.74 to 0.99) | 2 | 15 (2.0–111) | 0.36 (0.24 to 0.56)
- Prospective | | 0.46 (0.31 to 0.62); 0.46 (p=0.02) | 8 | 0.94 (0.80–0.98); 0.06 (p=0.62) | 4 | 7.6 (2.0–30) | 0.6 (0.41 to 0.79)
- United States or Europe | | 0.49 (0.32 to 0.66); 0.84 (p=0.01) | 10 | 0.95 (0.82 to 0.99); 0.16 (p=0.41) | 5 | 10 (2.3 to 43) | 0.54 (0.37 to 0.77)
- Reference standard: Histopathological, non-explant | | 0.46 (0.28 to 0.65); 0.81 (p=0.01) | 7 | 0.91 (0.42 to 0.99); 0.02 (p=0.86) | 2 | 5.2 (0.45 to 60) | 0.59 (0.38 to 0.91)
- Reference standard: Mixed histological and imaging/clinical | | 0.58 (0.40–0.75) | 8 | 0.97 (0.79 to 0.996) | 3 | 18 (2.4 to 132) | 0.43 (0.28 to 0.67)
| HCC lesion | 0.53 (0.41 to 0.65); 0.23 (p=0.08) | 5 | 0.91 (0.76 to 0.98) | 1 | Not calculated | Not calculated
- Excluding high risk of bias studies | | 0.58 (0.46 to 0.68); 0.11 (p=0.26) | 3 | 0.91 (0.76 to 0.98) | 1 | Not calculated | Not calculated
- PET type: PET/CT | | 0.51 (0.38 to 0.65); 0.26 (p=0.11) | 4 | 0.91 (0.76 to 0.98) | 1 | Not calculated | Not calculated
- Reference standard: Histopathological, non-explant | | 0.49 (0.37 to 0.61); 0.25 (p=0.15) | 4 | No data | No data | -- | --
- United States or Europe | | 0.67 (0.55 to 0.78) | 1 | 0.91 (0.76 to 0.98) | 1 | Not calculated | Not calculated
^ 11 ^ C-acetate PET for intrahepatic HCC | Patient | 0.85 (0.67 to 0.94); 0.70 (p=0.13) | 4 | No data | No data | -- | --
| HCC lesion | 0.78 (0.61 to 0.89); 0.55 (p=0.15) | 4 | No data | No data | -- | --
- Excluding high risk of bias studies | | 0.76 (0.69 to 0.82); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
- PET type: PET | | 0.68 (0.46 to 0.84); 0.22 (p=0.49) | 2 | No data | No data | -- | --
- PET type: PET/CT | | 0.85 (0.67 to 0.94); 0.42 (p=0.39) | 2 | No data | No data | -- | --
- Reference standard: Histopathological, non-explant | | 0.78 (0.61 to 0.89); 0.55 (p=0.15) | 4 | No data | No data | -- | --
- United States or Europe | | 0.78 (0.64 to 0.89) | 1 | No data | No data | -- | --
FDG + ^11^C-acetate PET for intrahepatic HCC | Patient | 0.89 (0.80 to 0.95) | 1 | No data | No data | -- | --
| HCC lesion | 0.95 (0.86 to 0.99) | 1 | No data | No data | -- | --
^ 18 ^ F-fluorothymidine PET for intrahepatic HCC | Patient | 0.69 (0.41 to 0.89) | 1 | No data | No data | -- | --
^ 18 ^ F-fluorochlorine PET for intrahepatic HCC | Patient | 0.91 (0.78 to 0.96); <0.0001 (p=1.0) | 2 | 0.47 (0.23 to 0.72) | 1 | Not calculated | Not calculated
| HCC lesion | 0.84 (0.74 to 0.92) | 1 | 0.62 (0.44 to 0.78) | 1 | Not calculated | Not calculated
FDG PET for recurrent intrahepatic HCC | Patient | 0.70 (0.32 to 0.92); 1.5 (p=0.29) | 3 | 0.71 (0.29 to 0.96) | 1 | Not calculated | Not calculated
| HCC lesion | 0.07 (2/27) and 0.73 (22/30) | 2 | 1.0 (1/0) | 1 | Not calculated | Not calculated
Staging of HCC (KQ 3)
FDG PET for metastatic HCC | Patient with metastatic HCC | 0.85 (0.71 to 0.93); 0.12 (p=0.13) | 6 | 0.93 (0.89 to 0.95); 1.0 (p=0.17) | 5 | 11 (7.8 to 17) | 0.16 (0.08 to 0.33)
- PET type: PET | | 0.98 (0.29 to 0.9998); 6.1 (p=0.30) | 2 | 0.93 (0.86 to 0.97); 0.005 (p=0.85) | 2 | 14 (7.1 to 29) | 0.02 (0.0003 to 2.2)
- PET type: PET/CT | | 0.78 (0.72 to 0.83); <0.0001 (p=1.0) | 4 | 0.92 (0.86 to 0.96); <0.0001 (p=1.0) | 4 | 9.8 (5.5 to 17) | 0.24 (0.18 to 0.30)
- Excluding high risk of bias studies | | 0.90 (0.71 to 0.97); 1.1 (p=0.26) | 4 | 0.93 (0.89 to 0.95); <0.0001 (p=1.0) | 3 | 13 (8.3 to 20) | 0.11 (0.04 to 0.34)
- Reference standard: Mixed histological and imaging/clinical | | 0.78 (0.73 to 0.83); <0.0001 (p=1.0) | 5 | 0.92 (0.87 to 0.96); <0.0001(p=1.0) | 4 | 10 (5.7 to 18) | 0.24 (0.18 to 0.30)
- Prospective | | 0.96 (0.87 to 0.99); <0.0001 (p=1.0) | 2 | 0.93 (0.90–0.96); <0.0001 (p=1.0) | 2 | 14 (9.0–22) | 0.05 (0.02 to 0.14)
- United States or Europe | | No data | -- | No data | -- | -- | --
- Avoided case-control design | | 0.88 (0.63 to 0.97); 1.6 (p=0.23) | 4 | 0.92 (0.88 to 0.95); <0.0001 (p=1.0) | 3 | 11 (7.1 to 17) | 0.14 (0.04 to 0.47)
- Blinded interpretation of imaging | | 0.92 (0.80–0.97); 0.26 (p=0.23) | 2 | 0.93 (0.88 to 0.95) | 1 | 13 (7.8 to 20) | 0.08 (0.03 to 0.23)
| Metastatic HCC lesion | 0.82 (0.72 to 0.90); 0.17 (p=0.21) | 5 | No data | -- | -- | --
- PET type: PET | | 0.81 (0.64 to 0.91); 0.31 (p=0.28) | 3 | No data | -- | -- | --
- PET type: PET/CT | | 0.92 (0.77 to 0.97); 0.63 (p=0.31) | 3 | No data | -- | -- | --
- Reference standard: Histopathological, non-explant | | 0.85 (0.70–0.93); <0.0001 (p=1.0) | 2 | No data | -- | -- | --
- Reference standard: Imaging and clinical criteria | | 0.90 (0.79 to 0.95) | 1 | No data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.72 (0.58 to 0.82) | 2 | No data | -- | -- | --
- Excluding high risk of bias studies | | 0.86 (0.70–0.95) | 1 | No data | -- | -- | --
- Blinded interpretation of imaging | | 0.87 (0.78 to 0.93); <0.0001 (p=1.0) | 3 | No data | -- | -- | --
- United States or Europe | | No data^a^ | -- | No data | -- | -- | --

CT = computed tomography; FDG = fluorodeoxyglucose; HCC = hepatocellular carcinoma; KQ = Key Question; PET = positron emission tomography

a 1 study with 5 patients

Figure 13 Test performance of FDG PET for detection of patients with hepatocellular carcinoma in nonsurveillance settings

FDG = ^18^F-fluorodeoxyglucose; PET = positron emission tomography

This figure is a forest plot that displays the test performance of FDG PET for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 15 studies, with a combined sensitivity of 0.52 (95% confidence interval: 0.39 to 0.66) and the tau-squared value is 0.87, p = 0.007. Specificity was reported or calculated for 5 studies, with a combined specificity of 0.95 (95% confidence interval: 0.82 to 0.99) and the tau-squared value is 0.17, p = 0.399.

Figure 14 Test performance of FDG PET for detection of hepatocellular carcinoma lesions in nonsurveillance settings

This figure is a forest plot that displays the test performance of FDG PET for detection of hepatocellular carcinoma lesions in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 5 studies, with a combined sensitivity of 0.53 (95% confidence interval: 0.41 to 0.65) and the tau-squared value is 0.23, p = 0.78. Specificity was reported or calculated for 1 study, with a combined specificity of 0.91 (95% confidence interval: 0.76 to 0.98) and the tau-squared value is not applicable.

Using patients with HCC as the unit of analysis, sensitivity of ^11^C-acetate PET was 0.85 (95% CI 0.67 to 0.94, 4 studies) (Figure 15).297,302,306,309 Using HCC lesions as the unit of analysis, sensitivity was 0.78 (95% CI 0.61 to 0.89, 4 studies) (Figure 16).127,306,309,319 Sensitivities of around 0.90 were reported for PET with dual tracers (FDG plus ^11^C-acetate)127,317 and alternative tracers such as ^18^F-fluorothymidine299 or ^18^F-fluorochlorine,313,314 but evidence was limited to one or two studies each.

Figure 15 Sensitivity of ^11^C-acetate PET for detection of patients with hepatocellular carcinoma in nonsurveillance settings*

* Specificity not available

PET = positron emission tomography

This figure is a forest plot that displays the sensitivity of 11C-acetate PET for detection of patients with hepatocellular carcinoma in nonsurveillance settings. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. An overall mixed-effects model was based on 4 studies, with a value of .85 (95% confidence interval: 0.67 to 0.94) and the tau-squared value is 0.70, p = 0.134.

Figure 16 Sensitivity of ^11^C-acetate PET for detection of hepatocellular carcinoma lesions in nonsurveillance settings^*^ * Specificity not available

PET = positron emission tomography

This figure is a forest plot that displays the sensitivity of 11C-acetate PET for detection of hepatocellular carcinoma lesions in nonsurveillance settings. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. An overall mixed-effects model was based on 4 studies, with a value of 0.78 (95% confidence interval: 0.61 to 0.89) and the tau-squared value is 0.55, p = 0.148.

Three studies found FDG PET associated with sensitivity of 0.70 (95% CI 0.32 to 0.92, 3 studies) for detection of recurrent intrahepatic HCC, with a specificity of 0.71 (95% CI 0.29 to 0.96).305,312,318

##### Ultrasound Versus Computed Tomography

Using patients with HCC as the unit of analysis, sensitivity was lower for US without contrast (0.68, 95% CI 0.54 to 0.80) than for CT (0.80, 95% CI 0.68 to 0.88), for a difference of −0.12 (95% CI −0.20 to −0.03), based on six studies conducted in surveillance or nonsurveillance settings (Table 10.).54,82,110–112,118 Findings were similar when one high risk of bias study 82 was excluded. Two of the studies were conducted in surveillance settings; both found US associated with lower sensitivity than CT (0.59 vs. 0.91^54^ and 0.60 vs. 0.70^112^), with similar specificity.

Table 10 Pooled direct (within-study) comparisons of test performance of imaging modalities for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity A (95% CI) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Detection of HCC (KQ 1)
US without contrast (A) vs. CT (B) | Patient | 0.68 (0.54 to 0.80) | 0.80 (0.68 to 0.88) | −0.12 (−0.20 to −0.03); 0.36 (p=0.15) | 6 | 0.92 (0.84 to 0.96) | 0.94 (0.87 to 0.97) | −0.01 (−0.05 to 0.02); 0.62 (p=0.07) | 5
- Excluding high risk of bias studies | Patient | 0.71 (0.58 to 0.82) | 0.82 (0.71 to 0.89) | −0.10 (−0.18 to −0.02); 0.19 (p=0.25) | 5 | 0.91 (0.81 to 0.96) | 0.94 (0.86 to 0.98) | −0.03 (−0.07 to 0.01); 0.73 (p=0.11) | 4
US without contrast (A) vs. CT (B) | Lesion | 0.55 (0.43 to 0.66) | 0.66 (0.54 to 0.76) | −0.11 (−0.18 to −0.04); 0.11 (p=0.28) | 3 | 0.83 (0.65 to 0.93) | 0.93 (0.83 to 0.98) | −0.10 (−0.20 to −0.008); 0.44 (p=0.29) | 2
- HCC lesions <2 cm | Lesion | 0.46 (0.30–0.63) | 0.54 (0.37 to 0.70) | −0.07 (−0.17 to 0.02); 0.31 (p=0.27) | 3 | 0.72 (0.61 to 0.80) | 0.80 (0.71 to 0.86) | −0.08 (−0.20 to 0.04); 0.002 (p=0.85) | 2
US with contrast (A) vs. CT (B) | Lesion | 0.58 (0.37 to 0.77) | 0.74 (0.54 to 0.87) | −0.16 (−0.32 to −0.01); 0.50 (p=0.15) | 3 | No data | No data | -- | --
- HCC lesions <2 cm | Lesion | 0.30 (0.17 to 0.43) | 0.44 (0.30–0.58) | −0.14 (−0.32 to 0.05) | 1 | No data | No data | -- | --
US without contrast (A) vs. MRI (B) | Patient | 0.61 (0.48 to 0.74) | 0.81 (0.69 to 0.89) | −0.19 (−0.30 to −0.08); 0.01 (p=0.79) | 3 | 0.94 (0.87 to 0.97) | 0.82 (0.66 to 0.91) | 0.13 (0.03 to 0.22); 0.01 (p=0.40) | 3
US without contrast (A) vs. MRI (B) | Lesion | 0.57 (0.42 to 0.71) | 0.79 (0.67 to 0.88) | −0.22 (−0.31 to −0.14); 0.22 (p=0.28) | 3 | 0.75 (0.66 to 0.82) | 0.78 (0.70–0.85) | −0.03 (−0.13 to 0.06); 0.001 (p=0.89) | 2
- HCC lesions <2 cm | Lesion | 0.40 (0.18 to 0.67) | 0.65 (0.38 to 0.85) | −0.26 (−0.36 to −0.15); 0.60 | 2 | 0.71 (0.60–0.80) | 0.84 (0.76 to 0.89) | −0.13 (−0.25 to −0.01); 0.006 | 2
US with contrast (A) vs. MRI (B) | Lesion | 0.65 (0.41 to 0.84) | 0.73 (0.50 to 0.88) | −0.08 (−0.19 to 0.02); 0.69 (p=0.15) | 3 | No data | No data | -- | --
- HCC lesions <2 cm | Lesion | 0.30 (0.17 to 0.43) | 0.42 (0.28 to 0.56) | −0.12 (−0.31 to 0.07) | 1 | No data | No data | -- | --
- Well-differentiated HCC lesions | Lesion | 0.43 (0.14 to 0.77) | 0.36 (0.11 to 0.72) | 0.07 (−0.19 to 0.33); 0.87 (p=0.34) | 2 | No data | No data | -- | --
MRI (A) vs. CT (B) | Patient | 0.88 (0.53 to 0.98) | 0.82 (0.41 to 0.97) | 0.06 (−0.05 to 0.17); 3.0 (p=0.21) | 4 | 0.84 (0.70 to 0.92) | 0.91 (0.82 to 0.96) | −0.08 (−0.16 to 0.00); 0.40 (p=0.21) | 4
- Excluding high risk of bias studies | Patient | 0.82 (0.75 to 0.88) | 0.75 (0.68 to 0.81) | 0.07 (−0.02 to 0.17); <0.0001 (p=0.10) | 2 | 0.80 (0.57 to 0.92) | 0.91 (0.77 to 0.97) | −0.11 (−0.23 to 0.01); 0.44 (p=0.11) | 2
MRI (A) vs. CT (B) | Lesion | 0.81 (0.76 to 0.84) | 0.71 (0.66 to 0.76) | 0.09 (0.07 to 0.12); 0.48 (p<0.0001) | 31 | 0.86 (0.78 to 0.91) | 0.91 (0.85 to 0.95) | −0.05 (−0.10 to 0.002); 0.42 (p=0.006) | 7
- Excluding high risk of bias studies | Lesion | 0.79 (0.73 to 0.85) | 0.72 (0.65 to 0.79) | 0.07 (0.04 to 0.10); 0.64 (p<0.0001) | 22 | 0.87 (0.79 to 0.92) | 0.92 (0.87 to 0.96) | −0.06 (−0.11 to −0.01) | 6
- MRI contrast type: Non-hepatic specific | Lesion | 0.81 (0.74 to 0.87) | 0.74 (0.65 to 0.81) | 0.08 (0.04 to 0.11); 0.39 (p=0.006) | 11 | 0.62 (0.51 to 0.72) | 0.86 (0.77 to 0.93) | −0.24 (−0.37 to −0.11) | 2
- MRI contrast type: Hepatic specific | Lesion | 0.80 (0.73 to 0.85) | 0.70 (0.62 to 0.77) | 0.10 (0.06 to 0.14); 0.56 (p<0.0001) | 11 | 0.92 (0.87 to 0.95) | 0.90 (0.85 to 0.94) | 0.01 (−0.04 to 0.07); 0.03 (p=0.40) | 2
- HCC lesions <2 cm | Lesion | 0.71 (0.64 to 0.78) | 0.56 (0.48 to 0.63) | 0.16 (0.11 to 0.20); 0.42 (p<0.0001) | 19 | 0.91 (0.80 to 0.96) | 0.91 (0.80 to 0.96) | 0.001 (−0.04 to 0.05); 0.74 (p=0.02) | 4
- Excluding high risk of bias studies | Lesion | 0.71 (0.62 to 0.78) | 0.54 (0.45 to 0.63) | 0.17 (0.12 to 0.22); 0.38 (p=0.0008) | 13 | 0.91 (0.80 to 0.96) | 0.91 (0.80 to 0.96) | 0.00 (−0.05 to 0.05); 0.74 (p=0.03) | 4
- MRI contrast: Non-hepatic contrast | Lesion | 0.61 (0.44 to 0.75) | 0.55 (0.38 to 0.70) | 0.06 (0.00 to 0.13); 0.65 (p=0.04) | 6 | 0.77 (0.64 to 0.86) | 0.74 (0.61 to 0.84) | 0.03 (−0.13 to 0.19); <0.0001 (p=1.0) | 1
- MRI contrast: Hepatic specific contrast | Lesion | 0.77 (0.70 to 0.83) | 0.54 (0.45 to 0.62) | 0.23 (0.17 to 0.29); 0.29 (p=0.002) | 12 | 0.94 (0.86 to 0.979) | 0.94 (0.87 to 0.98) | −0.01 (−0.05 to 0.04); 0.37 (p=0.10) | 3
- Restricted to studies meeting all CT and MRI technical criteria^*^ | Lesion | 0.75 (0.66 to 0.82) | 0.55 (0.44 to 0.65) | 0.29 (0.13 to 0.27); 0.30 (p=0.02) | 8 | 0.93 (0.82 to 0.98) | 0.90 (0.77 to 0.96) | 0.03 (−0.05 to 0.11); 0.21 (p=0.40) | 2
Evaluation of focal liver lesion (KQ 2)
US without contrast (A) vs. CT (B) | Patient | 0.78 (0.70 to 0.85) | 0.89 (0.84 to 0.95) | −0.12 (−0.21 to −0.02) | 1 | No data | No data | -- | --
US with contrast (A) vs. CT (B) | Patient | 0.91 (0.85 to 0.94) | 0.88 (0.81 to 0.92) | 0.03 (−0.02 to 0.08); 0.15 (p=0.13) | 5 | 0.93 (0.87 to 0.96) | 0.94 (0.88 to 0.97) | −0.01 (−0.06 to 0.05); 0.07 (p=0.32) | 2
- Excluding high risk of bias studies | Patient | 0.90 (0.79 to 0.95) | 0.87 (0.76 to 0.94) | 0.02 (−0.05 to 0.10); 0.28 (p=0.31) | 3 | 0.93 (0.87 to 0.97) | 0.94 (0.88 to 0.97) | −0.01 (−0.06 to 0.05); 0.08 (p=0.45) | 2
US with contrast (A) vs. CT (B) | Lesion | 0.92 (0.88 to 0.96) | 0.89 (0.83 to 0.93) | 0.04 (−0.02 to 0.09); 0.07 (p=0.33) | 4 | No data | No data | -- | --
- HCC lesions <2 cm | Lesion | 0.78 (0.61 to 0.89) | 0.71 (0.52 to 0.85) | 0.07 (−0.01 to 0.15); 1.1 (p-0.02) | 7 | 0.87 (0.62 to 0.97) | 0.94 (0.77 to 0.98) | −0.06 (−0.15 to 0.03); 2.4 (p=0.09) | 4
- HCC lesions <2 cm | Patient | 0.95 (0.85 to 1.0) | 0.95 (0.85 to 1.0) | 0.0 (−0.14 to 0.14) | 1 | 0.71 (0.52 to 0.91) | 0.81 (0.64 to 0.98) | 0.10 (−0.35 to 0.16) | 1
- Well-differentiated HCC lesions | Lesion | 0.55 (0.25 to 0.82) | 0.55 (0.25 to 0.82) | 0.00 (−0.30 to 0.30); 0.48 (p=0.40) | 2 | No data | No data | -- | --
US with contrast (A) vs. MRI (B) | Patient | 0.79 (0.65 to 0.94) | 0.83 (0.69 to 0.97) | −0.03 (−0.24 to 0.17) | 1 | 0.79 (0.68 to 0.90) | 0.75 (0.64 to 0.87) | 0.04 (−0.12 to 0.20) | 1
- HCC lesions <2 cm | Patient | 0.52 (0.39 to 0.64) | 0.62 (0.49 to 0.74) | −0.10 (−0.27 to 0.08) | 1 | 0.93 (0.84 to 1.0) | 0.97 (0.90–1.0) | −0.03 (−0.15 to 0.08) | 1
US with contrast (A) vs. MRI (B) | Lesion | 0.79 (0.65 to 0.94) | 0.83 (0.69 to 0.97) | −0.03 (−0.24 to 0.17) | 1 | 0.79 (0.68 to 0.90) | 0.75 (0.64 to 0.87) | 0.04 (−0.12 to 0.20) | 1
- HCC lesions <2 cm | Lesion | 0.53 (0.28 to 0.76) | 0.68 (0.43 to 0.86) | −0.16 (−0.30 to −0.02); 0.72 (p=0.25) | 3 | 0.95 (0.85 to 0.98) | 0.98 (0.91 to 0.99) | −0.03 (−0.08 to 0.02); 0.38 (p=0.43) | 3
MRI (A) vs. CT (B) | Patient | 0.81 (0.70 to 0.92) | 0.74 (0.62 to 0.87) | 0.06 (−0.10 to 0.23) | 1 | 0.85 (0.72 to 0.99) | 0.81 (0.66 to 0.96) | 0.04 (−0.16 to 0.24) | 1
MRI (A) vs. CT (B) | Lesion | 0.84 (0.76 to 0.92) | 0.62 (0.52 to 0.72) | 0.22 (0.09 to 0.35) | 1 | 0.36 (0.20–0.52) | 0.72 (0.58 to 0.87) | −0.36 (−0.58 to −0.15) | 1
- HCC lesion <2 cm | Lesion | 0.65 (0.04 to 0.99) | 0.50 (0.02 to 0.98) | 0.15 (−0.002 to 0.30); 11 (p=0.26) | 3 | 0.93 (0.21 to 0.998) | 0.98 (0.48 to 0.9996) | −0.05 (−0.23 to 0.13); 11 (p=0.24) | 3
Detection of metastatic HCC (KQ 4)
PET/CT (A) vs. CT (B) | Patient (2), lesion (1) | 0.82 (0.61 to 0.93) | 0.85 (0.66 to 0.95) | −0.03 (−0.12 to 0.060); 0.75 (p=0.17) | 3 | Insufficient data | Insufficient data | -- | --

* Defined for CT as multidetector CT≥=8 rows, contrast rate ≥3 ml/s, includes arterial, portal venous and delayed phase imaging, delayed phase imaging >120 s after administration of contrast, and section thickness ≤5 mm; for MRI includes arterial, portal venous and delayed phase imaging, delayed phase imaging >120 s after administration of contrast, and section thickness ≤5 mm

CT = computed tomography; HCC = hepatocellular carcinoma; MRI =magnetic resonance imaging; PET = positron emission tomography; US = ultrasound

Using HCC lesions as the unit of analysis, US without contrast was associated with lower sensitivity than CT (0.55, 95% CI 0.43 to 0.66 versus 0.66, 95% CI 0.54 to 0.76, for a difference of −0.11 95% CI −0.18 to −0.04), based on three studies.56,99,118 Four studies reported similar findings for US with contrast versus CT (sensitivity 0.51, 95% CI 0.29 to 0.74 vs. 0.61, 95% CI 0.38 to 0.81, for a difference of −0.10, 95% CI −0.20 to 0.00).51,69,92,119 There were no clear differences in sensitivity of US with or without contrast versus CT when analyses were restricted to HCC lesions <2 cm, but analyses were imprecise and based on small numbers of studies (Table 10).56,62,69,92,118 None of the studies were performed in surveillance settings.

##### Ultrasound Versus Magnetic Resonance Imaging

No study evaluated MRI versus CT in surveillance settings.

In nonsurveillance settings, using patients with HCC as the unit of analysis, three studies found US without contrast associated with lower sensitivity than MRI (0.61, 95% CI 0.48 to 0.74 vs. 0.81, 95% CI 0.69 to 0.89, for a difference of −0.19, 95% CI −0.30 to −0.08), but higher specificity (0.94, 95% CI 0.87 to 0.97 vs. 0.82, 95% CI 0.66 to 0.91, for a difference of 0.13, 95% CI 0.03 to 0.22) (Table 10).82,110,118 Using HCC lesions as the unit of analysis, three studies found US without contrast associated with lower sensitivity than MRI (0.57, 95% CI 0.42 to 0.71 versus 0.79, 95% CI 0.67 to 0.88, for a difference of −0.22, 95% CI −0.31 to −0.14).56,99,118

Three studies found US with contrast associated with lower sensitivity than MRI (0.65, 95% CI 0.41 to 0.84 vs. 0.73, 95% CI 0.50 to 0.88, for a difference of −0.08, 95% CI −0.19 to 0.02).51,69,106 There were no clear differences between US with contrast versus MRI for HCC lesions <2 cm or for well-differentiated HCC lesions, but estimates were imprecise and based on small numbers of studies.

##### Magnetic Resonance Imaging Versus Computed Tomography

No study evaluated MRI versus CT in surveillance settings. In nonsurveillance settings, using patients with HCC as the unit of analysis, four studies found no clear differences between MRI and CT in sensitivity or specificity (Table 10).82,110,118,126 Results were similar when high risk of bias studies were excluded.

Using HCC lesions as the unit of analysis, 31 studies found MRI associated with higher sensitivity than CT (0.81, 95% CI 0.76 to 0.84 vs. 0.71, 95% CI 0.66 to 0.76, for a difference of 0.09 (95% CI 0.07 to 0.12), with no difference in specificity.51,56,69,99,118,121,123,126,131,135,136,140,144,145,158,163,164,166,168,176,179,184,190,191,193,195,198,207,209,211,212 Results were similar when high risk of bias studies were excluded. Differences in sensitivity were also similar when studies were stratified according to use of nonhepatic-specific99,118,126,140,164,166,179,193,198,209,211 or hepatic-specific contrast51,56,69,121,123,131,135,136,144,145,158,163,168,184,191,195,207,212 with MRI. Specificity was lower with nonhepatic-specific MRI than CT (0.62, 95% CI 0.51 to 0.72 vs. 0.86, 95% CI 0.77 to 0.93, for a difference of −0.24, 95% CI −0.37 to −0.11), but only two studies of nonhepatic-specific contrast reported specificity.99,126

MRI was also associated with higher sensitivity than CT when the analysis was restricted to HCC lesions <2–3 cm (0.71, 95% CI 0.64 to 0.78 vs. 0.56, 95% CI 0.48 to 0.63, for an absolute difference of 0.16, 95% CI 0.11 to 0.20, based on 19 studies).56,69,74,118,123,126,131,135,140,141,145,168,176,184,193,195,200,203,218 The difference in sensitivity was greater in studies that evaluated hepatic specific MRI contrast agents (0.23, 95% CI 0.17 to 0.29, 12 studies) than in studies that evaluated non-hepatic specific MRI contrast agents (0.06, 95% CI −0.01 to 0.13, 6 studies) (Table 10).

##### Multiple Imaging Modalities

One study found sensitivity of imaging with various combinations of two imaging modalities was similar or lower than single modality imaging, based on concordant positive findings on two imaging modalities (Table 11).51 The other study reported higher sensitivity with multiple imaging modalities than with single modality imaging, but criteria for positive results based on multiple imaging modalities were not reported.69 Specificity was not reported in either study.

Table 11 Comparisons of test performance for hepatocellular carcinoma of single compared with multiple modality imaging^a^

Study, Year | Unit of Analysis | Single Imaging Modalities | Sensitivity | Specificity | Multiple Imaging Modalities | Criteria for Positive Results with Multiple Imaging Modalities | Sensitivity | Specificity
Detection of HCC (KQ 1)
Alaboudy, 2011^51^ | Lesion | A: US B: CT C: MRI | A: 0.72 B: 0.74 C: 0.86 | Not reported | A: US + MRI B: US + CT C: CT + MRI | Unclear | A: 0.90 B: 0.82 C: 0.88 | Not reported
Iavarone, 2010^69^ | Lesion (1 to 2 cm) | A: MRI B: CT C: US | A: 0.42 B: 0.45 C: 0.32 | Not reported | A: US + MR B: US + CT C: MRI + CT D: Any dual combination of MRI, CT, and US | Concordant positive findings on 2 imaging modalities | A: 0.16 B: 0.19 C: 0.29 D: 0.40 | Not reported
Evaluation of focal liver lesions (KQ 2)
Dai, 2008^55^ | Lesion | A: US B: CT | A: 0.91 B: 0.80 | A: 0.87 B: 0.98 | CT + US | Unclear | 0.80 | 0.87
Forner, 2008^59^ | Lesion (<2 cm) | MRI | 0.62 | 0.97 | MRI + US | 1: Definite positive findings on 2 imaging modalities 2: “At least suspicious” on 2 imaging modalities | 1: 0.33 2: 0.67 | 1: 1.0 2: 1.0
Golfieri, 2009^134^ | Lesion (<3 cm) | CT | 0.62 | 0.72 | MRI + CT | Unclear | 0.89 | 0.22
Khalili, 2011^75^ | Lesion (1 to 2 cm) | CT | 0.53 | 0.99 | A: US + MRI B: CT + MRI C: CT + US D: MRI then US E: MRI then CT F: CT then US | A-C: Concordant positive results on 2 imaging modalities D-F: Positive findings on initial imaging modality or positive findings on second imaging modality for indeterminate findings on first scan | A: 0.35 B: 0.41 C: 0.29 D: 0.79 E: 0.74 F: 0.76 | A: 1.0 B: 1.0 C: 0.99 D: 0.91 E: 0.99 F: 0.91
Quaia, 2009^96^ | Lesion (<3 cm) | A: CT B: US | A: 0.72 B: 0.88 | A: 0.71 B: 0.66 | CT + US | Positive findings from at least one imaging technique | 0.97 | 0.70
Sangiovanni, 2010^43^ | Lesion (1 to 2 cm) | A: US B: CT C: MRI | A: 0.26 B: 0.44 C: 0.44 | A: 1.0 B: 1.0 C: 1.0 | US, CT, and MRI | 1: Concordant positive findings on two imaging techniques 2: Positive findings from at least one imaging technique | 1: 0.35 2: 0.65 | Not reported
Serste, 2012^44^ | Patient | CT | 0.74 | 0.81 | CT + MRI | 1: Concordant positive findings on two imaging techniques 2: Positive findings from at least one imaging technique | 1: 0.57 2: 0.98 | 1: 0.85 2: 0.81

CT = computed tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; US = ultrasound

a Ultrasound contrast-enhanced in all studies except Forner 2008 and Iavarone 2010

#### KQ1.a.i How is a particular technique’s test performance modified by use of various reference standards?

##### Ultrasound

There were too few studies of US in surveillance settings to evaluate effects of using different reference standards on estimate of accuracy.

In nonsurveillance settings, using patients as the unit of analysis, the sensitivity of US without contrast was 0.48 (95% CI 0.35 to 0.61, 5 studies) with explanted liver as the reference standard52,64,76,82,118 and 0.95 (0.87 to 0.98, 3 studies) using a nonexplant histopathological reference standard (Table 6).83,110,111 Using HCC lesions as the unit of analysis, the sensitivity of US without contrast was 0.34 (95% CI 0.22 to 0.47, 5 studies) with explanted liver as the reference standard52,76,84,99,118 and ranged from 0.72 to 0.75 with other reference standards (nonexplant histopathological, imaging or mixed histological and imaging or clinical criteria).56,70,83,111 The sensitivity of US with contrast was 0.66 (95% CI 0.47 to 0.81, 4 studies) using a nonexplant histopathological reference standard;51,69,106,119 one study evaluated a mixed reference standard (0.98, 95% CI 0.86 to 0.99).71

##### Computed Tomography

Using patients as the unit of analysis, there were no clear differences in diagnostic accuracy based on the use of different reference standards (explanted liver, other histopathological reference standard, or mixed histological and clinical/imaging), with sensitivity ranging from 0.81 to 0.88 (Table 7).82,110,111,118,126,129,130,133,154,155,164,175,186,192,197,201,202 Using HCC lesions as the unit of analysis, studies using explanted livers as the reference standard reported a lower sensitivity (0.67, 95% CI 0.59 to −0.75, 23 studies)42,99,118,120,121,125,126,129,130,133,136,138,169,175,177–179,182,191,202,208,212,216 than studies that used a nonexplant histopathological reference standard (0.86, 95% CI 0.78 to 0.91, 12 studies)69,119,127,135,143,145,148,157,158,176,207,209 or studies that used a mixed histological and clinical/imaging reference standard (0.80, 95% CI 0.75 to 0.84, 34 studies).56,123,124,131,139,144,146,149,153,155,161–168,172,183,184,188,192–195,198,204,210,211,215,217,219,220 Only three studies used a clinical/imaging reference standard (sensitivity 0.65, 95% CI 0.43 to 0.83).137,140,190 Estimates of specificity stratified by the reference standard used were somewhat lower for studies that used an explanted liver reference standard (0.82, 95% CI 0.74 to 0.88) than a nonexplant histopathological reference standard (0.95, 95% CI 0.88 to 0.98) or mixed reference standard (0.92, 95% CI 0.83 to 0.96), but estimates for the nonexplant reference standards were imprecise due to small numbers of studies.

##### Magnetic Resonance Imaging

Too few studies with patients as the unit of analysis used a nonexplant reference standard to evaluate effects of different reference standards on estimates of diagnostic accuracy. Eight of 10 studies used an explanted liver reference standard, with a pooled sensitivity of 0.87 (95% CI 0.78 to 0.92).82,118,126,129,259,260,263,273,276

Using HCC lesions as the unit of analysis, studies using explanted livers as the reference standard reported a lower sensitivity (0.69, 95% CI 0.60 to 0.76, 18 studies)99,118,121,126,129,136,138,179,191,212,224,227,236,238,259,260,263,276 than studies that used a nonexplant histopathological reference standard or mixed histological and imaging/clinical reference standard (sensitivity estimates ranged from 0.86 to 0.88) (Table 8). Estimates of specificity stratified by the reference standard were imprecise due to small numbers of studies.

##### Positron Emission Tomography

No study of FDG PET used explanted livers as the reference standard. Using patients as the unit of analysis, there were no clear differences in sensitivity between studies that used a nonexplant histological reference standard (0.46, 95% CI 0.28 to 0.65, 7 studies)110,111,154,297,309,315,316 and studies that used a mixed histological and imaging/clinical criteria reference standard (0.58, 95% CI 0.40–0.75, 8 studies), based on relatively wide and overlapping confidence intervals (Table 9). Four of the five studies that used HCC lesions as the unit of analysis used a nonexplant histological reference standard; the pooled sensitivity from this subset of studies was similar to the overall pooled estimate.297,303,309,319

#### KQ1.a.ii How is the comparative effectiveness modified by patient, tumor, technical, or other factors?

##### Ultrasound

In two studies that directly compared US with versus without contrast, there was no clear difference in sensitivity (−0.04, 95% CI −0.11 to 0.04) (Table 12).67,79 Excluding studies that used Doppler had little effect on estimates of sensitivity and specificity, and one study62 that directly compared use of Doppler versus no Doppler showed no clear effect on estimates of sensitivity.

Table 12 Pooled direct (within-study) comparisons of ultrasound for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity A (95% CI) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Detection of HCC (KQ 1)
Contrast (A) vs. no contrast (B) | Lesion (1), liver segment (1) | 0.79 (0.72 to 0.76)) | 0.81 (0.76 to 0.86) | −0.04 (−0.11 to 0.04); −0.04 (p=1.0) | 2 | 0.98 (0.96 to 0.997) | 0.92 (0.89 to 0.95) | 0.06 (0.02 to 0.10) | 1
Doppler (A) vs. no Doppler B) | Lesion | 0.67 (0.52 to 0.81) | 0.60 (0.45 to 0.74) | 0.07 (−0.13 to 0.28) | 1 | No data | No data | -- | --
Evaluation of focal liver lesions (KQ 2)
Contrast (A) vs. no contrast (B) | Lesion | 0.89 (0.83 to 0.93) | 0.39 (0.32 to 0.47) | 0.50 (0.41 to 0.58); <0.0001 (p=1.0) | 2 | 1.0 (1.0–1.0) | 0.94 (0.85 to 1.0) | 0.06 (−0.02 to 0.15) | 1
Doppler (A) vs. no Doppler (B) | Lesion | 0.69 (0.29 to 0.93) | 0.68 (0.28 to 0.92) | −0.01 (−0.15 to 0.13); 1.2 (p=0.34) | 2 | No data | No data | -- | --
Doppler (A) vs. no Doppler (B) (also contrast vs. no contrast) | Patient | 0.93 (0.88 to 0.97) | 0.78 (0.70–0.85) | 0.15 (0.06 to 0.23) | 1 | No data | No data | -- | --
Moderately or poorly-differentiated (A) vs. well-differentiated HCC lesion (B), with contrast | Lesion | 0.83 (0.55 to 0.95) | 0.43 (0.15 to 0.76) | 0.40 (0.17 to 0.64); 1.2 (p=0.17) | 3 | No data | No data | -- | --
HCC lesion ≥20 mm (A) vs. <20 mm (B)
- No contrast | Patient (1), lesion (7), liver segment (1) | 0.82 (0.68 to 0.91) | 0.34 (0.19 to 0.53) | 0.48 (0.39 to 0.57); 1.3 (p=0.005) | 9 | 0.80 (0.61 to 0.91) | 0.81 (0.62 to 0.92) | −0.01 (−0.13 to 0.11); 0.51 (p=0.08) | 2
- With contrast | Lesion | 0.94 (0.83 to 0.98) | 0.77 (0.53 to 0.91) | 0.17 (0.03 to 0.32); 1.3 (p=0.05) | 5 | 1.0 (26/26) | 1.0 (2/2) | Not calculated | 1

HCC = hepatocellular carcinoma

In studies that reported accuracy stratified by HCC lesion size, sensitivity of US without contrast was greater for lesions ≥2 cm (0.82, 95% CI 0.68 to 0.91) than for lesions <2 cm (0.34, 95% CI 0.19 to 0.53), for an absolute difference in sensitivity of 0.48 (95% CI 0.39 to 0.51, 9 studies).52,56,67,70,76,80,83,84,118 For US with contrast, sensitivity was 0.94 (95% CI 0.83 to 0.98) for lesions <2 cm and 0.77 (95% CI 0.53 to 0.91) for lesions <2 cm, for an absolute difference in sensitivity of 0.17 (95% CI 0.03 to 0.32, 5 studies)63,66,69,115,117 For US without contrast, sensitivity progressively improved from 0.09 (95% CI 0.02 to 0.29, 4 studies) for lesions <10 mm to 0.50 (95% CI 0.23 to 0.78, 4 studies) for lesions 10–20 mm and 0.88 (95% CI 0.66 to 0.96, 4 studies) for lesions >20 mm, for a difference of 0.37 (95% CI 0.18 to 0.57) for lesions >20 mm vs. 10–20 mm, and 0.41 (95% CI 0.19 to 0.63) for lesions 10–20 mm vs. <10 mm (Table 13).52,56,80,83 For US with contrast, three studies found sensitivity lower for lesions 10–20 mm (0.64, 95% CI 0.33 to 0.87) than >20 mm (0.91, 95% CI 0.71 to 0.98), for a difference of 0.26 (95% CI 0.04 to 0.48).63,69,115

Table 13 Direct comparisons of diagnostic accuracy according to lesion size <10, 10–20, and >20 mm

| Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Ultrasound without contrast
- <10 mm | 0.09 (0.02 to 0.29); 1.5 (p=0.08) | 4 | 0.93 (0.79 to 1.0) | 1 | 1.3 | 0.98
- 10–20 mm | 0.50 (0.23 to 0.78) | 4 | 0.60 (0.46 to 0.74) | 1 | 1.2 | 0.83
- >20 mm | 0.88 (0.66 to 0.96) | 4 | 0.53 (0.35 to 0.71) | 1 | 1.9 | 0.23
- Difference >20 mm vs. 10–20 mm | 0.37 (0.18 to 0.57) | 4 | −0.33 (−0.53 to −0.14) | 1 | -- | --
- Difference 10–20 mm vs. <10 mm | 0.41 (0.19 to 0.63) | 4 | −0.06 (−0.29 to 0.16) | 1 | -- | --
Ultrasound with contrast
- 10–20 | 0.64 (0.33 to 0.87); 1.2 (p=0.15) | 3 | 1.0 (26/26) | 1 | -- | --
- >20 mm | 0.91 (0.71 to 0.98) | 3 | 1.0 (2/2) | 1 | -- | --
- Difference >20 mm vs. 10–20 mm | 0.26 (0.04 to 0.48) | 3 | 0.0 | 0 | -- | --
Computed Tomography (CT)
- <10 mm | 0.32 (0.25 to 0.41); 0.51 (p<0.0001) | 21 | 0.69 (0.52 to 0.82); <0.0001 (p=0.9993) | 2 | 1.0 (0.59 to 1.8) | 0.99 (0.77 to 1.3)
- 10–20 mm | 0.74 (0.67 to 0.80) | 23 | 0.86 (0.74 to 0.93) | 2 | 5.3 (2.8 to 10) | 0.30 (0.23 to 0.40)
- >20 mm | 0.95 (0.92 to 0.97) | 20 | 0.90 (0.73 to 0.97) | 1 | 9.5 (3.2 to 28) | 0.06 (0.04 to 0.09)
- Difference >20 mm vs. 10–20 mm | 0.21 (0.15 to 0.26) | 20 | 0.04 (−0.10 to 0.18) | 2 | -- | --
- Difference 10–20 mm vs. <10 mm | 0.42 (0.36 to 0.48) | 21 | 0.17 (−0.004 to 0.35) | 1 | -- | --
Magnetic Resonance Imaging (MRI)
- <10 mm | 0.45 (0.34 to 0.56); 0.86 (p<0.0001) | 20 | 0.68 (0.23 to 0.94); 1.9 (p=0.08) | 2 | 1.4 (0.37 to 5.3) | 0.81 (0.43 to 1.5)
- 10–20 mm | 0.78 (0.69 to 0.85) | 21 | 0.83 (0.41 to 0.97) | 2 | 4.6 (0.93 to 23) | 0.26 (0.17 to 0.41)
- >20 mm | 0.97 (0.94 to 0.98) | 18 | 0.92 (0.56 to 0.99) | 2 | 12 (1.6 to 93) | 0.03 (0.02 to 0.06)
- Difference >20 mm vs. 10–20 mm | 0.19 (0.12 to 0.26) | 18 | 0.09 (−0.10 to 0.28) | 2 | -- | --
- Difference 10–20 mm vs. <10 mm | 0.33 (0.26 to 0.40) | 20 | 0.15 (−0.10 to 0.41) | 2 | -- | --

In three studies, sensitivity was 0.83 (95% CI 0.55 to 0.95) for moderately- or poorly-differentiated HCC lesions versus 0.43 (95% CI 0.15 to 0.76) for well-differentiated lesions, for an absolute difference in sensitivity of 0.40 (95% CI 0.17 to 0.64).53,69,89 Lesion depth and body mass index had no effect on estimates of sensitivity (Table 6). Two studies reported conflicting results for effects of cirrhosis on estimates of sensitivity, with one study reporting presence of cirrhosis associated with lower sensitivity than in patients without cirrhosis77 but the other with slightly higher sensitivity.83 Evidence on effects of liver volume, subcapsular location, presence of ascites, and underlying condition on estimates of accuracy was very sparse and showed no clear differences.77,84

##### Computed Tomography

Using patients with HCC as the unit of analysis, studies with a contrast rate ≥3 ml/s reported a higher sensitivity (0.87, 95% CI 0.77 to 0.93, 8 studies)110,126,129,130,133,164,175,192,202 than studies with a contrast rate <3 ml/s (0.71, 95% CI 0.50–0.85, 4 studies),82,118,186,197 with similar specificity, but there was no clear difference in studies that used HCC lesions as the unit of analysis (0.78, 95% CI 0.74 to 0.82, 58 studies and 0.74, 95% CI 0.59 to 0.85, 7 studies, respectively) (Table 14).

Table 14 Pooled direct (within-study) comparisons of computed tomography for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity A (95% CI ) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Section thickness 7. 5 (A) vs. 5 mm (B) | Lesion | 0.64 (0.58 to 0.70) | 0.72 (0.64 to 0.78) | −0.07 (−0.17 to 0.02); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
Section thickness 7.5 (A) vs. 5 mm (B), restricted to lesions <2 cm | Lesion | 0.39 (0.27 to 0.52) | 0.41 (0.22 to 0.59) | −0.01 (−0.24 to 0.21) | 1 | No data | No data | -- | --
Spectral CT (A) vs. standard CT (B) | Lesion | 0.97 (0.89 to 0.99) | 0.91 (0.80–0.97) | 0.05 (−0.02 to 0.12); 0.33 (p=0.39) | 3 | 0.98 (0.80–0.998) | 0.92 (0.64 to 0.99) | 0.06 (−0.06 to 0.18); 0.99 (p=0.59) | 2
Moderately or poorly (A) vs. well differentiated (B) HCC lesion | Lesion | 0.82 (0.66 to 0.91) | 0.50 (0.29 to 0.70) | 0.32 (0.19 to 0.45); 0.77 (p=0.05) | 5 | No data | No data | -- | --
HCC lesion ≥20 mm (A) vs. <20 mm (B) | Lesion (32); liver segment (3) | 0.94 (0.92 to 0.95) | 0.63 (0.57 to 0.69) | 0.31 (0.26 to 0.36); 0.50 (p<0.0001) | 34 | 0.92 (0.85 to 0.96) | 0.80 (0.71 to 0.86) | 0.12 (0.03 to 0.21); <0.0001 (p=1.0) | 2
HCC lesion ≥20 mm (A) vs. <20 mm (B), restricted to studies meeting minimum technical criteria^*^ | Lesion | 0.94 (0.89 to 0.97) | 0.60 (0.49 to 0.70) | 0.35 (0.25 to 0.44); 0.26 (p=0.04) | 7 | 0.90 (0.73 to 0.97) | 0.85 (0.74 to 0.92) | 0.05 (−0.09 to 0.19); <0.0001 (p=0.999) | 1
Cirrhosis (A) vs. no cirrhosis (B) | Lesion | 0.85 (0.77 to 0.91) | 0.81 (0.74 to 0.87) | 0.04 (−0.05 to 0.14); <0.0001 (p=1.0) | 2 | No data | No data | -- | --

* Defined as multidetector CT with ≥8 rows, contrast rate ≥3 ml/s, imaging phases include arterial, portal venous and delayed phase imaging >120 s after administration of contrast, and section thickness for enhanced images ≤5 mm;

HCC = hepatocellular carcinoma

Using patients with HCC as the unit of analysis, studies with delayed phase imaging reported somewhat higher sensitivity (0.89, 95% CI 0.81 to 0.94, 7 studies)82,111,118,129,154,186,197 than studies without delayed phase imaging (0.78, 95% CI 0.66 to 0.87, 7 studies),110,126,130,155,164,175,202 but there was no clear difference in studies that used HCC lesions as the unit of analysis (0.74, 95% CI 0.69 to 0.80, 42 studies and 0.81, 95% CI 0.75 to 0.86, 26 studies, respectively) (Table 7).

The type of CT scanner (≥8-row multidetector, <8-row multidetector, or nonmultidetector) had no clear effect on estimates of diagnostic accuracy. Based on two studies that directly compared spectral versus standard CT, there was no clear difference in estimates of diagnostic accuracy.180,181 Three studies compared effects of quantitative versus qualitative methods for evaluation of CT imaging findings on estimates of diagnostic accuracy.58,155,178 One study found use of quantitative arterial enhancement fraction mapping associated with higher sensitivity than qualitative assessment for all HCC lesions, as well as lesions ≤2 cm,155 but another study found qualitative assessment and quantitative assessment based on the arterial enhancement fraction both associated with a sensitivity of 1.0.^58^ In the other study, use of the percentage attention ratio threshold had no clear effect on sensitivity.178

In 34 studies that reported accuracy of CT stratified by HCC lesion size, sensitivity was greater for lesions ≥2 cm (0.94, 95% CI 0.92 to 0.95) than for lesions <2 cm (0.63, 95% CI 0.57 to 0.69), for an absolute difference in sensitivity of 0.31 (95% CI 0.26 to 0.36).56,66,117,118,120,123,125,126,130,131,138,140,142,145,146,155,157–160,167,169,174,183,184,188,192–195,202,207,208,215 Estimates were similar when the analysis was restricted to seven studies that met minimum technical criteria.56,131,158,183,184,195,215 Sensitivity progressively improved from 0.32 (95% CI 0.25 to 0.41, 21 studies) for lesions <10 mm, 0.74 (95% CI 0.67 to 0.80, 23 studies) for lesions 10–20 mm, and 0.95 (95% CI 0.92 to 0.97, 20 studies), for a difference of 0.21 (95% CI 0.15 to 0.26) for lesions >20 versus 10–20 mm and 0.42 (95% CI 0.36 to 0.48) for lesions 10–20 versus <10 mm (Table 13).42,56,69,123,125,126,130,134,138,140,141,146,157–160,174,176,192,195,200,202,207,215

In five studies that reported accuracy of CT stratified by degree of tumor differentiation, sensitivity was greater for moderately- or poorly-differentiated HCC lesions (0.82, 95% CI 0.66 to 0.91) than for well-differentiated lesions (0.50, 95% CI 0.29 to 0.70), for an absolute difference in sensitivity of 0.32 (95% CI 0.19 to 0.45).53,62,69,169,192

In two studies that directly compared sensitivity using a section thickness of 7.5 mm versus 5.0 mm, there was no clear difference (sensitivity 0.64, 95% CI 0.58 to 0.70 vs. 0.72, 95% CI 0.64 to 0.78, for a difference of −0.07, 95% CI −0.17 to 0.02) (Table 14).118,153

##### Magnetic Resonance Imaging

There were no clear differences in estimates of diagnostic accuracy when studies were stratified according to MRI scanner type (1.5 vs. 3.0 T), type of contrast (gadopentetate or gadodiamide vs. gadoxetic acid or gadobenate), imaging phases evaluated (with or without delayed phase imaging), timing of delayed phase imaging (>120 seconds vs. <120 seconds), or section thickness (≤5 mm vs. >5 mm) (Table 8). Relatively few studies evaluated 3.0 T MRI123,141,145,158,168,195,212,221,234,244,246,264,271,276,295 or MRI without delayed phase imaging,82,129,166,286 precluding strong conclusions regarding the effects of these technical factors on diagnostic accuracy.

In studies that directly compared diagnostic accuracy of MRI for HCC lesions using different types of contrast, hepatic specific contrast agents (gadoxetic acid or gadobenate) were associated with slightly higher sensitivity than nonhepatic-specific contrast agents (gadopentetate or gadodiamide) (0.83, 95% CI 0.75 to 0.90 vs. 0.74, 95% CI 0.62 to 0.83, difference 0.10, 95% CI 0.04 to 0.15, 6 studies), with no difference in specificity (Table 15).123,131,135,184,195,221 In studies restricted to HCC lesions <2 cm in diameter, the difference was somewhat larger (sensitivity 0.77, 95% CI 0.68 to 0.84 vs. 0.62, 95% CI 0.52 to 0.71, difference 0.15, 95% CI 0.08 to 0.22, 7 studies).56,123,135,184,195,221,241

Table 15 Pooled direct (within-study) comparisons of magnetic resonance imaging for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity A (95% CI ) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^(p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Gadoxetic acid or gadobenate (A) vs. gadopentetate or gadodiadmide (B) | Lesion | 0.83 (0.75 to 0.90) | 0.74 (0.62 to 0.83) | 0.10 (0.04 to 0.15); 0.36 (p=0.04) | 6 | 0.91 (0.86 to 0.95) | 0.89 (0.83 to 0.93) | 0.02 (−0.04 to 0.09); 0.002 (p=0.88) | 3
Gadoxetic acid or gadobenate (A) vs. gadopentetate or gadodiadmide (B), for HCC lesions <2 cm | Lesion | 0.77 (0.68 to 0.84) | 0.62 (0.52 to 0.71) | 0.15 (0.08 to 0.22); 0.20 (p=0.05) | 7 | 0.93 (0.82 to 0.98 | 0.91 (0.79 to 0.97) | 0.02 (−0.05 to 0.09); 0.14 (p=0.51) | 2
Diffusion-weighted imaging (A) vs. no diffusion-weighted imaging (B) | Lesion (7), patient (1) | 0.81 (0.74 to 0.86) | 0.81 (0.75 to 0.86) | −0.01 (−0.05 to 0.03); 0.14 (p=0.05) | 8 | 0.92 (0.83 to 0.97) | 0.81 (0.65 to 0.91) | 0.11 (0.02 to 0.20); 0.73 (p=0.13) | 5
Diffusion-weighted imaging (A) vs. no diffusion-weighted imaging (B) for HCC lesion <2 cm | Lesion | 0.78 (0.62 to 0.88) | 0.67 (0.50–0.81) | 0.10 (0.02 to 0.18); 0.75 (p=0.03) | 5 | 0.97 (0.31 to 0.9995) | 0.91 (0.15 to 0.999) | 0.06 (−0.16 to 0.28); 4.4 (p=0.37) | 2
Moderately or poorly (A) vs. well differentiated (B) HCC lesion | Lesion | 0.68 (0.44 to 0.86) | 0.37 (0.17 to 0.62) | 0.31 (0.13 to 0.49) | 3 | No data | No data | -- | --
HCC lesion ≥20 mm (A) vs. <20 mm (B) | Lesion (28); liver segment (1) | 0.96 (0.93 to 0.97) | 0.66 (0.58 to 0.74) | 0.29 (0.23 to 0.36); 0.74 (p<0.0001) | 29 | 0.94 (0.77 to 0.99) | 0.80 (0.50 to 0.94) | 0.14 (−0.01 to 0.30); 1.9 (p=0.03) | 4
HCC lesion ≥20 mm (A) vs. <20 mm (B), gadopentetate or gadodiamide contrast | Lesion (15); liver segment (1) | 0.94 (0.90 to 0.96) | 0.54 (0.43 to 0.63) | 0.40 (0.32 to 0.49); 0.58 (p=0.0003) | 16 | 0.96 (0.82 to 0.99) | 0.85 (0.61 to 0.95) | 0.11 (−0.01 to 0.23); 0.46 (p=0.45) | 2
HCC lesion ≥20 mm (A) vs. <20 mm (B), gadoxetic acid or gadobenate contrast | Lesion | 0.97 (0.95 to 0.99) | 0.78 (0.71 to 0.84) | 0.19 (0.13 to 0.25); 0.29 (p=0.01) | 12 | 0.93 (0.77 to 0.98) | 0.90 (0.80 to 0.96) | 0.03 (−0.08 to 0.15); <0.0001 (p=1.0) | 1
HCC lesion ≥20 mm (A) vs. <20 mm (B), restricted to studies meeting minimum technical criteria^*^ | Lesion | 0.97 (0.95 to 0.99) | 0.73 (0.65 to 0.79) | 0.25 (0.18 to 0.31); 0.30 (p=0.004) | 13 | 0.93 (0.76 to 0.98) | 0.90 (0.79 to 0.96) | 0.03 (−0.09 to 0.15); <0.0001 (p=1.0) | 1

* Defined as 1.5 or 3.0 T MRI with contrast, imaging phases included arterial, portal venous, and delayed or hepatobiliary phases; delayed phase imaging >−120 s following contrast administration, and section thickness for enhanced images ≤5 mm

HCC = hepatocellular carcinoma

In eight studies that directly compared diagnostic accuracy of MRI with versus without diffusion-weighted imaging, there was no difference in sensitivity.235,244,248,269,273,277,287,289 Restricted to HCC lesions <2 cm in diameter, diffusion-weighted imaging was associated with slightly higher sensitivity (0.78, 95% CI 0.62 to 0.88 vs. 0.67, 95% CI 0.50–0.81, difference 0.10, 95% CI 0.02 to 0.18, 5 studies).245,246,273,277,287

In 29 studies that reported accuracy of MRI stratified by HCC lesion size, sensitivity was greater for lesions 2 cm (0.96, 95% CI 0.93 to 0.97) than for lesions <2 cm (0.66, 95% CI 0.58 to 0.74), for an absolute difference in sensitivity of 0.29 (95% CI 0.23 to 0.36)56,118,123,126,131,134,138,140,145,158,184,191,193,195,207,221,226,227,234,245,259,260,263,266,270,273,277,284,292. The difference was greater in studies of nonhepatic-specific contrast (0.40, 95% CI 0.32–0.49, 16 studies)118,126,138,140,193,226,234,245,259,260,263,266,273,277,284,292 than in studies of hepatic-specific contrast (0.19, 95% CI 0.13 to 0.25, 12 studies).56,123,131,145,158,184,191,195,207,221,227,270 Sensitivity progressively improved from 0.45 (95% CI 0.34 to 0.56, 20 studies) for lesions <10 mm, 0.78 (95% CI 0.69 to 0.85, 21 studies) for lesions 10–20 mm, and 0.97 (95% CI 0.94 to 0.98, 18 studies) for lesions >20 mm, for a difference of 0.19 (95% CI 0.12 to 0.26) for >20 versus 10–20 mm and 0.33 (95% CI 0.26 to 0.40) for 10–20 versus <10 mm (Table 13).69,123,126,131,134,138,140,141,158,191,195,200,207,221,226,227,246,259,260,273,292

In three studies that reported accuracy of MRI stratified by degree of tumor differentiation, sensitivity was greater for moderately- or poorly-differentiated HCC lesions (0.68, 95% CI 0.44 to 0.86) than for well-differentiated lesions (0.37, 95% CI 0.17 to 0.62), for an absolute difference in sensitivity of 0.31 (95% CI 0.31 to 0.49).69,136,191 In two studies, sensitivity decreased as Child-Pugh class increased (class A 0.97, 95% CI 0.90–0.99, class B 0.91, 95% CI 0.74 to 0.97, class C 0.79 (0.54 to 0.93).244,284

##### Positron Emission Tomography

In studies that directly compared accuracy of PET using different tracers, FDG PET was associated with lower sensitivity that ^11^C-acetate PET when either patients (0.58 vs. 0.81, for a difference of −0.23, 95% CI −0.34 to −0.13, 3 studies297,302,309) or HCC lesions (0.52 vs. 0.79, for a difference of −0.27, 95 %CI −0.36 to −0.17, 3 studies297,309,319) were the unit of analysis. FDG PET was also associated with lower sensitivity than dual tracer PET with FDG and ^11^C-acetate127,317 or ^18^F-choline PET,313,314 but evidence was limited to 1 or 2 studies for each of these comparisons.

Using patients as the unit of analysis, sensitivity of FDG PET (0.39, 95% CI 0.24 to 0.56, 8 studies)110,111,154,307,308,315,316,318 was lower than sensitivity of FDG PET/CT (0.65, 95% CI 0.50–0.78, 7 studies) (Table 16).297,302,309,310,313,314,317. Similar findings were seen in studies that used ^11^C-acetate as the tracer and HCC lesions as the unit of analysis, but the number of studies was small (0.68, 95% CI 0.46 to 0.84, 2 studies306,319 versus 0.85, 95% CI 0.67 to 0.94, 2 studies127,309).

Table 16 Pooled direct (within-study) comparisons of positron emission tomography for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity A (95% CI) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Detection of intrahepatic HCC (KQ 1)
FDG (A) vs. ^11^C-acetate (B) PET | Patient | 0.58 (0.44 to 0.70) | 0.81 (0.70–0.89) | −0.23 (−0.34 to −0.13) ; 0.13 (p=0.23) | 3 | No data | No data | -- | --
| Lesion | 0.52 (0.45 to 0.59) | 0.79 (0.72 to 0.84) | −0.27 (−0.36 to −0.17) | 3 | No data | No data | -- | --
FDG (A) vs. FDG + ^11^C-acetate (B) PET | Patient | 0.63 (0.52 to 0.74) | 0.89 (−0.83 to 0.96) | −0.26 (−0.39 to −0.13) | 1 | No data | No data | -- | --
| Lesion | 0.33 (0.21 to 0.45) | 0.95 (0.89 to 1.0) | −0.62 (−0.75 to −0.49) | 1 | No data | No data | -- | --
FDG (A) vs. ^18^F-fluorocholine (B) | Patient | 0.65 (0.50–0.78) | 0.91 (0.78 to 0.96) | −0.26 (−0.42 to −0.09) | 2 | 0.94 (0.83 to 1.0) | 0.47 (0.23 to 0.71) | 0.47 (0.23 to 0.71) | 1
| Lesion | 0.67 (0.56 to 0.78) | 0.84 (0.76 to 0.93) | −0.17 (−0.31 to −0.03) | 1 | 0.91 (0.82 to 1.0) | 0.62 (0.45 to 0.78) | 0.29 (0.10–0.48) | 1
Moderately- or poorly-differentiated (A) vs. well-differentiated (B) HCC lesion, FDG PET | Patient (2), lesion (4) | 0.72 (0.59 to 0.83) | 0.39 (0.26 to 0.55) | 0.33 (0.20 to 0.46); 0.32 (p=0.05) | 6 | No data | No data | -- | --
Moderately- or pooly-differentiated (A) vs. well-differentiated (B) HCC lesion, ^11^C-acetate PET | Lesion (2) | 0.80 (0.65 to 0.89) | 0.76 (0.67 to 0.83) | 0.04 (−0.11 to 0.18); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
Detection of metastatic HCC (KQ 3)
FDG (A) vs. ^11^C-acetate (B) PET | Patient | 0.79 (0.71 to 0.87) | 0.64 (0.54 to 0.73) | 0.15 (0.03 to 0.28) | 1 | 0.91 (0.79 to 1.0) | 0.95 (0.87 to 1.0) | −0.05 (−0.19 to 0.10) | 1
FDG (A) vs. FDG + ^11^C-acetate (B) PET | Patient | 0.79 (0.71 to 0.87) | 0.98 (0.95 to 1.0) | −0.19 (−0.28 to −0.11) | 1 | 0.91 (0.79 to 1.0) | 0.86 (0.72 to 1.0) | 0.05 (−0.14 to 0.23) | 1
PET vs. PET/CT | Metastatic HCC lesion | 0.90 (0.82 to 0.97) | 0.98 (0.95 to 1.0) | −0.09 (−0.17 to 0.0) | 1 | No data | No data | -- | --

CT = computed tomography; FDG = 18F-fluorodeoxyglucose; HCC = hepatocellular carcinoma; PET = positron emission tomography

In five studies that reported accuracy of FDG PET stratified by HCC lesion size, sensitivity was consistently higher for larger lesions (Table 17).111,297,305,309,316 Data were not pooled due to differences in the tumor size categories evaluated, with small samples in some studies. One study reported a similar pattern for ^11^C-acetate PET, although the difference was less pronounced, due to higher sensitivity for lesions 2 to 5 cm in diameter.309 Another study reported high sensitivity of ^11^C-acetate PET for lesions ≤5 cm or >5 cm.297

Table 17 Test performance of ^18^F-fluorodeoxyglucose positron emission tomography for hepatocellular carcinoma, stratified by lesion size

Study, Year | HCC Location | Unit of Analysis | Sensitivity: FDG | Sensitivity: ^11^C-acetate
Cheung, 2011^297^ | Intrahepatic | Patient | ≤5 cm: 0.24 (7/29) >5 cm: 0.62 (18/29) | ≤5 cm: 0.97 (28/29) >5 cm: 0.97 (28/29)
Kim YK, 2010 (3)305 | Intrahepatic | Lesion | <1 cm: 0.0 (0/21) ≥1 cm: 0.33 (2/6) | --
Park JW, 2008^309^ | Intrahepatic | Lesion | ≥1 to 2 cm: 0.27 (6/22) ≥2 to 5 cm: 0.48 (22/46) ≥5 cm: 0.93 (39/42) | ≥1 to 2 cm: 0.32 (7/22) ≥2 to 5 cm: 0.78 (36/46) ≥5 cm: 0.95 (40/42)
Trojan, 1999^111^ | Intrahepatic | Patient | <5 cm: 0.12 (1/8) ≥5 cm: 1.0 (6/6) | --
Wolfort, 2010^316^ | Intrahepatic | Lesion | ≤5 cm: 0.25 (2/8) >5 cm: 1.0 (5/5) | --
Kim YK, 2010 (3)305 | Extrahepatic | Lesion | <1 cm: 0.0 (0/2) ≤1 cm: 0.93 (13/14) | --
Lee JE, 2012^171^ | Lung | Patient | <1 cm: 0.20 (2/10) ≥1 cm: 0.92 (12/13) | --
Park JW, 2008^309^ | Extrahepatic | Lesion | ≤1 to 2 cm: 0.80 (16/20) ≥2 cm: 0.93 (14/15) | ≤1 to 2 cm: 0.65 (13/20) ≥2 cm: 0.93 (14/15)
Sugiyama, 2004^311^ | Extrahepatic | Lesion | <1 cm: 0.12 (1/8) ≥1 cm: 0.83 (24/29) | --

FDG = ^18^F-fluorodeoxyglucose; HCC = hepatocellular carcinoma

Six studies of FDG PET found lower sensitivity for more poorly-differentiated lesions than for more well-differentiated lesions (0.39, 95% CI 0.26 to 0.55 vs. 0.72, 95% CI 0.59 to 0.83, for a difference of −0.33, 95% CI −0.46 to −0.20) (Table 18).111,309,313,316,317 In two studies of ^11^C-acetate PET306,309 and one study of ^18^F-fluorochlorine,313 this pattern was not observed, due in part to higher sensitivity for more well-differentiated lesions.

Table 18 Test performance of ^18^F-fluorodeoxyglucose positron emission tomography for hepatocellular carcinoma, stratified by degree of tumor differentiation

Study, Year | Unit of Analysis | Sensitivity: FDG | Sensitivity: 11C-Acetate
Li, 2006 | Lesion | -- | Well- or moderately differentiated: 0.67 (8/12) Poorly differentiated: 0.62 (8/13)
Park JW, 2008 | Lesion | Grade I or II: 0.50 (35/70) Grade III or IV: 0.87 (27/31) | Grade I or II: 0.71 (50/70) Grade III or IV: 0.87 (27/31)
Talbot, 2010 | Lesion | Well-differentiated: 0.59 (19/32) Poorly-differentiated: 0.74 (28/38) | --
Trojan, 1999 | Patient | Well-differentiated: 0.0 (0/6) Moderately or poorly differentiated: 0.88 (7/8) | --
Wolfort, 2010 | Lesion | Well-differentiated: 0.67 (4/6) Moderately or poorly differentiated: 0.75 (6/8) | --
Wu, 2011 | Patient | Well differentiated: 0.36 (5/14) Moderately or poorly differentiated: 0.74 (23/31) | --
Yamamoto, 2008 | Lesion | Moderately differentiated: 0.42 (5/12) Poorly differentiated: 0.75 (3/4) | Moderately differentiated: 0.75 (9/12) Poorly differentiated: 0.25 (1/4)

FDG = ^18^F-fluorodeoxyglucose

#### KQ1.b What is the comparative effectiveness of imaging-based strategies on intermediate outcomes related to clinical decisionmaking?

One study (n=163) evaluated effects of US without contrast versus CT for HCC surveillance in veterans with cirrhosis.322 It was rated moderate risk of bias due to unclear allocation concealment methods and open-label design. It found no clear difference between imaging strategies in rates of HCC detection. US without contrast was associated with more subsequent CT tests (17 vs. 8) but similar numbers of MRI (9 vs. 12); the total number of subsequent imaging tests was similar (28 vs. 25). The strategy of surveillance with US with contrast was associated with lower cost per HCC detected ($12,069 vs. $18,768).

#### KQ1.c What is the comparative effectiveness of imaging-based strategies on clinical and patient-centered outcomes?

One cluster randomized controlled trial (n=18,816) conducted in China compared screening every 6 months with noncontrast US plus serum AFP versus no screening in persons 35 to 79 years of age (mean 42 years) with HBV infection (n=17,250) or chronic hepatitis without HBV infection (n=1566) (Appendix H).50 Technical details regarding the US methods used were not reported. Patients with an AFP >20 g/l or solid liver lesion on US underwent repeat testing; patients with repeatedly positive results underwent further diagnostic evaluation, including repeat US and CT or MRI “when necessary”. Final diagnoses were based on liver biopsy or long-term followup. The trial was rated as high risk of bias; important methodological shortcomings included inadequate description of randomization or allocation concealment methods, unblended design, failure to report attrition, and failure to control for clustering affects (Appendix C). In addition, outcomes were based on physician reporting or data from the Shanghai Cancer Registry, but the completeness and accuracy of outcomes ascertainment could not be determined.

All screened patients underwent 5 to 10 cycles of screening; compliance with screening was 58 percent. The trial found screening associated with lower risk of HCC-related mortality (32 vs. 54 deaths, rate ratio 0.63, 95% CI 0.41 to 0.98) at 5-year followup. Screening was associated with a trend towards more HCC diagnoses (86 vs. 67, rate ratio 1.37, 95% CI 0.99 to 1.89), but also more Stage I (subclinical or early stage) cancers (52 vs. 0), with more patients undergoing surgical resection. All-cause mortality and harms were not reported.

One other randomized trial323 compared screening versus no screening, but did not meet inclusion criteria because AFP testing was the primary mode of screening, with US only obtained to evaluate high AFP values. It found no difference between screening and no screening in risk of all-cause or HCC mortality.

Two trials compared different US screening intervals (Appendix H).48,49 Technical details regarding the US methods used were not reported. One cluster randomized trial in Taiwan (n=744) found no difference between 4- versus 12-month intervals in risk of mortality after 4 years in patients with HBV or HCV infection (57% vs. 56%), even though more frequent screening was associated with higher likelihood of early stage disease (37.5 vs. 6.7%, p=0.017).49 The second trial (n=1278) in France and Belgium found no difference between 3- versus 6-month intervals in all-cause mortality in patients with cirrhosis related to alcohol use or viral hepatitis.48

One randomized trial (n=163) of surveillance among veterans with cirrhosis found no difference between surveillance with US without contrast versus CT in risk of death due to HCC, but was underpowered to detect differences (6.0% or 5/83 vs. 8.8% or 7/80).322

#### KQ1.d What are the adverse effects or harms associated with imaging-based surveillance strategies?

Two studies that met inclusion criteria reported harms associated with diagnostic imaging for HCC. One study reported 25 percent of patients (n=178) undergoing MRI experienced an adverse event following gadoxetic acid administration, with 56 events classified as mild and 6 as moderate.144 There were two events classified as serious (anemia and hypotension); neither was considered related to the study drug. Twenty-one drug-related adverse events were reported in 10 percent of the patients, with nausea (1.7%) the most frequently reported event. One other study reported no clear differences between CT with contrast at 3 ml/s versus 5 ml/s in rate of overall adverse events (13% and 15%), discomfort (8% vs. 2%), or adverse events not related to contrast agents (5% vs. 3%). 204 No study reported rates of adverse events associated with use of microbubble contrast agents in US, and harms were not reported in randomized trials of screening with imaging.

## Key Question 2 What is the comparative effectiveness of imaging techniques, used singly, in combination, or in sequence, in diagnosing hepatocellular carcinoma among individuals in whom a focal liver lesion has been detected?

### Description of Included Studies

Fifty-four studies43,44,53,55,57–60,63,65,66,68,72,73,75,80,81,85–89,91,93,96–98,100,101,104,107,109,113–117,128,134,142,147,228–230,232,233,245,247,266,279,282,291,298,304 evaluated diagnostic accuracy of imaging tests in diagnosing HCC among individuals in whom an abnormal lesion has been detected and 19 studies95,105,108,156,181,206,213,214,231,239,240,243,265,269,272,278,287,289,293 evaluated the accuracy of imaging tests for distinguishing HCC from another specific type of liver lesion.

No study compared effects of different imaging modalities or strategies on clinical decisionmaking or on clinical or patient-centered outcomes. One study reported harms.91

### Key Points

#### Test Performance

- For evaluation of focal liver lesions, using patients with HCC as the unit of analysis:
  ○ US with contrast: Sensitivity was 0.87 (95% CI 0.79 to 0.92, 12 studies) and specificity was 0.91 (95% CI 0.83 to 0.95, 8 studies), for a LR+ of 9.6 (95% CI 5.1 to 18) and LR− of 0.14 (95% CI 0.09 to 0.23). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ US without contrast: Sensitivity was 0.78 (95% CI 0.69 to 0.86) in 1 study; specificity was not reported. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ CT: Sensitivity was 0.86 (95% CI 0.75 to 0.92, 8 studies) and specificity was 0.88 (95% CI 0.76 to 0.95, 5 studies), for a LR+ of 7.4 (95% CI 3.3 to 17) and LR− of 0.16 (95% CI 0.09 to 0.30). (Strength of Evidence: moderate for sensitivity, low for specificity)
  ○ MRI: Sensitivity was 0.77 (95% CI 0.66 to 0.84, 4 studies) and specificity was 0.81 (95% CI 0.52 to 0.94, 4 studies), for a LR+ of 4.0 (95% CI 1.4 to 12) and LR− of 0.29 (95% CI 0.21 to 0.39). (Strength of Evidence: low for sensitivity and specificity)
- For evaluation of focal liver lesions, using HCC lesions as the unit of analysis:
  ○ US with contrast: Sensitivity was 0.87 (95% CI 0.80 to 0.92, 21 studies) and specificity was 0.91 (95% CI 0.85 to 0.95, 10 studies) for a LR+ of 9.8 (95% CI 5.7 to 17) and LR− of 0.14 (95% CI 0.09 to 0.23). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ CT: Sensitivity was 0.79 (95% CI 0.67 to 0.87, 13 studies) and specificity was 0.90 (95% CI 0.37 to 0.99, 6 studies), for a LR+ of 7.7 (95% CI 0.71 to 84) and LR− of 0.24 (95% CI 0.15 to 0.38). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ MRI: Sensitivity was 0.81 (95% CI 0.72 to 0.87, 14 studies) and specificity was 0.93 (95% CI 0.80 to 0.98, 11 studies), for a LR+ of 12 (95% CI 3.8 to 39) and LR− of 0.21 (95% CI 0.15 to 0.30). (Strength of Evidence: moderate for sensitivity and specificity)
  ○ PET: Sensitivity was 0.56 to 0.57 and specificity was 1.0 in two studies of FDG PET. (Strength of Evidence: low for sensitivity and specificity)
- For distinguishing HCC lesions from non-HCC hepatic lesions:
  ○ US with contrast: One study found US with sulfur hexafluoride contrast associated with a sensitivity of 0.94 (62/66) and a specificity of 0.68 (23/34) for distinguishing hypervascular HCC from focal nodular hyperplasia, using quantitative methods and one study found US with perflubutane contrast associated with a sensitivity of 0.59 (32/54) and specificity of 1.0 (13/13) for distinguishing small (<3 cm), well-differentiated HCC lesions from regenerative nodules. (Strength of Evidence: low for sensitivity and specificity)
  ○ CT: Five studies evaluated accuracy of CT for distinguishing HCC from non-HCC lesions, but the non-HCC lesions varied in the studies, precluding strong conclusions. (Strength of Evidence: low for sensitivity and specificity)
  ○ MRI: Four studies reported inconsistent results for distinguishing small (<2 to 3 cm) hypervascular HCC lesions from hypervascular pseudolesions, with sensitivity of 0.47 and 0.52 in two studies, and 0.91 and 0.92 in the other two. Specificity was 0.93 or higher in all four studies. Eight other studies evaluated accuracy of MRI for distinguishing HCC from other non-HCC lesions, but the non-HCC lesions varied in the studies, precluding strong conclusions. (Strength of Evidence: moderate for sensitivity and specificity)
- For direct (within-study) comparisons of imaging modalities, using patients with HCC as the unit of analysis:
  ○ US without contrast versus CT: Sensitivity was 0.78 (95% CI 0.70 to 0.85) versus 0.89 (95% CI 0.84 to 0.95), for a difference of −0.12 (95% CI −0.21 to −0.02), based on one study. (Strength of Evidence: low for sensitivity, insufficient for specificity)
  ○ US with contrast versus CT: Sensitivity was 0.91 (0.85 to 0.94) versus 0.88 (95% CI 0.81 to 0.92), for a difference of 0.03 (95% CI −0.02 to 0.08), based on five studies. (Strength of Evidence: moderate for sensitivity, low for specificity)
  ○ MRI versus CT: Sensitivity was 0.81 (95% CI 0.70 to 0.92) versus 0.74 (95% CI 0.62 to 0.87), for a difference of 0.06 (−0.10 to 0.23), based on one study. (Strength of Evidence: low for sensitivity and specificity)
- Direct (within-study) comparisons of imaging modalities, using HCC lesions as the unit of analysis
  ○ US with contrast versus CT: Sensitivity was 0.91 (95% CI 0.85 to 0.94) versus 0.88 (95% CI 0.81 to 0.92), for a difference of 0.03 (95% CI −0.02 to 0.08), based on five studies. (Strength of Evidence: moderate for sensitivity, insufficient for specificity)
  ○ US with contrast versus MRI: Sensitivity was 0.79 (95% CI 0.65 to 0.94) versus 0.83 (95% CI 0.69 to 0.97), for a difference of −0.03 (95% CI −0.24 to 0.17), based on one study. (Strength of Evidence: low for sensitivity and specificity)
  ○ MRI versus CT: One study found MRI associated with higher sensitivity (0.84, 95% CI 0.76 to 0.92 versus 0.62, 95% CI 0.52 to 0.72, for a difference of 0.22, 95% CI 0.09 to 0.35) but lower specificity (0.36, 95% CI 0.20 to 0.52 versus 0.72, 95% CI 0.58 to 0.87, for a difference of −0.36, 95% CI −0.58 to −0.15) than CT. (Strength of Evidence: low for sensitivity and specificity)
- Multiple imaging modalities
  ○ In four studies in which positive results with multiple modality imaging were defined as concordant typical findings for HCC on two imaging modalities, sensitivity was lower than with a single modality (difference in sensitivity ranged from 0.09 to 0.27), with no clear difference in specificity. In three studies in which positive results with multiple modality imaging were defined as typical findings for HCC on at least one of the imaging techniques, sensitivity was higher than with a single modality (increase in sensitivity ranged from 0.09 to 0.25), with no clear difference in specificity. One study found that a sequential imaging strategy, in which a second imaging test was only performed for indeterminant results on initial CT, increased sensitivity for HCC from 0.53 to 0.74 to 0.79. (Strength of Evidence: moderate)
- No study used explanted liver as the reference standard. There were no clear differences across imaging modalities in estimates of diagnostic accuracy in analyses stratified by use of different nonexplant reference standards. (Strength of Evidence: moderate for sensitivity and specificity)
- Effects of lesion size and degree of tumor differentiation: See Key Question 1
- Other factors
  ○ US: In two studies that directly compared US with versus without contrast, US with contrast was associated with sensitivity of 0.89 (95% CI 0.83 to 0.93) and US without contrast with a sensitivity of (0.39) 95% CI 0.32 to 0.47), for a difference in sensitivity of 0.50 (95% CI 0.41 to 0.58). Based on across-study comparisons, there were no clear differences in sensitivity between different US contrast agents; no study directly compared different contrast agents. There were no differences in sensitivity of US based on lesion depth (3 studies) or body mass index (2 studies). (Strength of Evidence: low)
  ○ CT: Evidence on effects of technical parameters (type of CT scanner, use of delayed phase imaging, section thickness) was limited by small numbers of studies, wide confidence intervals and methodological limitations, precluding reliable conclusions. Two studies found no clear difference in sensitivity of CT for HCC in patients with versus without cirrhosis. (Strength of Evidence: low)
  ○ MRI: There were no clear differences in estimates of sensitivity based on the type of MRI machine (3.0 T versus 1.5 T), type of contrast, use of delayed phase imaging, timing of delayed phase imaging, and section thickness. Estimates were similar when studies that used diffusion-weighted imaging were excluded. (Strength of Evidence: low)

#### Clinical Decisionmaking

- No study compared effects of different imaging modalities or strategies on clinical decisionmaking. (Strength of Evidence: insufficient)

#### Clinical and Patient-Centered Outcomes

- No study compared effects of different imaging modalities or strategies on clinical outcomes. (Strength of Evidence: insufficient)

#### Harms

- One study of US (with and without contrast) and CT reported harms, but did not stratify results by imaging technique. The overall rate of adverse drug-related events was 10 percent, with all events classified as mild. (Strength of Evidence: insufficient)

### Detailed Synthesis

#### KQ2.a What is the comparative test performance of imaging techniques for diagnosing HCC in patients with a focal liver lesion?

##### Ultrasound

For evaluation of focal liver lesions, using patients with HCC as the unit of analysis, sensitivity of US with contrast was 0.87 (95% CI 0.79 to 0.92, 12 studies) and specificity was 0.91 (95% CI 0.83 to 0.95, 8 studies), for a LR+ of 9.6 (95% CI 5.1 to 18) and LR− of 0.14 (95% CI 0.09 to 0.23) (Table 6; Figure 17).53,58–60,63,73,87,88,97,100,101,113 Sensitivity was lower in studies restricted to HCC lesions <2–3 cm (0.79, 95% CI 0.56 to 0.92),59,60,73,113 but excluding these studies had little effect on the pooled estimates (Table 6). Using HCC lesions as the unit of analysis, sensitivity of US with contrast was 0.87 (95% CI 0.80 to 0.92, 21 studies) and specificity was 0.91 (95% CI 0.85 to 0.95, 10 studies) for a LR+ of 9.8 (95% CI 5.7 to 17) and LR− of 0.14 (95% CI 0.09 to −0.23) (Figure 18).43,53,55,57,63,65,66,68,75,81,85,86,89,93,96,104,107,109,114,116,117 Sensitivity was lower in studies restricted to HCC lesions <2–3 cm (0.73, 95% CI 0.55 to 0.85, 7 studies),43,55,65,75,89,96,116 but excluding these studies had little effect on the pooled estimates (Table 6). Sensitivity analyses based on study country, use of prospective design, use of Doppler, excluding high risk of bias studies, avoidance of case-control design, and interpretation of imaging blinded to the reference standard had little impact on estimates, and did not reduce heterogeneity.

Figure 17 Test performance of ultrasound with contrast in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma

This figure is a forest plot that displays the test performance of ultrasound with contrast in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 12 studies, with a combined sensitivity of 0.87 (95% confidence interval: 0.079 to 0.92) and the tau-squared value is 0.59, p = 0.0046. Specificity was reported or calculated for 8 studies, with a combined specificity of 0.91 (95% confidence interval: 0.83 to 0.95) and the tau-squared value is 0.62, p = 0.037.

Figure 18 Test performance of ultrasound with contrast for evaluation of focal liver lesions for identification of hepatocellular carcinoma lesions

This figure is a forest plot that displays the test performance of ultrasound with contrast for evaluation of focal liver lesions for identification of hepatocellular carcinoma lesions. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 23 studies, with a combined sensitivity of 0.87 (95% confidence interval: 0.80 to 0.92) and the tau-squared value is 1.19, p < 0.0001. Specificity was reported or calculated for 11 studies, with a combined specificity of 0.91 (95% confidence interval: 0.85 to 0.95) and the tau-squared value is 0.51, p = 0.012.

One study found US with sulfur hexafluoride contrast associated with a sensitivity of 0.94 (62/66) and specificity of 0.68 (23/34) for distinguishing hypervascular HCC from focal nodular hyperplasia, based on quantitative analysis of US findings,95 and one study found US with perflubutane contrast associated with a sensitivity of 0.59 (32/54) and specificity of 1.0 (13/13) for distinguishing small (<3 cm ), well-differentiated HCC lesions from regenerative nodules.108

##### Computed Tomography

For evaluation of focal liver lesions, using patients with HCC as the unit of analysis, sensitivity of CT was 0.86 (95% CI 0.75 to 0.92, 8 studies) and specificity was 0.88 (95% CI 0.76 to 0.95, 5 studies), for a LR+ of 7.4 (95% CI 3.3 to 17) and LR− of 0.16 (95% CI 0.09 to −0.30) (Table 7; Figure 19).44,53,58,60,87,91,101,134 Using HCC lesions as the unit of analysis, sensitivity was 0.79 (95% CI 0.67 to 0.87, 13 studies) and specificity was 0.90 (95% CI 0.37 to 0.99, 6 studies), for a LR+ of 7.7 (95% CI 0.71 to 84) and LR− of 0.24 (95% CI 0.15 to 0.38) (Figure 20).43,53,55,66,75,81,89,96,117,128,134,142,147 Excluding high risk of bias studies, excluding studies restricted to HCC lesions <2–3 cm and restricting the analysis to studies that were performed in the United States or Europe, used a prospective design, used a confidence rating scale, avoided a case-control design, or used blinded interpretation of imaging findings had little effect on estimates of sensitivity.

Figure 19 Test performance of CT in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma

CT = computed tomography

This figure is a forest plot that displays the test performance of CT in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 8 studies, with a combined sensitivity of 0.86 (95% confidence interval: 0.75 to 0.92) and the tau-squared value is 0.65 p = 0.036. Specificity was reported or calculated for 5 studies, with a combined specificity of 0.88 (95% confidence interval: 0.76 to 0.95) and the tau-squared value is 0.64, p = 0.083.

Figure 20 Test performance of CT in evaluation of focal liver lesions for hepatocellular carcinoma lesions

CT = computed tomography

This figure is a forest plot that displays the test performance of CT in evaluation of focal liver lesions for hepatocellular carcinoma lesions. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 13 studies, with a combined sensitivity of 0.79 (95% confidence interval: 0.67 to 0.87) and the tau-squared value is 0.97, p = 0.001. Specificity was reported or calculated for 6 studies, with a combined specificity of 0.90 (95% confidence interval: 0.37 to 0.99) and the tau-squared value is 4.39, p = 0.110.

Five studies evaluated accuracy of CT for distinguishing HCC from non-HCC lesions (Table 19). The non-HCC lesions varied in the studies, precluding strong conclusions. In three studies, sensitivity ranged from 0.84 to 0.95 and specificity 0.84 to 1.0 for distinguishing HCC from hemangioma,181 focal nodular hyperplasia,214 or various non-HCC lesions.156 One study found CT associated with a sensitivity of 0.54 (18/33) and specificity of 0.96 (26/27) for distinguishing hypervascular HCC lesions <2 cm from hypervascular pseudolesions206 and another study found spectral CT associated with a sensitivity of 0.84 and specificity of 0.50 for distinguishing HCC from angiomyolipma based on assessment of the enhancement pattern, and sensitivity of 0.91 to 1.0 and specificity of 1.0 based on various quantitative parameters.213

Table 19 Studies on accuracy of imaging for differentiating hepatocellular carcinoma from other hepatic lesions

Study, Year | Imaging Modality | HCC Lesion | Lesion for Differentiation | Unit of Analysis | Reference Standard | Sensitivity | Specificity | Diagnostic Criteria
Pei, 2012^95^ | US with contrast | Hypervascular HCC | Focal nodular hyperplasia | Patient | Histological | 0.94 (62/66) | 0.68 (23/34) | Based on quantitative analysis of contrast-enhanced US findings
Kim SE, 2011^156^ | CT | HCC | Non-HCC lesion (including cholangiocarcinoma, metastasis, and FNH) | Lesion | Histological | 0.85 (140/164) | 0.90 (38/42) | Based on arterial enhancement and venous washout
Lv, 2011^181^ | CT | Hypervascular HCC lesion <3 cm | Hemangioma | Lesion | Mixed histological and clinical/imaging | 0.91 (32/35) | 0.87 (26/30) | Based on enhancement pattern on standard CT images
Sun, 2010^206^ | CT | Hypervascular HCC lesion <2 cm | Hypervascular pseudolesion | Patient | Mixed histological and clinical/imaging | 0.54 (18/33) | 0.96 (26/27) | Confidence level score of 4–5 on 1 to 5 scale, based on enhancement pattern
Yu, 2013^214^ | CT | HCC | Focal nodular hyperplasia | Lesion | Histological | 0.95 (40/42) | 1.0 (16/16) | Criteria for diagnosis not defined
Yu, 2013^213^ | CT (spectral) | HCC | Angiomyolipoma | Lesion | Histological | 0.84–1.0 (n=45) | 0.50–1.0 (n=8) | Specificity 0.50 based on enhancement pattern, 0.91 to 1.0 based on various quantitative parameters
Filippone, 2010^231^ | MRI | HCC | Dysplastic nodule | Lesion | Mixed histological and clinical/imaging | 0.92 (36/39) | 0.93 (14/15) | Confidence level score 3–4 on 1 to 4 scale, based on enhancement pattern including hepatobiliary phase imaging
Ito, 2004^239^ | MRI | Hypervascular HCC lesion <3 cm | Hypervascular pseudolesion | Lesion | Mixed histological and clinical/imaging | 0.52 (21/40) | 1.0 (30/30) | Based on rapid central washout after early enhancement and peritumoral coronal enhancement
Jeong, 1999^240^ | MRI | Hypervascular HCC lesion | Hemangioma | Lesion | Mixed histological and clinical/imaging | 0.94 (31/33) | 0.82 (15/18) | Based on contrast to noise ratio of 7.00 on imaging 60 s after administration of contrast
Kamura, 2002^243^ | MRI | Hypervascular HCC lesion <2 cm | Hypervascular pseudolesion | Lesion | Mixed histological and clinical/imaging | 0.47 (9/19) | 0.93 (13/14) | Based on hyperintensity on T2 to weighted images
Lee MH, 2011^265^ | MRI | Well-differentiated HCC lesion | Benign nodule (regenerative nodule or dysplastic nodule) | Lesion | Histological | 0.85 (39/46) | 0.42 (10/24) | Based on hypointensity on hepatobiliary phase imaging
Motosugi, 2010^269^ | MRI | Hypervascular HCC lesion (mean 16 mm) | Hypervascular pseudolesion (mean 11 mm) | Lesion | Mixed histological and clinical/imaging | 0.91 (112/123) | 0.91 (29/32) | Based on hepatocyte-phase signal intensity ratio of 0.84 on gadoxetic-enhanced images
Park, 2013^272^ | MRI | HCC lesion <2 cm | Benign lesions (dysplastic nodules, regenerative nodules, hemangiomas, arterioportal shunts) | Lesion | Histological | 0.97–0.98 (100–101/103) | 0.97 (30/33) | Based on meeting one or more of 5 categories based on enhanced and diffusion-weighted imaging
Sun, 2010^206^ | MRI | Hypervascular HCC lesion <2 cm | Hypervascular pseudolesion | Patient | Mixed histological and clinical/imaging | 0.92 (30.5/33) | 0.94 (25/27) | Confidence level score 4–5 on 1 to 5 scale, based on enhancement pattern
Takahashi, 2013^108^ | MRI | Well-differentiated HCC lesion <3 cm | Regenerative nodules | Lesion | Histological | 0.87 (47/54) | 0.46 (6/13) | Based on enhancement pattern with hepatobiliary phase imaging
Vandecaveye, 2009^287^ | MRI | HCC lesion^a^ | Benign lesions (regenerative nodules, low-grade dysplastic nodules, stable lesions, or other benign lesions) | Lesion | Mixed histological and clinical/imaging | 0.81 (50/62) | 0.65 (34/52) | Based on T2- and T1- signal intensity ratio and enhancement pattern
Xu, 2010^289^ | MRI | HCC lesion | Dysplastic nodule | Lesion | Histological | 0.82 (33/40) | 0.58 (11/18) | Confidence level score 4–5 on 1 to 5 scale, based on enhancement pattern
Yu, 2002^293^ | MRI | HCC lesion <4 cm | Cavernous hemangioma | Lesion | Mixed histological and clinical/imaging | 0.88 (137/155) | 0.15 (31/207) | Based on absence of transient peritumoral enhancement
Takahashi, 2013^108^ | US | Well-differentiated HCC lesion <3 cm | Regenerative nodules | Lesion | Histological | 0.44 (24/54) | 1.0 (13/13) | Based on enhancement pattern with hepatobiliary phase imaging

CT = computed tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; US = ultrasound

a Including two cholangiocarcinomas and two high-grade dysplastic nodules

##### Magnetic Resonance Imaging

For evaluation of focal liver lesions, using patients with HCC as the unit of analysis, sensitivity of MRI was 0.77 (95% CI 0.66 to 0.84, 4 studies) and specificity was 0.81 (95% CI 0.52 to −0.94, 4 studies), for a LR+ of 4.0 (95% CI 1.4 to 12) and LR− of 0.29 (95% CI 0.21 to 0.39) (Table 8; Figure 21).44,59,100,134

Figure 21 Test performance of MRI in evaluation of focal liver lesions for patients with hepatocellular carcinoma

MRI = magnetic resonance imaging

This figure is a forest plot that displays the test performance of MRI in evaluation of focal liver lesions for patients with hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 4 studies, with a combined sensitivity of 0.77 (95% confidence interval: 0.66 to 0.84) and the tau-squared value is 0.14, p = 0.216. Specificity was reported or calculated for 4 studies, with a combined specificity of 0.81 (95% confidence interval: 0.52 to 0.94) and the tau-squared value is 1.60, p = 0.189.

Using HCC lesions as the unit of analysis, sensitivity was 0.81 (95% CI 0.72 to 0.87, 14 studies and specificity was 0.93 (95% CI 0.80 to 0.98, 11 studies), for a LR+ of 12 (95% CI 3.8 to 39) and LR− of 0.21 (95% CI 0.15 to 0.30) (Figure 22).43,65,75,134,229,230,232,245,247,253,266,279,282,291 Excluding studies that were restricted to HCC lesions <2 cm increased the sensitivity to 0.90 (95% C I 0.86 to 0.93, 5 studies)229,230,266,282,291 and excluding studies that were restricted to hypervascular HCC lesions decreased the sensitivity (0.75, 95% CI 0.64 to 0.84, 9 studies).43,65,75,134,232,247,253,279,291 No study was rated high risk of bias.

Figure 22 Test performance of MRI in evaluation of focal liver lesions for hepatocellular carcinoma lesions

MRI = magnetic resonance imaging

This figure is a forest plot that displays the test performance of MRI in evaluation of focal liver lesions for hepatocellular carcinoma lesions. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 14 studies, with a combined sensitivity of 0.81 (95% confidence interval: 0.73 to 0.88. Specificity was reported or calculated for 11 studies, with a combined specificity of 0.92 (95% confidence interval: 0.78 to 0.97).

Twelve studies evaluated accuracy of MRI for distinguishing HCC from non-HCC lesions (Table 19).108,206,231,239,240,243,265,269,272,287,289,293 Four studies reported inconsistent results for distinguishing small (<2 to 3 cm) hypervascular HCC lesions from hypervascular pseudolesions, with sensitivity 0.47 and 0.52 in two studies,239,243 and 0.91 and 0.92 in the other two.206,269 Specificity was 0.93 or higher in all four studies. There was no clear pattern based on factors such as risk of bias, the diagnostic criteria applied, the reference standard, or the unit of analysis to account for the observed heterogeneity.

One study found MRI associated with poor specificity (0.15, 31/207) for distinguishing HCC lesions from cavernous hemangioma, with sensitivity of 0.88 (137/155), based on the absence of transient peritumoral enhancement.293 Another study reported a sensitivity of 0.94 (31/33) and specificity of 0.82 (15/18) for distinguishing hypervascular HCC from hemangioma, based on quantitative evaluation of contrast-to-noise ratio.240 One study reported high (>0.90) sensitivity and specificity of MRI with hepatobiliary phase imaging for distinguishing HCC from dysplastic nodules231 and one study reported high sensitivity and specificity of MRI with diffusion-weighted imaging for distinguishing small HCC from various benign lesions.272 Four other studies reported high sensitivity (0.81 to 0.87) but low specificity (0.42 to 0.65) for distinguishing HCC from dysplastic nodules,289 regenerative nodules,108 or various benign lesions.265,287

##### Positron Emission Tomography

For evaluation of focal liver lesions, using patients with HCC as the unit of analysis, two studies reported similar sensitivity of FDG PET (0.56 to 0.57) and specificity of 1.0.^298,304^

##### Ultrasound Versus Computed Tomography

Using patients with HCC as the unit of analysis, based on five studies that directly compared diagnostic accuracy of imaging modalities, sensitivity was similar for US with contrast and CT (0.91, 95% CI 0.85 to 0.94 versus 0.88, 95% CI 0.81 to 0.92) (Table 20).53,58,87,91,101 Using HCC lesions as the unit of analysis, US with contrast and CT were also associated with similar sensitivity (0.92, 95% CI 0.88 to 0.96 versus 0.89, 95% CI 0.83 to 0.93, for a difference of 0.04, 95% CI −0.02 to 0.09), based on four studies.53,66,81,117 There were also no differences between US with contrast and CT for HCC lesions <2 cm (0.78, 95% CI 0.61 to 0.89 versus 0.71, 95% CI 0.52 to 0.85, for a difference of 0.07, 95% CI −0.01 to 0.15), based on seven studies,43,55,66,75,89,96,117 or for well-differentiated HCC lesions, based on two studies.53,89

Table 20 Pooled direct (within-study) comparisons of test performance of one imaging modality versus another imaging modality for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity A (95% CI) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Identification of lesions (KQ 1)
US without contrast (A) vs. CT (B) | Patient | 0.68 (0.54 to 0.80) | 0.80 (0.68 to 0.88) | −0.12 (−0.20 to −0.03); 0.36 (p=0.15) | 6 | 0.92 (0.84 to 0.96) | 0.94 (0.87 to 0.97) | −0.01 (−0.05 to 0.02); 0.62 (p=0.07) | 5
- Excluding high risk of bias studies | Patient | 0.71 (0.58 to 0.82) | 0.82 (0.71 to 0.89) | −0.10 (−0.18 to −0.02); 0.19 (p=0.25) | 5 | 0.91 (0.81 to 0.96) | 0.94 (0.86 to 0.98) | −0.03 (−0.07 to 0.01); 0.73 (p=0.11) | 4
US without contrast (A) vs. CT (B) | Lesion | 0.55 (0.43 to 0.66) | 0.66 (0.54 to 0.76) | −0.11 (−0.18 to −0.04); 0.11 (p=0.28) | 3 | 0.83 (0.65 to 0.93) | 0.93 (0.83 to 0.98) | −0.10 (−0.20 to −0.008); 0.44 (p=0.29) | 2
- HCC lesions <2 cm | Lesion | 0.46 (0.30–0.63) | 0.54 (0.37 to 0.70) | −0.07 (−0.17 to 0.02); 0.31 (p=0.27) | 3 | 0.72 (0.61 to 0.80) | 0.80 (0.71 to 0.86) | −0.08 (−0.20 to 0.04); 0.002 (p=0.85) | 2
US with contrast (A) vs. CT (B) | Lesion | 0.58 (0.37 to 0.77) | 0.74 (0.54 to 0.87) | −0.16 (−0.32 to −0.01); 0.50 (p=0.15) | 3 | No data | No data | -- | --
- HCC lesions <2 cm | Lesion | 0.30 (0.17 to 0.43) | 0.44 (0.30–0.58) | −0.14 (−0.32 to 0.05) | 1 | No data | No data | -- | --
US without contrast (A) vs. MRI (B) | Patient | 0.61 (0.48 to 0.74) | 0.81 (0.69 to 0.89) | −0.19 (−0.30 to −0.08); 0.01 (p=0.79) | 3 | 0.94 (0.87 to 0.97) | 0.82 (0.66 to 0.91) | 0.13 (0.03 to 0.22); 0.01 (p=0.40) | 3
US without contrast (A) vs. MRI (B) | Lesion | 0.57 (0.42 to 0.71) | 0.79 (0.67 to 0.88) | −0.22 (−0.31 to −0.14); 0.22 (p=0.28) | 3 | 0.75 (0.66 to 0.82) | 0.78 (0.70–0.85) | −0.03 (−0.13 to 0.06); 0.001 (p=0.89) | 2
- HCC lesion <2 cm | Lesion | 0.40 (0.18 to 0.67) | 0.65 (0.38 to 0.85) | −0.26 (−0.36 to −0.15); 0.60 | 2 | 0.71 (0.60–0.80) | 0.84 (0.76 to 0.89) | −0.13 (−0.25 to −0.01); 0.006 | 2
US with contrast (A) vs. MRI (B) | Lesion | 0.54 (0.25 to 0.80) | 0.70 (0.40–0.89) | −0.16 (−0.30 to −0.02); 0.71 (p=0.31) | 2 | No data | No data | -- | --
- HCC lesions <2 cm | Lesion | 0.30 (0.17 to 0.43) | 0.42 (0.28 to 0.56) | −0.12 (−0.31 to 0.07) | 1 | No data | No data | -- | --
- Well-differentiated HCC Lesion | Lesion | 0.43 (0.14 to 0.77) | 0.36 (0.11 to 0.72) | 0.07 (−0.19 to 0.33); 0.87 (p=0.34) | 2 | No data | No data | -- | --
MRI (A) vs. CT (B) | Patient | 0.88 (0.53 to 0.98) | 0.82 (0.41 to 0.97) | 0.06 (−0.05 to 0.17); 3.0 (p=0.21) | 4 | 0.84 (0.70–0.92) | 0.91 (0.82 to 0.96) | −0.08 (−0.16 to 0.00); 0.40 (p=0.21) | 4
- Excluding high risk of bias studies | Patient | 0.82 (0.75 to 0.88) | 0.75 (0.68 to 0.81) | 0.07 (−0.02 to 0.17); <0.0001 | 2 | 0.80 (0.57 to 0.92) | 0.91 (0.77 to 0.97) | −0.11 (−0.23 to 0.01); 0.44 | 2
MRI (A) vs. CT (B) | Lesion | 0.81 (0.77 to 0.84) | 0.72 (0.67 to 0.77) | 0.09 (0.06 to 0.12); 0.37 (p<0.0001) | 28 | 0.85 (0.76 to 0.92) | 0.90 (0.82 to 0.95) | −0.05 (−0.10 to 0.01); 0.43 (p=0.01) | 6
- Excluding high risk of bias studies | Lesion | 0.80 (0.73 to 0.85) | 0.73 (0.66 to 0.79) | 0.07 (0.04 to 0.10); 0.50 (p<0.0001) | 19 | 0.87 (0.78 to 0.93) | 0.93 (0.86 to 0.96) | −0.05 (−0.10 to 0.00); 0.37 (p=0.03) | 5
- Non-hepatic specific contrast | Lesion | 0.81 (0.74 to 0.87) | 0.74 (0.65 to 0.81) | 0.08 (0.04 to 0.11); 0.39 (p=0.01) | 11 | 0.62 (0.51 to 0.72) | 0.86 (0.77 to 0.93) | −0.24 (−0.37 to −0.11); <0.0001 (p=1.0) | 2
- Hepatic specific contrast | Lesion | 0.80 (0.74 to 0.85) | 0.70 (0.62 to 0.77) | 0.10 (0.06 to 0.14); 0.41 (p=0.0003) | 15 | 0.93 (0.88 to 0.96) | 0.91 (0.85 to 0.94) | 0.02 (−0.03 to 0.07); 0.01 (p=0.78) | 4
- HCC lesions <2 cm | Lesion | 0.59 (0.43 to 0.73) | 0.46 (0.32 to 0.62 | 0.12 (0.03 to 0.22); 0.25 (p=0.27) | 3 | 0.84 (0.73 to 0.91) | 0.80 (0.67 to 0.89) | 0.04 (−0.06 to 0.14); 0.12 (p=0.41) | 2
Evaluation of previously identified lesion (KQ 2)
US without contrast (A) vs. CT (B) | Patient | 0.78 (0.70–0.85) | 0.89 (0.84 to 0.95) | −0.12 (−0.21 to −0.02) | 1 | No data | No data | -- | --
US with contrast (A) vs. CT (B) | Patient | 0.91 (0.85 to 0.94) | 0.88 (0.81 to 0.92) | 0.03 (−0.02 to 0.08); 0.15 (p=0.13) | 5 | 0.93 (0.87 to 0.96) | 0.94 (0.88 to 0.97) | −0.01 (−0.06 to 0.05); 0.07 (p=0.32) | 2
- Excluding high risk of bias studies | Patient | 0.90 (0.79 to 0.95) | 0.87 (0.76 to 0.94) | 0.02 (−0.05 to 0.10); 0.28 (p=0.31) | 3 | 0.93 (0.87 to 0.97) | 0.94 (0.88 to 0.97) | −0.01 (−0.06 to 0.05); 0.08 (p=0.45) | 2
US with contrast (A) vs. CT (B) | Lesion | 0.94 (0.89 to 0.97) | 0.91 (0.85 to 0.94) | 0.03 (−0.03 to 0.09); <0.0001 (p=1.0) | 3 | No data | No data | -- | --
- HCC lesion <2 cm | Lesion | 0.78 (0.61 to 0.89) | 0.71 (0.52 to 0.85) | 0.07 (−0.01 to 0.15); 1.1 (p-0.02) | 7 | 0.87 (0.62 to 0.97) | 0.94 (0.77 to 0.98) | −0.06 (−0.15 to 0.03); 2.4 (p=0.09) | 4
- Well-differentiated HCC Lesion | Lesion | 0.55 (0.25 to 0.82) | 0.55 (0.25 to 0.82) | 0.00 (−0.30 to 0.30); 0.48 (p=0.40) | 2 | No data | No data | -- | --
US with contrast (A) vs. MRI (B) | Patient | 0.79 (0.65 to 0.94) | 0.83 (0.69 to 0.97) | −0.03 (−0.24 to 0.17) | 1 | 0.79 (0.68 to 0.90) | 0.75 (0.64 to 0.87) | 0.04 (−0.12 to 0.20) | 1
- HCC lesion <2 cm | Patient | 0.52 (0.39 to 0.64) | 0.62 (0.49 to 0.74) | −0.10 (−0.27 to 0.08) | 1 | 0.93 (0.84 to 1.0) | 0.97 (0.90–1.0) | −0.03 (−0.15 to 0.08) | 1
US with contrast (A) vs. MRI (B) | Lesion | 0.79 (0.65 to 0.94) | 0.83 (0.69 to 0.97) | −0.03 (−0.24 to 0.17) | 1 | 0.79 (0.68 to 0.90) | 0.75 (0.64 to 0.87) | 0.04 (−0.12 to 0.20) | 1
- HCC lesion <2 cm | Lesion | 0.53 (0.28 to 0.76) | 0.68 (0.43 to 0.86) | −0.16 (−0.30 to −0.02); 0.72 (p=0.25) | 3 | 0.95 (0.85 to 0.98) | 0.98 (0.91 to 0.99) | −0.03 (−0.08 to 0.02); 0.38 (p=0.43) | 3
MRI (A) vs. CT (B) | Patient | 0.81 (0.70–0.92) | 0.74 (0.62 to 0.87) | 0.06 (−0.10 to 0.23) | 1 | 0.85 (0.72 to 0.99) | 0.81 (0.66 to 0.96) | 0.04 (−0.16 to 0.24) | 1
MRI (A) vs. CT (B) | Lesion | 0.84 (0.76 to 0.92) | 0.62 (0.52 to 0.72) | 0.22 (0.09 to 0.35) | 1 | 0.36 (0.20–0.52) | 0.72 (0.58 to 0.87) | −0.36 (−0.58 to −0.15) | 1
Identification of metastatic HCC (KQ 4)
PET/CT (A) vs. CT (B) | Patient (2), lesion (1) | 0.82 (0.61 to 0.93) | 0.85 (0.66 to 0.95) | −0.03 (−0.12 to 0.060); 0.75 (p=0.17) | 3 | Insufficient data | Insufficient data | -- | --

CT = computed tomography; HCC = hepatocellular carcinoma; MRI =magnetic resonance imaging; PET = positron emission tomography; US = ultrasound

##### Ultrasound Versus Magnetic Resonance Imaging

Using patients with HCC as the unit of analysis, one study found no difference in sensitivity between US with contrast and MRI (0.79, 95% CI 0.65 to 0.94 versus 0.83, 95% CI 0.69 to 0.97).100

##### Magnetic Resonance Imaging Versus Computed Tomography

Using patients with HCC as the unit of analysis, one study found no clear difference between MRI and CT in sensitivity or specificity.44 Using HCC lesions as the unit of analysis, one study found MRI associated with higher sensitivity (0.84, 95% CI 0.76 to 0.92 vs. 0.62, 95% CI 0.52 to 0.72, for a difference of 0.22, 95% CI 0.09 to 0.35) but lower specificity (0.36, 95% CI 0.20–0.52 vs. 0.72, 95% CI 0.58 to 0.87, for a difference of −0.36, 95% CI −0.58 to −0.15) than CT.134 Sensitivity was also lower when the analysis was restricted to HCC lesions <2–3 cm, but results were based on only three studies and did not reach statistical significance (0.65, 95% CI 0.04 to 0.99 vs. 0.50, 95% CI 0.02 to 0.98, for a difference of 0.15, 95% CI 0.00 to 0.30).43,75,134

##### Multiple Imaging Modalities

Seven studies compared diagnostic performance of single versus multiple modality imaging for diagnosis of HCC in patients with focal liver lesions (Table 11).43,44,55,59,75,96,134 Five reported diagnostic accuracy for small (<2 or <3 cm) HCC lesions.43,59,75,96,134 In four studies in which positive results with multiple modality imaging were defined as concordant typical findings for HCC on two imaging modalities, sensitivity was lower than with a single modality (decrease insensitivity ranged from 0.09 to 0.27), with no clear difference in specificity.43,44,59,75 In three studies in which positive results with multiple modality imaging were defined as typical findings for HCC on at least one of the imaging techniques, sensitivity was higher than with a single modality (increases in sensitivity ranged from 0.09 to 0.25), with no clear difference in specificity.43,44,96 One study found that a sequential imaging strategy in which a second imaging test was only performed for indeterminant results on initial CT increased sensitivity from 0.53 to 0.74 to 0.79.^75^ Two other studies also found multiple imaging modalities associated with higher sensitivity than a single technique, but did not clearly describe criteria used to define a positive result with multiple modality imaging.55,134 There were too few studies to evaluate the comparative diagnostic performance of different combinations of imaging modalities.

#### KQ2.a.i How is a particular technique’s test performance modified by use of various reference standards?

##### Ultrasound

No study evaluated diagnostic accuracy of US for evaluation of focal liver lesions using explanted livers as the reference standard. There were no clear differences in sensitivity for nonexplant reference standards (histopathological, imaging/clinical criteria, or mixed) based on pooled sensitivity (range 0.89 to 0.94), using either patients with HCC or HCC lesions as the unit of analysis (Table 6).

##### Computed Tomography

No study of CT for evaluation of focal liver lesions used explanted livers as the reference standard. Accuracy was slightly lower for studies that used a nonexplant histopathological reference standard (0.83, 95% CI 0.73 to 0.90, 6 studies)53,66,81,89,96,128 than a mixed (histological with clinical/imaging criteria) reference standard (0.93, 95% CI 0.82 to 0.98),117,142 but only two studies used a mixed reference standard (Table 7).

##### Magnetic Resonance Imaging

No study of MRI for evaluation of focal liver lesions used explanted livers as the reference standard. Using HCC lesions as the unit of analysis, sensitivity was the same for one study that used a nonexplant histopathological reference standard (0.91, 95% CI 0.81 to 0.96), 95% CI 0.53 to 0.85)266 and four studies that used a mixed (histological with clinical/imaging criteria) reference standard (0.90, 95% CI 0.86 to 0.94),229,230,282,291 (Table 8).

#### KQ2.a.ii How is the comparative effectiveness modified by patient, tumor, technical, or other factors?

##### Ultrasound

Using HCC lesions as the unit of analysis, studies of US with contrast reported higher sensitivity (0.87, 95% CI 0.80 to 0.92, 21 studies)43,53,55,57,63,65,66,68,75,81,85,86,89,93,96,104,107,109,114,116,117 than studies of US without contrast (0.62, 95% CI 0.18 to 0.93, 4 studies)72,98,115,116 (Table 6). Using patients with HCC as the unit of analysis, all studies except for one80 evaluated US with contrast. Two studies that directly compared US with versus without contrast using HCC lesions as the unit of analysis found US with contrast associated with higher sensitivity (0.89, 95% CI 0.83 to 0.93) than US without contrast (0.39, 95% CI 0.32 to 0.47), for a difference in sensitivity of 0.50 (95% CI 0.41 to 0.58) (Table 12).115,116 Based on patients as the unit of analysis, sensitivity was similar in studies that used perflubutane (0.95, 95% CI 0.89 to 0.97, 2 studies)86,87 or sulfur hexafluoride contrast (0.87, 95% CI 0.82 to 0.91, 6 studies).53,58,63,97,100,101 Using HCC lesions as the unit of analysis, sensitivity was similar for sulfur hexafluoride (0.91, 95% CI 0.84 to 0.96, 7 studies),53,57,63,66,81,93,114 perflubutane (0.86, 95% CI 0.67 to 0.95, 2 studies),68,86 and galactose (0.94, 95% CI 0.85 to 0.97, 4 studies).85,107,109,117 No study directly compared different types of contrast agents.

One study using patients with HCC as the unit of analysis compared US with contrast versus without contrast (sensitivity 0.93, 95% CI 0.88 to 0.97 vs. 0.78, 95% CI 0.70–0.85, for a difference of 0.15, 95% CI 0.06 to 0.23), but results were potentially confounded by use of Doppler in the contrast group.91 One study that used HCC lesions as the unit of analysis that directly compared US with versus without Doppler found no clear difference in sensitivity.104 Effects of lesion size, tumor differentiation, lesion depth, and body mass index are presented in the results for Key Question 1.

##### Computed Tomography

Using HCC lesions as the unit of analysis, there were no clear differences in sensitivity between studies of multidetector CT with ≥8 or <8 rows, studies with versus without delayed phase imaging, or studies with section thickness ≤5 vs. >5 mm (Table 7). However, several estimates based on these technical parameters were imprecise.

Two studies found no clear difference in sensitivity of CT for HCC in patients with versus without cirrhosis.156,181 Effects of lesion size and tumor differentiation on accuracy are presented in the results for Key Question 1.

##### Magnetic Resonance Imaging

Using HCC lesions as the unit of analysis, sensitivity was the same for studies that used non-hepatobiliary229,266,291 or hepatobiliary230,282 contrast (Table 8). Effects of lesion size and tumor differentiation on accuracy are presented in the results for Key Question 1. Among five studies that were not restricted to HCC lesions <2–3 cm, all used 1.5 T MRI, included delayed or hepatobiliary phase imaging, and had section thickness of ≤5 mm.

#### KQ2.b What is the comparative effectiveness of the various imaging techniques on intermediate outcomes related to clinical decisionmaking?

No study evaluated the comparative effectiveness of different imaging techniques on clinical decisionmaking.

#### KQ2.c What is the comparative effectiveness of the various imaging techniques on clinical and patient-centered outcomes?

No study evaluated the comparative effectiveness of different imaging techniques on clinical and patient-centered outcomes.

#### KQ2.d What are the adverse effects or harms associated with imaging-based diagnostic strategies?

One study of US (with and without contrast) and CT reported harms, but did not stratify results by imaging technique. The overall rate of adverse drug-related events was 10 percent, with all events classified as mild.91

## Key Question 3 What is the comparative effectiveness of imaging techniques used singly, in combination, or in sequence, in staging HCC among patients diagnosed with HCC?

### Description of Included Studies

Six studies reported test performance of various imaging techniques for staging of patients with HCC based on TNM criteria.42,61,122,126,127,216 Ten studies reported test performance of PET for detection of metastatic disease.152,171,189,300,309–311,316,317,320

Seven studies reported effects of imaging on transplant decisions82,102,122,127,179,202,208 and one study reported comparative effects of imaging on clinical and patient-centered outcomes.152,171,189,300,309–311,316,317,320 No study reported harms associated with imaging for HCC staging.

### Key Points

#### Test Performance

- For staging, using TNM criteria, using explanted liver or surgical resection reference standard:
  ○ CT: The proportion correctly staged ranged from 28 to 58 percent, the proportion overstaged from 2 to 27 percent, and the proportion understaged from 25 to 52 percent, based on six studies. (Strength of Evidence: moderate)
  ○ MRI: The proportion correctly staged was 40 to 75 percent, the proportion overstaged 3.1 to 31 percent, and the proportion understaged 19 to 31 percent, based on three studies. (Strength of Evidence: low)
  ○ PET: One study found 26 percent of patients were correctly staged with FDG PET and 91 percent with ^11^C-choline PET. (Strength of Evidence: low)
  ○ MRI versus CT: Two studies reported similar staging accuracy. (Strength of Evidence: low)
- For identification of metastatic disease, using patients with metastatic HCC as the unit of analysis:
  ○ PET: Sensitivity of FDG PET was 0.85 (95% CI 0.71 to 0.93, 6 studies) and specificity was 0.93 (95% CI 0.89 to 0.95, 5 studies), for a LR+ of 11 (95% CI 7.8 to 17) and LR− of 0.16 (95% CI 0.08 to 0.33). One study that directly compared sensitivity of FDG PET to ^11^C-acetate PET reported comparable sensitivity (0.79 vs. 0.71), although sensitivity was higher when both tracers were used (0.98). (Strength of Evidence: low for sensitivity and specificity)
  ○ PET/CT versus CT: Three studies found no difference in sensitivity (0.82, 95% CI 0.61 to 0.93 vs. 0.85, 95% CI 0.66 to 0.95). (Strength of Evidence: low)
- For identification of metastatic disease, using metastatic HCC lesions as the unit of analysis:
  ○ PET: Sensitivity of FDG PET was 0.82 (95% CI 0.72 to 0.90, 5 studies). One study that directly compared sensitivity of FDG to ^11^C-acetate PET reported comparable sensitivity (0.86 vs. 0.77, respectively). (Strength of Evidence: low for sensitivity, insufficient for specificity)
- Evidence was insufficient to determine effects of different reference standards on test performance:
  ○ For accuracy of staging using TNM criteria, all but one study used explanted livers as the reference standard. (Strength of Evidence: insufficient for sensitivity and specificity)
  ○ For accuracy of PET for identifying metastatic HCC, five of the six studies that used patients with metastatic HCC as the reference standard used mixed histological and imaging/clinical criteria as the reference standard. For studies that used metastatic HCC lesions as the unit of analysis, different reference standards were each evaluated in only one or two studies. (Strength of Evidence: insufficient for sensitivity and specificity)
- Effects of patients, tumor, or technical factors on test performance:
  ○ For accuracy of staging using TNM criteria, no study evaluated effects of patient-level characteristics or other factors on accuracy of imaging techniques for staging. (Strength of Evidence: insufficient)
  ○ For identifying metastatic HCC, estimates for sensitivity were too imprecise to determine how use of PET versus PET/CT affected test performance. In one study that directly compared sensitivity of PET versus PET/CT for identifying metastatic HCC lesions, there was no clear difference in sensitivity. (Strength of Evidence: low)
  ○ Four studies of PET with FDG found sensitivity increased as lesion size increased, but the number of lesions <1 cm was small (total of 20). (Strength of Evidence: low)
  ○ Eight studies reported test performance of FDG PET stratified by location of metastasis. In most studies, sensitivity was higher for lymph and bone metastasis than for lung metastasis, but samples were small, precluding strong conclusions. (Strength of Evidence: low)

#### Clinical Decisionmaking

- Transplant eligibility, using Milan criteria
  ○ CT: The proportion correctly assessed for transplant eligibility ranged from 40 to 96 percent. Three studies reported that the proportion of patients who met transplant criteria based on CT but exceeded criteria based on the reference standard was 3.5 to 7.8 percent. Two studies found that 2.3 and 16 percent of patients who underwent transplantation based on Milan criteria had no HCC lesions on examination of explanted livers. (Strength of Evidence: moderate)
  ○ CT versus MRI: One study reported similar accuracy. (Strength of Evidence: low)
  ○ PET versus CT: One study found ^11^C-choline PET more accurate than CT (95% vs. 40%). (Strength of Evidence: low)
  ○ MRI versus CT: One study reported that the proportion of decisions to perform resection or ablative therapies that were classified as correct were similar for MRI (90% and 90%, respectively) and CT (80% and 77%, respectively). (Strength of Evidence: low)

#### Clinical and Patient-Centered Outcomes

- US with contrast versus US without contrast plus CT: One cohort study found that contrast enhanced US identified more small (≤2 cm) HCC lesions than noncontrast US plus CT (36 vs. 31), and was associated with a higher complete necrosis rate following ablation (92% or 106/115 vs. 83% or 93/112 lesions, p=0.036), but was rated high risk of bias. Another study that appeared to be performed in the same series of patients found US with contrast prior to radiofrequency ablation associated with lower local tumor progression rate (7.2% vs. 18%, RR 0.40, 95% CI 0.16 to 0.87) and longer tumor-free survival (38 vs. 26 months), but was also rated high risk of bias. (Strength of Evidence: low)

#### Harms

- No evidence. (Strength of Evidence: insufficient)

### Detailed Synthesis

#### KQ3.a What is the comparative test performance of imaging techniques to predict HCC tumor stage?

##### Accuracy of Imaging for Staging

Seven studies evaluated accuracy of imaging techniques for staging using TNM criteria (six studies), BCLC criteria (one study), or UNOS criteria (one study) (Table 21).42,47,61,122,126,127,216 Six studies used an explanted liver reference standard and the other127 used an explanted liver or surgical resection reference standard. CT was evaluated in six studies, MRI in three studies, and PET in one study. For CT, the proportion correctly staged ranged from 28 to 58 percent, the proportion overstaged from 2 to 27 percent, and the proportion understaged from 25 to 52 percent.42,61,122,126,127,216 For MRI, the TNM, BCLC, and UNOS criteria were used in one study each, with estimates of the proportion correctly staged ranging from 40 to 75 percent, the proportion overstaged from 3.1 to 31 percent, and the proportion understaged from 19 to 31 percent.47,61,126 One study found 26 percent of patients correctly staged with FDG PET and 91 percent with ^11^C-choline PET.127

Table 21 Accuracy of imaging for staging of hepatocellular carcinoma

Author, Year | Diagnostic Test | Dates of Imaging | Reference Standard | Country | Sample Size | Patient Population | Staging System | Stage Analysis | Correctly Staged | Over-staged | Under-staged
Baccarini, 2006^122^ | CT | 1996–2005 | Explant | Italy | 50 | Liver transplant | TNM | 0, 1, 2, 3, 4a | 28% | 20% | 52%
Burrel, 2003^126^ | MRI | 2000–2001 | Explant | Spain | 50 | Liver transplant | BCLC | A, B, C | 59% | 10% | 31%
| CT | | | | | | | | 58% | 4% | 38%
Cheung, 2013^127^ | FDG PET | 2004–2010 | Explant or surgical resection | China | 43 | Liver transplant or surgical resection | TNM | 1, 2, 3 | 26% | NR | NR
| ^11^C-choline PET | | | | | | | | 91% | NR | NR
| Dual tracer PET | | | | | | | | 91% | NR | NR
| CT | | | | | | | | 42% | NR | NR
Freeman, 2006^61^ | MRI | 2003–2005 | Explant | United States | 285 | Liver transplant | TNM | 0, 1, 2, 3, 4a, 4b | 40% | 31% | 29%
| CT | | | | 357 | | | | 47% | 27% | 25%
| US | | | | 10 | | | | 30% | 30% | 40%
| Two or more imaging methods | | | | 117 | | | | 49% | 29% | 22%
Libbrecht, 2002^82^ | US, CT, or MRI | 2000–2001 | Explant | Belgium | 13 | Liver transplant | NR | NR | NR | NR | NR
Lu CH, 2010^179^ | CT | 2006–2008 | Explant | Taiwan | 57 | Liver transplant | NR | NR | NR | NR | NR
| MRI
Luca, 2010^42^ | CT | 2004–2006 | Explant | Italy | 57 | Liver transplant | TNM | 1, 2, 3 | 46% | 2% | 52%
Ronzoni, 2007^202^ | CT | 2003–2006 | Explant | Italy | 88 | Liver transplant | NR | NR | NR | NR | NR
Shah, 2006^102^ | US or CT | 1991–2004 | Explant | Canada | 118 | Liver transplant | TNM | NR | NR | NR | NR
Valls, 2004^208^ | CT | 1995–2002 | Explant | Spain | 85 | Liver transplant | NR | NR | NR | NR | NR
Zacherl, 2002^216^ | CT | 1998–2000 | Explant | Austria | 23 | Liver transplant | TNM | 1, 2, 3, 4 | 39% | NR | NR

BCLC = Barcelona Clinic Liver Cancer; NR = not reported; TNM = tumor nodule metastasis

Two studies that directly compared staging accuracy of imaging modalities found similar staging accuracy for MRI versus CT.61,126

##### PET for Detection of Metastatic Hepatocellular Carcinoma Disease

Using patients with metastatic HCC as the unit of analysis, sensitivity of FDG PET was 0.85 (95% CI 0.71 to 0.93, 6 studies) and specificity was 0.93 (95% CI 0.89 to 0.95, 5 studies), for a LR+ of 11 (95% CI 7.8 to 17) and LR− of 0.16 (95% CI 0.08 to 0.33) (Table 9; Figure 23).152,171,300,311,317,320 Estimates were similar when high risk of bias studies were excluded and when the analysis was restricted to studies that used a prospective design. All studies were conducted in Asia. One study that directly compared sensitivity of FDG PET to ^11^C-acetate PET reported comparable sensitivity (0.79 vs. 0.71), although sensitivity was higher when both tracers were used (0.98).300

Figure 23 Test performance of FDG PET for detection of patients with metastatic hepatocellular carcinoma

FDG = ^18^F-fluorodeoxyglucose; PET = positron emission tomography

This figure is a forest plot that displays the test performance of FDG PET for detection of patients with metastatic hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 6 studies, with a combined sensitivity of 0.85 (95% confidence interval: 0.71 to 0.93) and the tau-squared value is 0.72, p = 0.114. Specificity was reported or calculated for 5 studies, with a combined specificity of 0.93 (95% confidence interval: 0.89 to 0.95) and the tau-squared value is 0.00, p = 1.00.

Using metastatic HCC lesions as the unit of analysis, sensitivity of FDG PET was 0.82 (95% CI 0.72 to 0.90, 5 studies) (Figure 24).189,305,309,311,316 No study reported specificity. All studies except one were rated high risk of bias. In the one moderate risk of bias study, sensitivity was 0.86 (95% CI 0.70–0.95).309 All studies were conducted in Asia except for one small study (n=5) conducted in the United States.316 One study that directly compared sensitivity of FDG to ^11^C-acetate PET reported comparable sensitivity (0.86 vs. 0.77, respectively) (Table 16. PET direct comparisons). 309

Figure 24 Test performance of FDG PET for detection of metastatic hepatocellular carcinoma lesions

* Only sensitivity available

This figure is a forest plot that displays the test performance of FDG PET for detection of metastatic hepatocellular carcinoma lesions. The center of the graph corresponds to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. An overall mixed-effects model was based on 5 studies, with a value of 82 (95% confidence interval: 0.72 to 0.89) and the tau-squared value is 0.17, p = 0.213.

##### PET Versus Other Imaging Modalities

Three studies found no difference in sensitivity between PET/CT versus CT for metastatic HCC (0.82, 95% CI 0.61 to 0.93 vs. 0.85, 95% CI 0.66 to 0.95).152,171,189

One study found FDG PET associated with higher sensitivity than conventional imaging with CT, MRI, and chest x-ray for identifying HCC metastatic to lymph node (1.0 vs. 0.79) or bone (1.0 vs. 0.46), with no difference in specificity.320 Both imaging methods identified all 12 patients with lung metastases. However, one other study found FDG PET associated with lower sensitivity than imaging with chest x-ray and CT for identifying lung metastases (1.0 vs. 0.61).171

#### KQ3.a.i How is a particular technique’s test performance modified by use of various reference standards?

##### Accuracy of Imaging for Staging

Evidence was insufficient to determine effects of the use of different reference standards on accuracy of imaging techniques for staging. All studies used explanted livers as the reference standard except for one, which used explanted livers or surgical resection as the reference standard.42,47,61,122,126,127,216

##### PET for Detection of Metastatic Hepatocellular Carcinoma Disease

Evidence was too limited to determine effects of the use of different reference standards on accuracy of FDG PET for detection of metastatic HCC. Five of the six studies that used patients with metastatic HCC as the unit of analysis used mixed histological and imaging/clinical criteria as the reference standard.152,171,300,311,317,320 For studies that used metastatic HCC lesions as the reference standard, different reference standards (nonexplant histological reference standard, imaging and clinical criteria, or mixed) were each evaluated in only one or two studies. 189,305,309,311,316

#### KQ3.a.ii How is the comparative effectiveness modified by patient, tumor, technical, or other factors?

##### Accuracy of Imaging for Staging

No study evaluated effects of patient-level characteristics or other factors on accuracy of imaging techniques for staging.

##### PET for Detection of Metastatic Hepatocellular Disease

Estimates of sensitivity stratified by use of PET or PET/CT showed no clear differences, with overlapping confidence intervals (Table 9). In one study that directly compared sensitivity of PET versus PET/CT for identifying metastatic HCC lesions, there was no clear difference in sensitivity (0.90 vs. 0.98, respectively, difference of −0.09, 95% CI −0.17 to 0.0) (Table 16).189

One study found PET with FDG associated with higher sensitivity than ^11^C-acetate (0.79 vs. 0.64, for a difference of 0.15, 95% CI 0.03 to 0.28), but lower sensitivity than the combination of FDG and ^11^C-acetate (0.98, difference −0.19, 95% CI −0.28 to −0.11).

Four studies of FDG PET that stratified analyses by metastatic lesion size found higher sensitivity as lesion size increased, but the number of lesions <1 cm was small (total of 20), precluding strong conclusions (Table 17).171,305,309,311

Eight studies reported test performance of FDG PET stratified by location of metastasis (Table 22).152,171,189,305,309,311,317,320 In most studies, sensitivity was higher for lymph and bone metastasis than for lung metastasis, but samples were small, precluding strong conclusions.

Table 22 Test performance of ^18^F-fluorodeoxyglucose positron emission tomography for metastatic hepatocellular carcinoma, stratified by location of metastasis

Study, Year | Unit of Analysis | Sensitivity: Lung Metastasis | Sensitivity: Lymph Node Metastasis | Sensitivity: Bone Metastasis | Specificity: Lung Metastasis | Specificity: Lymph Node Metastasis | Specificity: Bone Metastasis
Kawaoka, 2009^a,152^ | Patient | 0.59 (10.7/18) | 0.67 (10.7/16) | 0.83 (10/12) | 0.92 (14.7/16) | 0.92 (16.7/18) | 0.86 (20.7/24)
Kim YK, 2010 (3)305 | Lesion | 0.60 (3/5) | 1.0 (3/3) | 1.0 (5/5) | Not reported | Not reported | Not reported
Lee JE, 2012^171^ | Patient | 0.61 (14/23) | 0.91 (20/22) | 1.0 (11/11) | 0.99^b^ | 0.96^b^ | 1.0^b^
Nagaoka, 2006^189^ | Lesion | 0.70 (7/10) | 0.95 (21/22) | 1.0 (16/16) | Not reported | Not reported | Not reported
Park JW, 2008^309^ | Lesion | 0.80 (16/20) | Not reported | 1.0 (6/6) | Not reported | Not reported | Not reported
Sugiyama, 2004^311^ | Lesion | 0.42 (5/12) | 1.0 (9/9) | 0.80 (8/10) | Not reported | Not reported | Not reported
Wu, 2011^317^ | Patient | 0.80 (8/10) | Not reported | 0.75 (3/4) | Not reported | Not reported | Not reported
Yoon, 2007^320^ | Patient | 1.0 (12/12) | 1.0 (19/19) | 1.0 (11/11) | 0.84 (63/75) | 0.94 (64/68) | 1.0 (76/76)

a Based on average from three readers

b Unable to determine number of true-negatives from information provided in study

#### KQ3.b What is the comparative test performance of imaging techniques on intermediate outcomes related to clinical decisionmaking?

Seven studies evaluated accuracy of imaging techniques for assessing transplant eligibility based on Milan criteria (Table 21).82,102,122,127,179,202,208 Two studies also evaluated University of California, San Francisco (UCSF) liver transplantation criteria.122,179 Six studies used explanted liver as the reference standard and the seventh127 used an explanted liver or surgical resection. Five studies evaluated CT, one study evaluated MRI, one study evaluated PET, and two studies evaluated use of more than one imaging modality (US or CT and US, CT, or MRI). For CT, the proportion correctly assessed for transplant eligibility ranged from 40 to 96 percent using Milan criteria;122,127,179,202,208 estimates from two studies that used UCSF criteria were similar to estimates based on Milan criteria. The proportion that met transplant criteria based on CT but exceeded criteria based on the reference standard was 3.5 to 7.8 percent in three studies179,202,208 and 26 percent in the fourth.122 In two studies, the proportion of patients who underwent transplantation based on CT but had no HCC lesion on examination of explanted livers was 2.3 percent and 16 percent.122,202 In two studies not restricted to a single imaging modality (e.g., CT or MRI, or CT, MRI, or US), the proportion correctly assessed were 38 percent and 57 percent.82,102

Two studies directly compared accuracy of two or more imaging modalities for assessing transplant eligibility. One study reported similar accuracy for CT and MRI.179 The other study found ^11^C-choline PET more accurate than CT (95% vs. 40%).127

One study reported that the proportion of decisions to perform resection or ablative therapies that were classified as correct were similar for MRI (90% and 90%, respectively) and CT (80% and 77%, respectively). 126

#### KQ3.c What is the comparative effectiveness of imaging techniques on clinical and patient-centered outcomes?

One high risk of bias cohort study (n=167) of patients with HCC who underwent radiofrequency ablation compared effects of preprocedure US with contrast versus US without contrast plus CT on clinical outcomes (Appendix I).46 US with contrast was performed within 10 minutes prior to the ablation procedure by two experienced radiologists using sulfur hexafluoride microbubble contrast; technical information for US without contrast was not reported. Contrast-enhanced CT with arterial and portal venous phase imaging was performed within one month prior to ablation, with followup one month after ablation. The study found that contrast enhanced US identified more small (≤2 cm) HCC lesions than US without contrast plus CT (36 vs. 31), and was associated with a higher complete necrosis rate following ablation (92% or 106/115 vs. 83% or 93/112 lesions, p=0.036). An important methodological shortcoming of this study was failure to adjust for potential confounders (Appendix C). Furthermore, additional lesions identified on US with contrast and cases classified as complete necrosis (treatment response) did not undergo histopathological or other confirmation prior to ablation. Another cohort study that appeared to be performed in the same patient population found US with contrast prior to radiofrequency ablation associated with a lower likelihood of local tumor progression (7.2% vs. 18.3%, RR 0.40, 95% CI 0.16 to 0.87), and longer progression-free (40 vs. 33 months, p=0.015) and tumor-free survival (38 vs. 26 months, p<0.001) than US without contrast, but also failed to adjust for confounders. 45

#### KQ3.d What are the adverse effects or harms associated with imaging-based staging strategies?

No study evaluated harms associated with use of imaging techniques for staging in patients diagnosed with HCC.