# References

1 Parkin DM. Global cancer statistics in the year 2000. Lancet Oncol. Sep. 2001;2(9):533-43. [pmid: 11905707].
2 National Cancer Institute. Liver Cancer. http://www.cancer.gov/cancertopics/types/liver. Accessed on September 21, 2011.
3 Howlader NNA, Neyman N, Altekruse SF, Kosary CL, Yu M, Ruhl J, Tatalovich Z, Cho H, Mariotto A, Lewis DR, Chen HS, Feuer EJ, Cronin KA. SEER Cancer Statistics Review, 1975–2010. Bethesda, MD. National Cancer Institute. 2013. http://seer.cancer.gov/csr/1975_2010/.
4 Kohler BA, Ward E, McCarthy BJ, et al. Annual report to the nation on the status of cancer, 1975–2007, featuring tumors of the brain and other nervous system. J Natl Cancer Inst. May. 4. 2011;103(9):714-36. [pmid: 21454908].
5 McGlynn KA, London WT. Epidemiology and natural history of hepatocellular carcinoma. Best Pract Res Clin Gastroenterol. Feb. 2005;19(1):3-23. [pmid: 15757802].
6 El-Serag HB. Epidemiology of hepatocellular carcinoma in USA. Hepatol Res. Sep. 2007;37(Suppl 2):S88-94. [pmid: 17877502].
7 El-Serag HB. Hepatocellular carcinoma: an epidemiologic view. J Clin Gastroenterol. Nov–Dec. 2002;35(5 Suppl 2):S72-8. [pmid: 12394209].
8 Zanetti AR, Van Damme P, Shouval D. The global impact of vaccination against hepatitis B: a historical overview. Vaccine. Nov. 18. 2008;26(49):6266-73. [pmid: 18848855].
9 Bruix J, Sherman M. Management of hepatocellular carcinoma: an update. Hepatology. Mar. 2011;53(3):1020-2. [pmid: 21374666].
10 Cabibbo G, Enea M, Attanasio M, et al. A meta-analysis of survival rates of untreated patients in randomized clinical trials of hepatocellular carcinoma. Hepatology. Apr. 2010;51(4):1274-83. [pmid: 20112254].
11 Pons F, Varela M, Llovet JM. Staging systems in hepatocellular carcinoma. HPB (Oxford). 2005;7(1):35-41. [pmid: 18333159].
12 Forner A, Reig ME, de Lope CR, et al. Current strategy for staging and treatment: the BCLC update and future prospects. Semin Liver Dis. Feb. 2010;30(1):61-74. [pmid: 20175034].
13 Mazzaferro V, Bhoori S, Sposito C, et al. Milan criteria in liver transplantation for hepatocellular carcinoma: An evidence-based analysis of 15 years of experience. Liver Transpl. 2011;17(S2):S44-S57. [pmid: 21695773].
14 Wilson SR, Greenbaum LD, Goldberg BB. Contrast-enhanced ultrasound: what is the evidence and what are the obstacles?. AJR Am J Roentgenol. Jul. 2009;193(1):55-60. [pmid: 19542395].
15 Wald C, Russo MW, Heimbach JK, et al. New OPTN/UNOS policy for liver transplant allocation: standardization of liver imaging, diagnosis, classification, and reporting of hepatocellular carcinoma. Radiology. Feb. 2013;266(2):376-82. [pmid: 23362092].
16 Seale MK, Catalano OA, Saini S, et al. Hepatobiliary-specific MR contrast agents: role in imaging the liver and biliary tree. Radiographics. Oct. 1. 2009;29(6):1725-48. [pmid: 19959518].
17 Frydrychowicz A, Lubner MG, Brown JJ, et al. Hepatobiliary MR imaging with gadolinium-based contrast agents. J Magn Reson Imaging. Mar. 2012;35(3):492-511. [pmid: 22334493].
18 Altenbernd J, Heusner TA, Ringelstein A, et al. Dual-energy-CT of hypervascular liver lesions in patients with HCC: investigation of image quality and sensitivity. Eur Radiol. Apr. 2011;21(4):738-43. [pmid: 20936520].
19 Silva AC, Morse BG, Hara AK, et al. Dual-Energy (Spectral) CT: applications in abdominal imaging. Radiographics 2011. July. 1. 2011;31(4):1031-46. [pmid: 21768237].
20 Lencioni R, Piscaglia F, Bolondi L. Contrast-enhanced ultrasound in the diagnosis of hepatocellular carcinoma. J Hepatol. May. 2008;48(5):848-57. [pmid: 18328590].
21 Treglia G, Giovannini E, Di Franco D, et al. The role of positron emission tomography using carbon-11 and fluorine-18 choline in tumors other than prostate cancer: a systematic review. Ann Nucl Med. Jul. 2012;26(6):451-61. [pmid: 22566040].
22 Li C, Zhang Z, Zhang P, et al. Diagnostic accuracy of des-gamma-carboxy prothrombin versus alpha-fetoprotein for hepatocellular carcinoma: A systematic review. Hepatol Res. 2013. Jul. 9. [Epub ahead of print]. [pmid: 23834468].
23 Di Tommaso L, Franchi G, Park YN, et al. Diagnostic value of HSP70, glypican 3, and glutamine synthetase in hepatocellular nodules in cirrhosis. Hepatology. Mar. 2007;45(3):725-34. [pmid: 17326147].
24 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
25 Chang SM, Matchar DB, editors. Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. Available at http://effectivehealthcare.ahrq.gov/ehc/products/246/558/Methods-Guide-for-Medical-Test-Reviews_Full-Guide_20120530.pdf.
26 Imaging Techniques for the Surveillance, Diagnosis, and Staging of Hepatocellular Carcinoma. Research Protocol. Rockville, MD. Agency for Healthcare Research and Quality. 2013. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=1600&pageaction=displayproduct. Accessed on November 11, 2013.
27 Imaging techniques for the surveillance, diagnosis, and staging of hepatocellular carcinoma. PROSPERO 2013: CRD42013005246. 2013. Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42013005246. Accessed on November 11, 2013.
28 Submit Scientific Information Packets. Lencioni R, Piscaglia F, Bolondi L. Contrast-enhanced ultrasound. http://effectivehealthcare.ahrq.gov/index.cfm/submit-scientific-information-packets/. Accessed on November 12, 2013.
29 Barr RG. Off-label use of ultrasound contrast agents for abdominal imaging in the United States. J Ultrasound Med. Jan. 2013;32(1):7-12. [pmid: 23269705].
30 Greenbaum L, Burns P, Copel J, et al. American Institute of Ultrasound in Medicine recommendations for contrast-enhanced liver ultrasound imaging clinical trials. J Ultrasound Med 2007. June. 1. 2007;26(6):705-16. [pmid: 17526602].
31 Nelson TR, Fowlkes JB. Contrast-enhanced ultrasound: an idea whose time has come. J Ultrasound Med 2007. June. 1. 2007;26(6):703-4. [pmid: 17526601].
32 Kansagara D, Papak J, Pasha A, et al. Screening for Hepatocellular Cancer in Chronic Liver Disease: A Systematic Review. Washington. Department of Veterans Affairs. January. 2014. www.ncbi.nlm.nih/gov/books/NBK222184.
33 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
34 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
35 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(13)-EHC063-EF. Agency for Healthcare Research and Quality. Rockville, MD. 2013;Chapter 9. Chapter available at http://www.effectivehealthcare.ahrq.gov/.
36 Takwoingi Y, Leeflang MM, Deeks JJ. Empirical evidence of the importance of comparative studies of diagnostic test accuracy. Ann Intern Med. Apr. 2. 2013;158(7):544-54. [pmid: 23546566].
37 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol. Dec. 2006;59(12):1331-2. author reply 2–3. [pmid: 17098577].
38 Zwinderman AH, Bossuyt PM. We should not pool diagnostic likelihood ratios in systematic reviews. Stat Med. Feb. 28. 2008;27(5):687-97. [pmid: 17611957].
39 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med. Jun. 2012;27(Suppl 1):S56-66. [pmid: 22648676].
40 Chappell FM, Raab GM, Wardlaw JM. When are summary ROC curves appropriate for diagnostic meta-analyses?. Stat Med. Sep. 20. 2009;28(21):2653-68. [pmid: 19591118].
41 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
42 Luca A, Caruso S, Milazzo M, et al. Multidetector-row computed tomography (MDCT) for the diagnosis of hepatocellular carcinoma in cirrhotic candidates for liver transplantation: prevalence of radiological vascular patterns and histological correlation with liver explants. [Erratum appears in Eur Radiol. 2011 Jul;21(7):1574 Note: Grutttadauria, Salvatore [corrected to Gruttadauria, Salvatore]]. Eur Radiol. Apr. 2010;20(4):898-907. [pmid: 19802612].
43 Sangiovanni A, Manini MA, Iavarone M, et al. The diagnostic and economic impact of contrast imaging techniques in the diagnosis of small hepatocellular carcinoma in cirrhosis. Gut. May. 2010;59(5):638-44. [pmid: 19951909].
44 Serste T, Barrau V, Ozenne V, et al. Accuracy and disagreement of computed tomography and magnetic resonance imaging for the diagnosis of small hepatocellular carcinoma and dysplastic nodules: role of biopsy. Hepatology. Mar. 2012;55(3):800-6. [pmid: 22006503].
45 Chen MH, Wu W, Yang W, et al. The use of contrast-enhanced ultrasonography in the selection of patients with hepatocellular carcinoma for radio frequency ablation therapy. J Ultrasound Med. 2007;26(8):1055-63. [pmid: 17646367].
46 Chen MH, Yang W, Yan K, et al. The role of contrast-enhanced ultrasound in planning treatment protocols for hepatocellular carcinoma before radiofrequency ablation. Clin Radiol. Aug. 2007;62(8):752-60. [pmid: 17604763].
47 Fowler KJ, Karimova EJ, Arauz AR, et al. Validation of organ procurement and transplant network (OPTN)/united network for organ sharing (UNOS) criteria for imaging diagnosis of hepatocellular carcinoma. Transplantation. 2013;95(12):1506-11. [pmid: 23778569].
48 Trinchet JC, Chaffaut C, Bourcier V, et al. Ultrasonographic surveillance of hepatocellular carcinoma in cirrhosis: a randomized trial comparing 3- and 6-month periodicities. Hepatology. Dec. 2011;54(6):1987-97. [pmid: 22144108].
49 Wang JH, Chang KC, Kee KM, et al. Hepatocellular carcinoma surveillance at 4- vs. 12-month intervals for patients with chronic viral hepatitis: a randomized study in community. Am J Gastroenterol. Mar. 2013;108(3):416-24. [pmid: 23318478].
50 Zhang BH, Yang BH, Tang ZY. Randomized controlled trial of screening for hepatocellular carcinoma. J Cancer Res Clin Oncol. Jul. 2004;130(7):417-22. [pmid: 15042359].
51 Alaboudy A, Inoue T, Hatanaka K, et al. Usefulness of combination of imaging modalities in the diagnosis of hepatocellular carcinoma using Sonazoid(R)-enhanced ultrasound, gadolinium diethylene-triamine-pentaacetic acid-enhanced magnetic resonance imaging, and contrast-enhanced computed tomography. Oncology. 2011;81(Suppl 1):66-72. [pmid: 22212939].
52 Bennett GL, Krinsky GA, Abitbol RJ, et al. Sonographic detection of hepatocellular carcinoma and dysplastic nodules in cirrhosis: correlation of pretransplantation sonography and liver explant pathology in 200 patients. AJR Am J Roentgenol. Jul. 2002;179(1):75-80. [pmid: 12076908].
53 Catala V, Nicolau C, Vilana R, et al. Characterization of focal liver lesions: comparative study of contrast-enhanced ultrasound versus spiral computed tomography. Eur Radiol. Apr. 2007;17(4):1066-73. [pmid: 17072617].
54 Chalasani N, Horlander JC Sr, Said A, et al. Screening for hepatocellular carcinoma in patients with advanced cirrhosis. Am J Gastroenterol. Oct. 1999;94(10):2988-93. [pmid: 10520857].
55 Dai Y, Chen MH, Fan ZH, et al. Diagnosis of small hepatic nodules detected by surveillance ultrasound in patients with cirrhosis: Comparison between contrast-enhanced ultrasound and contrast-enhanced helical computed tomography. Hepatol Res. Mar. 2008;38(3):281-90. [pmid: 17908168].
56 Di Martino M, Marin D, Guerrisi A, et al. Intraindividual comparison of gadoxetate disodium-enhanced MR imaging and 64-section multidetector CT in the Detection of hepatocellular carcinoma in patients with cirrhosis. Radiology. Sep. 2010;256(3):806-16. [pmid: 20720069].
57 D’Onofrio M, Rozzanigo U, Masinielli BM, et al. Hypoechoic focal liver lesions: characterization with contrast enhanced ultrasonography. J Clin Ultrasound. May. 2005;33(4):164-72. [pmid: 15856516].
58 Egger C, Goertz RS, Strobel D, et al. Dynamic contrast-enhanced ultrasound (DCE-US) for easy and rapid evaluation of hepatocellular carcinoma compared to dynamic contrast-enhanced computed tomography (DCE-CT)--a pilot study. Ultraschall Med. 2012;33(6):587-92. [pmid: 23154871].
59 Forner A, Vilana R, Ayuso C, et al. Diagnosis of hepatic nodules 20 mm or smaller in cirrhosis: Prospective validation of the noninvasive diagnostic criteria for hepatocellular carcinoma. [Erratum appears in Hepatology. 2008 Feb;47(2):769]. Hepatology. Jan. 2008;47(1):97-104. [pmid: 18069697].
60 Fracanzani AL, Burdick L, Borzio M, et al. Contrast-enhanced Doppler ultrasonography in the diagnosis of hepatocellular carcinoma and premalignant lesions in patients with cirrhosis. Hepatology. Dec. 2001;34(6):1109-12. [pmid: 11731999].
61 Freeman RB, Mithoefer A, Ruthazer R, et al. Optimizing staging for hepatocellular carcinoma before liver transplantation: A retrospective analysis of the UNOS/OPTN database. Liver Transpl. Oct. 2006;12(10):1504-11. [pmid: 16952174].
62 Furuse J, Maru Y, Yoshino M, et al. Assessment of arterial tumor vascularity in small hepatocellular carcinoma. Comparison between color doppler ultrasonography and radiographic imagings with contrast medium: dynamic CT, angiography, and CT hepatic arteriography. Eur J Radiol. Oct. 2000;36(1):20-7. [pmid: 10996754].
63 Gaiani S, Celli N, Piscaglia F, et al. Usefulness of contrast-enhanced perfusional sonography in the assessment of hepatocellular carcinoma hypervascular at spiral computed tomography. J Hepatol. Sep. 2004;41(3):421-6. [pmid: 15336445].
64 Gambarin-Gelwan M, Wolf DC, Shapiro R, et al. Sensitivity of commonly available screening tests in detecting hepatocellular carcinoma in cirrhotic patients undergoing liver transplantation. Am J Gastroenterol. Jun. 2000;95(6):1535-8. [pmid: 10894592].
65 Giorgio A, De Stefano G, Coppola C, et al. Contrast-enhanced sonography in the characterization of small hepatocellular carcinomas in cirrhotic patients: comparison with contrast-enhanced ultrafast magnetic resonance imaging. Anticancer Res. Nov–Dec. 2007;27(6C):4263-9. [pmid: 18214030].
66 Giorgio A, Ferraioli G, Tarantino L, et al. Contrast-enhanced sonographic appearance of hepatocellular carcinoma in patients with cirrhosis: Comparison with contrast-enhanced helical CT appearance. AJR Am J Roentgenol. 2004;183(5):1319-26. [pmid: 15505297].
67 Goto E, Masuzaki R, Tateishi R, et al. Value of post-vascular phase (Kupffer imaging) by contrast-enhanced ultrasonography using Sonazoid in the detection of hepatocellular carcinoma. J Gastroenterol. 2012;47(4):477-85. [pmid: 22200940].
68 Hatanaka K, Kudo M, Minami Y, et al. Differential diagnosis of hepatic tumors: value of contrast-enhanced harmonic sonography using the newly developed contrast agent, Sonazoid. Intervirology. 2008;51(Suppl 1):61-9. [pmid: 18544950].
69 Iavarone M, Sangiovanni A, Forzenigo LV, et al. Diagnosis of hepatocellular carcinoma in cirrhosis by dynamic contrast imaging: the importance of tumor cell differentiation. Hepatology. Nov. 2010;52(5):1723-30. [pmid: 20842697].
70 Imamura M, Shiratori Y, Shiina S, et al. Power Doppler sonography for hepatocellular carcinoma: factors affecting the power Doppler signals of the tumors. Liver. Dec. 1998;18(6):427-33. [pmid: 9869398].
71 Inoue T, Kudo M, Hatanaka K, et al. Imaging of hepatocellular carcinoma: Qualitative and quantitative analysis of postvascular phase contrast-enhanced ultrasonography with sonazoid. Oncology. 2008;75(SUPPL 1):48-54. [pmid: 19092272].
72 Inoue T, Kudo M, Maenishi O, et al. Value of liver parenchymal phase contrast-enhanced sonography to diagnose premalignant and borderline lesions and overt hepatocellular carcinoma. AJR Am J Roentgenol. Mar. 2009;192(3):698-705. [pmid: 19234266].
73 Jang HJ, Kim TK, Wilson SR. Small nodules (1–2 cm) in liver cirrhosis: characterization with contrast-enhanced ultrasound. Eur J Radiol. Dec. 2009;72(3):418-24. [pmid: 18834687].
74 Kawada N, Ohkawa K, Tanaka S, et al. Improved diagnosis of well-differentiated hepatocellular carcinoma with gadolinium ethoxybenzyl diethylene triamine pentaacetic acid-enhanced magnetic resonance imaging and Sonazoid contrast-enhanced ultrasonography. Hepatol Res. 2010;40(9):930-6. [pmid: 20887598].
75 Khalili K, Kim TK, Jang H-J, et al. Optimization of imaging diagnosis of 1–2 cm hepatocellular carcinoma: an analysis of diagnostic performance and resource utilization. J Hepatol. Apr. 2011;54(4):723-8. [pmid: 21156219].
76 Kim CK, Lim JH, Lee WJ. Detection of hepatocellular carcinomas and dysplastic nodules in cirrhotic liver: accuracy of ultrasonography in transplant patients. J Ultrasound Med. Feb. 2001;20(2):99-104. [pmid: 11211142].
77 Kim PN, Choi D, Rhim H, et al. Planning ultrasound for percutaneous radiofrequency ablation to treat small (≤ 3 cm) hepatocellular carcinomas detected on computed tomography or magnetic resonance imaging: a multicenter prospective study to assess factors affecting ultrasound visibility. J Vasc Interv Radiol. May. 2012;23(5):627-34. [pmid: 22387030].
78 Korenaga K, Korenaga M, Furukawa M, et al. Usefulness of Sonazoid contrast-enhanced ultrasonography for hepatocellular carcinoma: Comparison with pathological diagnosis and superparamagnetic iron oxide magnetic resonance images. J Gastroenterol. 2009;44(7):733-41. [pmid: 19387532].
79 Kunishi Y, Numata K, Morimoto M, et al. Efficacy of fusion imaging combining sonography and hepatobiliary phase MRI with Gd-EOB-DTPA to detect small hepatocellular carcinoma. AJR Am J Roentgenol. Jan. 2012;198(1):106-14. [pmid: 22194485].
80 Lee MW, Kim YJ, Park HS, et al. Targeted sonography for small hepatocellular carcinoma discovered by CT or MRI: factors affecting sonographic detection. AJR Am J Roentgenol. May. 2010;194(5):W396-400. [pmid: 20410384].
81 Li R, Guo Y, Hua X, et al. Characterization of focal liver lesions: comparison of pulse-inversion harmonic contrast-enhanced sonography with contrast-enhanced CT. J Clin Ultrasound. Mar–Apr. 2007;35(3):109-17. [pmid: 17295272].
82 Libbrecht L, Bielen D, Verslype C, et al. Focal lesions in cirrhotic explant livers: pathological evaluation and accuracy of pretransplantation imaging examinations. Liver Transpl. Sep. 2002;8(9):749-61. [pmid: 12200773].
83 Lim JH, Kim SH, Lee WJ, et al. Ultrasonographic detection of hepatocellular carcinoma: Correlation of preoperative ultrasonography and resected liver pathology. Clin Radiol. 2006;61(2):191-7. [pmid: 16439225].
84 Liu WC, Lim JH, Park CK, et al. Poor sensitivity of sonography in detection of hepatocellular carcinoma in advanced liver cirrhosis: accuracy of pretransplantation sonography in 118 patients. Eur Radiol. Jul. 2003;13(7):1693-8. [pmid: 12835987].
85 Luo BM, Wen YL, Yang HY, et al. Differentiation between malignant and benign nodules in the liver: use of contrast C3-MODE technology. World J Gastroenterol. Apr. 28. 2005;11(16):2402-7. [pmid: 15832408].
86 Luo W, Numata K, Kondo M, et al. Sonazoid-enhanced ultrasonography for evaluation of the enhancement patterns of focal liver tumors in the late phase by intermittent imaging with a high mechanical index. J Ultrasound Med. Apr. 2009;28(4):439-48. [pmid: 19321671].
87 Luo W, Numata K, Morimoto M, et al. Focal liver tumors: characterization with 3D perflubutane microbubble contrast agent-enhanced US versus 3D contrast-enhanced multidetector CT. Radiology. Apr. 2009;251(1):287-95. [pmid: 19221060].
88 Luo W, Numata K, Morimoto M, et al. Three-dimensional contrast-enhanced sonography of vascular patterns of focal liver tumors: pilot study of visualization methods. AJR Am J Roentgenol. Jan. 2009;192(1):165-73. [pmid: 19098197].
89 Mita K, Kim SR, Kudo M, et al. Diagnostic sensitivity of imaging modalities for hepatocellular carcinoma smaller than 2 cm. World J Gastroenterol. Sep. 7. 2010;16(33):4187-92. [pmid: 20806437].
90 Mok TSK, Yu SCH, Lee C, et al. False-negative rate of abdominal sonography for detecting hepatocellular carcinoma in patients with hepatitis B and elevated serum alpha-fetoprotein levels. AJR Am J Roentgenol. Aug. 2004;183(2):453-8. [pmid: 15269040].
91 Moriyasu F, Itoh K. Efficacy of perflubutane microbubble-enhanced ultrasound in the characterization and detection of focal liver lesions: phase 3 multicenter clinical trial. AJR Am J Roentgenol. Jul. 2009;193(1):86-95. [pmid: 19542399].
92 Numata K, Fukuda H, Miwa H, et al. Contrast-enhanced ultrasonography findings using a perflubutane-based contrast agent in patients with early hepatocellular carcinoma. Eur J Radiol. 2014. [pmid: 24176532].
93 Ooi C-C, Low S-C, Schneider-Kolsky M, et al. Diagnostic accuracy of contrast-enhanced ultrasound in differentiating benign and malignant focal liver lesions: a retrospective study. J Med Imaging Radiat Oncol. Oct. 2010;54(5):421-30. [pmid: 20958940].
94 Paul SB, Gulati MS, Sreenivas V, et al. Evaluating patients with cirrhosis for hepatocellular carcinoma: value of clinical symptomatology, imaging and alpha-fetoprotein. Oncology. 2007;72(Suppl 1):117-23. [pmid: 18087192].
95 Pei XQ, Liu LZ, Xiong YH, et al. Quantitative analysis of contrast-enhanced ultrasonography: Differentiating focal nodular hyperplasia from hepatocellular carcinoma. Br J Radiol. Mar. 2013;86(1023):20120536. Epub 2013 Feb 7. [pmid: 23392189].
96 Quaia E, Alaimo V, Baratella E, et al. The added diagnostic value of 64-row multidetector CT combined with contrast-enhanced US in the evaluation of hepatocellular nodule vascularity: implications in the diagnosis of malignancy in patients with liver cirrhosis. Eur Radiol. Mar. 2009;19(3):651-63. [pmid: 18815790].
97 Quaia E, Bertolotto M, Calderan L, et al. US characterization of focal hepatic lesions with intermittent high-acoustic-power mode and contrast material. Acad Radiol. Jul. 2003;10(7):739-50. [pmid: 12862283].
98 Rickes S, Schulze S, Neye H, et al. Improved diagnosing of small hepatocellular carcinomas by echo-enhanced power Doppler sonography in patients with cirrhosis. Eur J Gastroenterol Hepatol. Aug. 2003;15(8):893-900. [pmid: 12867800].
99 Rode A, Bancel B, Douek P, et al. Small nodule detection in cirrhotic livers: evaluation with US, spiral CT, and MRI and correlation with pathologic examination of explanted liver. J Comput Assist Tomogr. May–Jun. 2001;25(3):327-36. [pmid: 11351179].
100 Seitz K, Bernatik T, Strobel D, et al. Contrast-enhanced ultrasound (CEUS) for the characterization of focal liver lesions in clinical practice (DEGUM Multicenter Trial): CEUS vs. MRI--a prospective comparison in 269 patients. Ultraschall Med. Oct. 2010;31(5):492-9. [pmid: 20652854].
101 Seitz K, Strobel D, Bernatik T, et al. Contrast-Enhanced Ultrasound (CEUS) for the characterization of focal liver lesions - prospective comparison in clinical practice: CEUS vs. CT (DEGUM multicenter trial). Parts of this manuscript were presented at the Ultrasound Dreilandertreffen 2008, Davos. Ultraschall Med. Aug. 2009;30(4):383-9. [pmid: 19688670].
102 Shah SA, Tan JC, McGilvray ID, et al. Accuracy of staging as a predictor for recurrence after liver transplantation for hepatocellular carcinoma. Transplantation. Jun. 27. 2006;81(12):1633-9. [pmid: 16794527].
103 Singh P, Erickson RA, Mukhopadhyay P, et al. EUS for detection of the hepatocellular carcinoma: results of a prospective study. Gastrointest Endosc. Aug. 2007;66(2):265-73. [pmid: 17543307].
104 Strobel D, Raeker S, Martus P, et al. Phase inversion harmonic imaging versus contrast-enhanced power Doppler sonography for the characterization of focal liver lesions. Int J Colorectal Dis. Jan. 2003;18(1):63-72. [pmid: 12458384].
105 Sugimoto K, Moriyasu F, Saito K, et al. Comparison of Kupffer-phase Sonazoid-enhanced sonography and hepatobiliary-phase gadoxetic acid-enhanced magnetic resonance imaging of hepatocellular carcinoma and correlation with histologic grading. J Ultrasound Med. Apr. 2012;31(4):529-38. [pmid: 22441909].
106 Sugimoto K, Moriyasu F, Shiraishi J, et al. Assessment of arterial hypervascularity of hepatocellular carcinoma: comparison of contrast-enhanced US and gadoxetate disodium-enhanced MR imaging. Eur Radiol. Jun. 2012;22(6):1205-13. [pmid: 22270142].
107 Suzuki S, Iijima H, Moriyasu F, et al. Differential diagnosis of hepatic nodules using delayed parenchymal phase imaging of levovist contrast ultrasound: comparative study with SPIO-MRI. Hepatol Res. Jun. 2004;29(2):122-6. [pmid: 15163434].
108 Takahashi M, Maruyama H, Shimada T, et al. Characterization of hepatic lesions (≤ 30 mm) with liver-specific contrast agents: a comparison between ultrasound and magnetic resonance imaging. Eur J Radiol. 2013;82(1):75-84. [pmid: 23116806].
109 Tanaka S, Ioka T, Oshikawa O, et al. Dynamic sonography of hepatic tumors. AJR Am J Roentgenol. Oct. 2001;177(4):799-805. [pmid: 11566675].
110 Teefey SA, Hildeboldt CC, Dehdashti F, et al. Detection of primary hepatic malignancy in liver transplant candidates: prospective comparison of CT, MR imaging, US, and PET. Radiology. Feb. 2003;226(2):533-42. [pmid: 12563151].
111 Trojan J, Schroeder O, Raedle J, et al. Fluorine-18 FDG positron emission tomography for imaging of hepatocellular carcinoma. Am J Gastroenterol. Nov. 1999;94(11):3314-9. [pmid: 10566736].
112 Van Thiel DH, Yong S, Li SD, et al. The development of de novo hepatocellular carcinoma in patients on a liver transplant list: frequency, size, and assessment of current screening methods. Liver Transpl. May. 2004;10(5):631-7. [pmid: 15108254].
113 Wang J-H, Lu S-N, Hung C-H, et al. Small hepatic nodules (≤ 2 cm) in cirrhosis patients: characterization with contrast-enhanced ultrasonography. Liver Int. Oct. 2006;26(8):928-34. [pmid: 16953832].
114 Wang ZL, Tang J, Weskott HP, et al. Undetermined focal liver lesions on gray-scale ultrasound in patients with fatty liver: characterization with contrast-enhanced ultrasound. J Gastroenterol Hepatol. Oct. 2008;23(10):1511-9. [pmid: 18713302].
115 Xu HX, Lu MD, Liu LN, et al. Discrimination between neoplastic and non-neoplastic lesions in cirrhotic liver using contrast-enhanced ultrasound. Br J Radiol. Oct. 2012;85(1018):1376-84. [pmid: 22553290].
116 Xu H-X, Xie X-Y, Lu M-D, et al. Contrast-enhanced sonography in the diagnosis of small hepatocellular carcinoma ≤ 2 cm. J Clin Ultrasound. Jun. 2008;36(5):257-66. [pmid: 18088056].
117 Yamamoto K, Shiraki K, Deguchi M, et al. Diagnosis of hepatocellular carcinoma using digital subtraction imaging with the contrast agent, Levovist: comparison with helical CT, digital subtraction angiography, and US angiography. Oncol Rep. Jul–Aug. 2002;9(4):789-92. [pmid: 12066210].
118 Yu NC, Chaudhari V, Raman SS, et al. CT and MRI improve detection of hepatocellular carcinoma, compared with ultrasound alone, in patients with cirrhosis. Clin Gastroenterol Hepatol. Feb. 2011;9(2):161-7. [pmid: 20920597].
119 Zhou K-R, Yan F-H, Tu B-W. Arterial phase of biphase enhancement spiral CT in diagnosis of small hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. Feb. 2002;1(1):68-71. [pmid: 14607626].
120 Addley HC, Griffin N, Shaw AS, et al. Accuracy of hepatocellular carcinoma detection on multidetector CT in a transplant liver population with explant liver correlation. Clin Radiol. Apr. 2011;66(4):349-56. [pmid: 21295772].
121 Akai H, Kiryu S, Matsuda I, et al. Detection of hepatocellular carcinoma by Gd-EOB-DTPA-enhanced liver MRI: comparison with triple phase 64 detector row helical CT. Eur J Radiol. Nov. 2011;80(2):310-5. [pmid: 20732773].
122 Baccarani U, Adani GL, Avellini C, et al. Comparison of clinical and pathological staging and long-term results of liver transplantation for hepatocellular carcinoma in a single transplant center. Transplant Proc. May. 2006;38(4):1111-3. [pmid: 16757280].
123 Baek CK, Choi JY, Kim KA, et al. Hepatocellular carcinoma in patients with chronic liver disease: a comparison of gadoxetic acid-enhanced MRI and multiphasic MDCT. Clin Radiol. Feb. 2012;67(2):148-56. [pmid: 21920517].
124 Bartolozzi C, Donati F, Cioni D, et al. MnDPDP-enhanced MRI vs dual-phase spiral CT in the detection of hepatocellular carcinoma in cirrhosis. Eur Radiol. 2000;10(11):1697-702. [pmid: 11097390].
125 Bhattacharjya S, Bhattacharjya T, Quaglia A, et al. Liver transplantation in cirrhotic patients with small hepatocellular carcinoma: an analysis of pre-operative imaging, explant histology and prognostic histologic indicators. Dig Surg. 2004;21(2):152-9. discussion 9–60. [pmid: 15166485].
126 Burrel M, Llovet JM, Ayuso C, et al. MRI angiography is superior to helical CT for detection of HCC prior to liver transplantation: an explant correlation. Hepatology. Oct. 2003;38(4):1034-42. [pmid: 14512891].
127 Cheung TT, Ho CL, Lo CM, et al. 11C-acetate and 18F-FDG PET/CT for clinical staging and selection of patients with hepatocellular carcinoma for liver transplantation on the basis of milan criteria: Surgeon’s perspective. J Nucl Med. 2013;54(2):192-200. [pmid: 23321459].
128 Colagrande S, Fargnoli R, Dal Pozzo F, et al. Value of hepatic arterial phase CT versus lipiodol ultrafluid CT in the detection of hepatocellular carcinoma. J Comput Assist Tomogr. Nov–Dec. 2000;24(6):878-83. [pmid: 11105704].
129 de Ledinghen V, Laharie D, Lecesne R, et al. Detection of nodules in liver cirrhosis: spiral computed tomography or magnetic resonance imaging? A prospective study of 88 nodules in 34 patients. Eur J Gastroenterol Hepatol. Feb. 2002;14(2):159-65. [pmid: 11981340].
130 Denecke T, Grieser C, Froling V, et al. Multislice computed tomography using a triple-phase contrast protocol for preoperative assessment of hepatic tumor load in patients with hepatocellular carcinoma before liver transplantation. Transpl Int. Apr. 2009;22(4):395-402. [pmid: 19000231].
131 Di Martino M, De Filippis G, De Santis A, et al. Hepatocellular carcinoma in cirrhotic patients: prospective comparison of US, CT and MR imaging. Eur Radiol. 2013;23:887-96. [pmid: 23179521].
132 Doyle DJ, O’Malley ME, Jang H-J, et al. Value of the unenhanced phase for detection of hepatocellular carcinomas 3 cm or less when performing multiphase computed tomography in patients with cirrhosis. J Comput Assist Tomogr. Jan–Feb. 2007;31(1):86-92. [pmid: 17259838].
133 Freeny PC, Grossholz M, Kaakaji K, et al. Significance of hyperattenuating and contrast-enhancing hepatic nodules detected in the cirrhotic liver during arterial phase helical CT in pre-liver transplant patients: radiologic-histopathologic correlation of explanted livers. Abdom Imaging. May–Jun. 2003;28(3):333-46. [pmid: 12719903].
134 Golfieri R, Marini E, Bazzocchi A, et al. Small (≤ 3 cm) hepatocellular carcinoma in cirrhosis: the role of double contrast agents in MR imaging vs. multidetector-row CT. Radiol Med (Torino). Dec. 2009;114(8):1239-66. [pmid: 19697104].
135 Haradome H, Grazioli L, Tinti R, et al. Additional value of gadoxetic acid-DTPA-enhanced hepatobiliary phase MR imaging in the diagnosis of early-stage hepatocellular carcinoma: comparison with dynamic triple-phase multidetector CT imaging. J Magn Reson Imaging. Jul. 2011;34(1):69-78. [pmid: 21598343].
136 Hidaka M, Takatsuki M, Okudaira S, et al. The expression of transporter OATP2/OATP8 decreases in undetectable hepatocellular carcinoma by Gd-EOB-MRI in the explanted cirrhotic liver. Hepatology International. 2012:1-7.
137 Higashihara H, Osuga K, Onishi H, et al. Diagnostic accuracy of C-arm CT during selective transcatheter angiography for hepatocellular carcinoma: comparison with intravenous contrast-enhanced, biphasic, dynamic MDCT. Eur Radiol. Apr. 2012;22(4):872-9. [pmid: 22120061].
138 Hirakawa M, Yoshimitsu K, Irie H, et al. Performance of radiological methods in diagnosing hepatocellular carcinoma preoperatively in a recipient of living related liver transplantation: comparison with step section histopathology. Jpn J Radiol. Feb. 2011;29(2):129-37. [pmid: 21359938].
139 Hori M, Murakami T, Kim T, et al. Detection of hypervascular hepatocellular carcinoma: comparison of SPIO-enhanced MRI with dynamic helical CT. J Comput Assist Tomogr. Sep–Oct. 2002;26(5):701-10. [pmid: 12439302].
140 Hori M, Murakami T, Oi H, et al. Sensitivity in detection of hypervascular hepatocellular carcinoma by helical CT with intra-arterial injection of contrast medium, and by helical CT and MR imaging with intravenous injection of contrast medium. Acta Radiol. Mar. 1998;39(2):144-51. [pmid: 9529444].
141 Hwang J, Kim SH, Lee MW, et al. Small (≤ 2 cm) hepatocellular carcinoma in patients with chronic liver disease: comparison of gadoxetic acid-enhanced 3.0 T MRI and multiphasic 64-multirow detector CT. Br J Radiol. Jul. 2012;85(1015):e314-22. [pmid: 22167508].
142 Iannaccone R, Laghi A, Catalano C, et al. Hepatocellular carcinoma: role of unenhanced and delayed phase multi-detector row helical CT in patients with cirrhosis. Radiology. Feb. 2005;234(2):460-7. [pmid: 15671002].
143 Ichikawa T, Kitamura T, Nakajima H, et al. Hypervascular hepatocellular carcinoma: can double arterial phase imaging with multidetector CT improve tumor depiction in the cirrhotic liver?. AJR Am J Roentgenol. Sep. 2002;179(3):751-8. [pmid: 12185057].
144 Ichikawa T, Saito K, Yoshioka N, et al. Detection and characterization of focal liver lesions: a Japanese phase III, multicenter comparison between gadoxetic acid disodium-enhanced magnetic resonance imaging and contrast-enhanced computed tomography predominantly in patients with hepatocellular carcinoma and chronic liver disease. Invest Radiol. Mar. 2010;45(3):133-41. [pmid: 20098330].
145 Inoue T, Kudo M, Komuta M, et al. Assessment of Gd-EOB-DTPA-enhanced MRI for HCC and dysplastic nodules and comparison of detection sensitivity versus MDCT. J Gastroenterol. Sep. 2012;47(9):1036-47. [pmid: 22526270].
146 Iwazawa J, Ohue S, Hashimoto N, et al. Detection of hepatocellular carcinoma: comparison of angiographic C-arm CT and MDCT. AJR Am J Roentgenol. Oct. 2010;195(4):882-7. [pmid: 20858813].
147 Jang HJ, Kim TK, Khalili K, et al. Characterization of 1- to 2-cm liver nodules detected on hcc surveillance ultrasound according to the criteria of the american association for the study of liver disease: Is quadriphasic CT necessary?. AJR Am J Roentgenol. 2013;201(2):314-21. [pmid: 23883211].
148 Jang HJ, Lim JH, Lee SJ, et al. Hepatocellular carcinoma: are combined CT during arterial portography and CT hepatic arteriography in addition to triple-phase helical CT all necessary for preoperative evaluation?. Radiology. May. 2000;215(2):373-80. [pmid: 10796910].
149 Jeng C-M, Kung C-H, Wang Y-C, et al. Spiral biphasic contrast-enhanced computerized tomography in the diagnosis of hepatocellular carcinoma. J Formos Med Assoc. Aug. 2002;101(8):588-92. [pmid: 12440092].
150 Kakihara D, Nishie A, Harada N, et al. Performance of gadoxetic acid-enhanced MRI for detecting hepatocellular carcinoma in recipients of living-related-liver-transplantation: Comparison with dynamic multidetector row computed tomography and angiography-assisted computed tomography. J Magn Reson Imaging. 2013. Nov. [Epub ahead of print]. [pmid: 24259437].
151 Kang BK, Lim JH, Kim SH, et al. Preoperative depiction of hepatocellular carcinoma: ferumoxides-enhanced MR imaging versus triple-phase helical CT. Radiology. Jan. 2003;226(1):79-85. [pmid: 12511672].
152 Kawaoka T, Aikata H, Takaki S, et al. FDG positron emission tomography/computed tomography for the detection of extrahepatic metastases from hepatocellular carcinoma. Hepatol Res. 2009;39(2):134-42. [pmid: 19208034].
153 Kawata S, Murakami T, Kim T, et al. Multidetector CT: diagnostic impact of slice thickness on detection of hypervascular hepatocellular carcinoma. AJR Am J Roentgenol. Jul. 2002;179(1):61-6. [pmid: 12076906].
154 Khan MA, Combs CS, Brunt EM, et al. Positron emission tomography scanning in the evaluation of hepatocellular carcinoma. J Hepatol. May. 2000;32(5):792-7. [pmid: 10845666].
155 Kim KW, Lee JM, Klotz E, et al. Quantitative CT color mapping of the arterial enhancement fraction of the liver to detect hepatocellular carcinoma. Radiology. Feb. 2009;250(2):425-34. [pmid: 19188314].
156 Kim SE, Lee HC, Shim JH, et al. Noninvasive diagnostic criteria for hepatocellular carcinoma in hepatic masses >2 cm in a hepatitis B virus-endemic area. Liver Int. Nov. 2011;31(10):1468-76. [pmid: 21745284].
157 Kim SH, Choi D, Kim SH, et al. Ferucarbotran-enhanced MRI versus triple-phase MDCT for the preoperative detection of hepatocellular carcinoma. AJR Am J Roentgenol. Apr. 2005;184(4):1069-76. [pmid: 15788575].
158 Kim SH, Kim SH, Lee J, et al. Gadoxetic acid-enhanced MRI versus triple-phase MDCT for the preoperative detection of hepatocellular carcinoma. AJR Am J Roentgenol. Jun. 2009;192(6):1675-81. [pmid: 19457834].
159 Kim SJ, Kim SH, Lee J, et al. Ferucarbotran-enhanced 3.0-T magnetic resonance imaging using parallel imaging technique compared with triple-phase multidetector row computed tomography for the preoperative detection of hepatocellular carcinoma. [Erratum appears in J Comput Assist Tomogr. 2008 Jul–Aug;32(4):615]. J Comput Assist Tomogr. May–Jun. 2008;32(3):379-85. [pmid: 18520541].
160 Kim SK, Lim JH, Lee WJ, et al. Detection of hepatocellular carcinoma: comparison of dynamic three-phase computed tomography images and four-phase computed tomography images using multidetector row helical computed tomography. J Comput Assist Tomogr. Sep–Oct. 2002;26(5):691-8. [pmid: 12439300].
161 Kim T, Murakami T, Hori M, et al. Small hypervascular hepatocellular carcinoma revealed by double arterial phase CT performed with single breath-hold scanning and automatic bolus tracking. AJR Am J Roentgenol. Apr. 2002;178(4):899-904. [pmid: 11906869].
162 Kim YK, Kim CS, Chung GH, et al. Comparison of gadobenate dimeglumine-enhanced dynamic MRI and 16-MDCT for the detection of hepatocellular carcinoma. AJR Am J Roentgenol. Jan. 2006;186(1):149-57. [pmid: 16357395].
163 Kim YK, Kim CS, Han YM, et al. Detection of hepatocellular carcinoma: gadoxetic acid-enhanced 3-dimensional magnetic resonance imaging versus multi-detector row computed tomography. J Comput Assist Tomogr. Nov–Dec. 2009;33(6):844-50. [pmid: 19940648].
164 Kim YK, Kwak HS, Kim CS, et al. Hepatocellular carcinoma in patients with chronic liver disease: comparison of SPIO-enhanced MR imaging and 16-detector row CT. Radiology. Feb. 2006;238(2):531-41. [pmid: 16371577].
165 Kitamura T, Ichikawa T, Erturk SM, et al. Detection of hypervascular hepatocellular carcinoma with multidetector-row CT: single arterial-phase imaging with computer-assisted automatic bolus-tracking technique compared with double arterial-phase imaging. J Comput Assist Tomogr. Sep–Oct. 2008;32(5):724-9. [pmid: 18830101].
166 Kumano S, Uemura M, Haraikawa T, et al. Efficacy of double arterial phase dynamic magnetic resonance imaging with the sensitivity encoding technique versus dynamic multidetector-row helical computed tomography for detecting hypervascular hepatocellular carcinoma. Jpn J Radiol. Jul. 2009;27(6):229-36. [pmid: 19626408].
167 Laghi A, Iannaccone R, Rossi P, et al. Hepatocellular carcinoma: detection with triple-phase multi-detector row helical CT in patients with chronic hepatitis. Radiology. Feb. 2003;226(2):543-9. [pmid: 12563152].
168 Lee CH, Kim KA, Lee J, et al. Using low tube voltage (80kVp) quadruple phase liver CT for the detection of hepatocellular carcinoma: two-year experience and comparison with Gd-EOB-DTPA enhanced liver MRI. Eur J Radiol. Apr. 2012;81(4):e605-11. [pmid: 22297180].
169 Lee DH, Kim SH, Lee JM, et al. Diagnostic performance of multidetector row computed tomography, superparamagnetic iron oxide-enhanced magnetic resonance imaging, and dual-contrast magnetic resonance imaging in predicting the appropriateness of a transplant recipient based on milan criteria: correlation with histopathological findings. Invest Radiol. Jun. 2009;44(6):311-21. [pmid: 19462486].
170 Lee J, Won JL, Hyo KL, et al. Early hepatocellular carcinoma: Three-phase helical CT features of 16 patients. Korean J Radiol. 2008;9(4):325-32. [pmid: 18682670].
171 Lee JE, Jang JY, Jeong SW, et al. Diagnostic value for extrahepatic metastases of hepatocellular carcinoma in positron emission tomography/computed tomography scan. World J Gastroenterol. Jun. 21. 2012;18(23):2979-87. [pmid: 22736922].
172 Lee J-M, Kim I-H, Kwak H-S, et al. Detection of small hypervascular hepatocellular carcinomas in cirrhotic patients: comparison of superparamagnetic iron oxide-enhanced MR imaging with dual-phase spiral CT. Korean J Radiol. Jan–Mar. 2003;4(1):1-8. [pmid: 12679628].
173 Li CS, Chen RC, Tu HY, et al. Imaging well-differentiated hepatocellular carcinoma with dynamic triple-phase helical computed tomography. Br J Radiol. Aug. 2006;79(944):659-65. [pmid: 16641423].
174 Lim JH, Choi D, Kim SH, et al. Detection of hepatocellular carcinoma: value of adding delayed phase imaging to dual-phase helical CT. AJR Am J Roentgenol. Jul. 2002;179(1):67-73. [pmid: 12076907].
175 Lim JH, Kim CK, Lee WJ, et al. Detection of hepatocellular carcinomas and dysplastic nodules in cirrhotic livers: accuracy of helical CT in transplant patients. AJR Am J Roentgenol. Sep. 2000;175(3):693-8. [pmid: 10954452].
176 Lin M-T, Chen C-L, Wang C-C, et al. Diagnostic sensitivity of hepatocellular carcinoma imaging and its application to non-cirrhotic patients. J Gastroenterol Hepatol. Apr. 2011;26(4):745-50. [pmid: 21418303].
177 Liu YI, Kamaya A, Jeffrey RB, et al. Multidetector computed tomography triphasic evaluation of the liver before transplantation: importance of equilibrium phase washout and morphology for characterizing hypervascular lesions. J Comput Assist Tomogr. Mar–Apr. 2012;36(2):213-9. [pmid: 22446362].
178 Liu YI, Shin LK, Jeffrey RB, et al. Quantitatively defining washout in hepatocellular carcinoma. AJR Am J Roentgenol. Jan. 2013;200(1):84-9. [pmid: 23255745].
179 Lu CH, Chen CL, Cheng YF, et al. Correlation between imaging and pathologic findings in explanted livers of hepatocellular carcinoma cases. Transplant Proc. Apr. 2010;42(3):830-3. [pmid: 20430183].
180 Lv P, Lin XZ, Chen K, et al. Spectral CT in patients with small HCC: investigation of image quality and diagnostic accuracy. Eur Radiol. Oct. 2012;22(10):2117-24. [pmid: 22618521].
181 Lv P, Lin XZ, Li J, et al. Differentiation of small hepatic hemangioma from small hepatocellular carcinoma: recently introduced spectral CT method. Radiology. Jun. 2011;259(3):720-9. [pmid: 21357524].
182 Maetani YS, Ueda M, Haga H, et al. Hepatocellular carcinoma in patients undergoing living-donor liver transplantation. Accuracy of multidetector computed tomography by viewing images on digital monitors. Intervirology. 2008;51(Suppl 1):46-51. [pmid: 18544948].
183 Marin D, Catalano C, De Filippis G, et al. Detection of hepatocellular carcinoma in patients with cirrhosis: added value of coronal reformations from isotropic voxels with 64-MDCT. AJR Am J Roentgenol. Jan. 2009;192(1):180-7. [pmid: 19098199].
184 Marin D, Di Martino M, Guerrisi A, et al. Hepatocellular carcinoma in patients with cirrhosis: qualitative comparison of gadobenate dimeglumine-enhanced MR imaging and multiphasic 64-section CT. Radiology. Apr. 2009;251(1):85-95. [pmid: 19332848].
185 Monzawa S, Ichikawa T, Nakajima H, et al. Dynamic CT for detecting small hepatocellular carcinoma: usefulness of delayed phase imaging. AJR Am J Roentgenol. Jan. 2007;188(1):147-53. [pmid: 17179357].
186 Mortele KJ, De Keukeleire K, Praet M, et al. Malignant focal hepatic lesions complicating underlying liver disease: dual-phase contrast-enhanced spiral CT sensitivity and specificity in orthotopic liver transplant patients. Eur Radiol. 2001;11(9):1631-8. [pmid: 11511882].
187 Murakami T, Kim T, Kawata S, et al. Evaluation of optimal timing of arterial phase imaging for the detection of hypervascular hepatocellular carcinoma by using triple arterial phase imaging with multidetector-row helical computed tomography. Invest Radiol. Aug. 2003;38(8):497-503. [pmid: 12874516].
188 Murakami T, Kim T, Takamura M, et al. Hypervascular hepatocellular carcinoma: detection with double arterial phase multi-detector row helical CT. Radiology. Mar. 2001;218(3):763-7. [pmid: 11230652].
189 Nagaoka S, Itano S, Ishibashi M, et al. Value of fusing PET plus CT images in hepatocellular carcinoma and combined hepatocellular and cholangiocarcinoma patients with extrahepatic metastases: preliminary findings. Liver Int. Sep. 2006;26(7):781-8. [pmid: 16911459].
190 Nakamura H, Ito N, Kotake F, et al. Tumor-detecting capacity and clinical usefulness of SPIO-MRI in patients with hepatocellular carcinoma. J Gastroenterol. 2000;35(11):849-55. [pmid: 11085494].
191 Nakamura Y, Tashiro H, Nambu J, et al. Detectability of hepatocellular carcinoma by gadoxetate disodium-enhanced hepatic MRI: Tumor-by-tumor analysis in explant livers. J Magn Reson Imaging. 2013;37(3):684-91. [pmid: 23055436].
192 Nakayama A, Imamura H, Matsuyama Y, et al. Value of lipiodol computed tomography and digital subtraction angiography in the era of helical biphasic computed tomography as preoperative assessment of hepatocellular carcinoma. Ann Surg. Jul. 2001;234(1):56-62. [pmid: 11420483].
193 Noguchi Y, Murakami T, Kim T, et al. Detection of hepatocellular carcinoma: comparison of dynamic MR imaging with dynamic double arterial phase helical CT. AJR Am J Roentgenol. Feb. 2003;180(2):455-60. [pmid: 12540451].
194 Noguchi Y, Murakami T, Kim T, et al. Detection of hypervascular hepatocellular carcinoma by dynamic magnetic resonance imaging with double-echo chemical shift in-phase and opposed-phase gradient echo technique: comparison with dynamic helical computed tomography imaging with double arterial phase. J Comput Assist Tomogr. Nov–Dec. 2002;26(6):981-7. [pmid: 12488747].
195 Onishi H, Kim T, Imai Y, et al. Hypervascular hepatocellular carcinomas: detection with gadoxetate disodium-enhanced MR imaging and multiphasic multidetector CT. Eur Radiol. Apr. 2012;22(4):845-54. [pmid: 22057248].
196 Park JH, Kim SH, Park HS, et al. Added value of 80 kVp images to averaged 120 kVp images in the detection of hepatocellular carcinomas in liver transplantation candidates using dual-source dual-energy MDCT: results of JAFROC analysis. Eur J Radiol. Nov. 2011;80(2):e76-85. [pmid: 20875937].
197 Peterson MS, Baron RL, Marsh JW Jr, et al. Pretransplantation surveillance for possible hepatocellular carcinoma in patients with cirrhosis: epidemiology and CT-based tumor detection rate in 430 cases with surgical pathologic correlation. Radiology. Dec. 2000;217(3):743-9. [pmid: 11110938].
198 Pitton MB, Kloeckner R, Herber S, et al. MRI versus 64-row MDCT for diagnosis of hepatocellular carcinoma. World J Gastroenterol. Dec. 28. 2009;15(48):6044-51. [pmid: 20027676].
199 Pozzi Mucelli RM, Como G, Del Frate C, et al. Multidetector CT with double arterial phase and high-iodine-concentration contrast agent in the detection of hepatocellular carcinoma. Radiol Med (Torino). Mar. 2006;111(2):181-91. [pmid: 16671376].
200 Pugacheva O, Matsui O, Kozaka K, et al. Detection of small hypervascular hepatocellular carcinomas by EASL criteria: comparison with double-phase CT during hepatic arteriography. Eur J Radiol. Dec. 2011;80(3):e201-6. [pmid: 20855175].
201 Rizvi S, Camci C, Yong Y, et al. Is post-Lipiodol CT better than i.v. contrast CT scan for early detection of HCC? A single liver transplant center experience. Transplant Proc. Nov. 2006;38(9):2993-5. [pmid: 17112883].
202 Ronzoni A, Artioli D, Scardina R, et al. Role of MDCT in the diagnosis of hepatocellular carcinoma in patients with cirrhosis undergoing orthotopic liver transplantation. AJR Am J Roentgenol. Oct. 2007;189(4):792-8. [pmid: 17885047].
203 Sano K, Ichikawa T, Motosugi U, et al. Imaging study of early hepatocellular carcinoma: usefulness of gadoxetic acid-enhanced MR imaging. Radiology. Dec. 2011;261(3):834-44. [pmid: 21998047].
204 Schima W, Hammerstingl R, Catalano C, et al. Quadruple-phase MDCT of the liver in patients with suspected hepatocellular carcinoma: Effect of contrast material flow rate. AJR Am J Roentgenol. 2006;186(6):1571-9. [pmid: 16714645].
205 Sofue K, Tsurusaki M, Kawasaki R, et al. Evaluation of hypervascular hepatocellular carcinoma in cirrhotic liver: comparison of different concentrations of contrast material with multi-detector row helical CT--a prospective randomized study. Eur J Radiol. Dec. 2011;80(3):e237-42. [pmid: 21067880].
206 Sun HY, Lee JM, Shin CI, et al. Gadoxetic acid-enhanced magnetic resonance imaging for differentiating small hepatocellular carcinomas (≤ 2 cm in diameter) from arterial enhancing pseudolesions: special emphasis on hepatobiliary phase imaging. Invest Radiol. Feb. 2010;45(2):96-103. [pmid: 20057319].
207 Toyota N, Nakamura Y, Hieda M, et al. Diagnostic capability of gadoxetate disodium-enhanced liver MRI for diagnosis of hepatocellular carcinoma: Comparison with multi-detector CT. Hiroshima J Med Sci. 2013;62(3):55-61. [pmid: 24279123].
208 Valls C, Cos M, Figueras J, et al. Pretransplantation diagnosis and staging of hepatocellular carcinoma in patients with cirrhosis: value of dual-phase helical CT. AJR Am J Roentgenol. Apr. 2004;182(4):1011-7. [pmid: 15039179].
209 Wagnetz U, Atri M, Massey C, et al. Intraoperative ultrasound of the liver in primary and secondary hepatic malignancies: comparison with preoperative 1.5-T MRI and 64-MDCT. AJR Am J Roentgenol. Mar. 2011;196(3):562-8. [pmid: 21343497].
210 Xiao X-g, Han X, Shan W-d, et al. Multi-slice CT angiography by triple-phase enhancement in preoperative evaluation of hepatocellular carcinoma. Chin Med J (Engl). May. 20. 2005;118(10):844-9. [pmid: 15989766].
211 Yan FH, Shen JZ, Li RC, et al. Enhancement patterns of small hepatocellular carcinoma shown by dynamic MRI and CT. Hepatobiliary Pancreat Dis Int. Aug. 2002;1(3):420-4. [pmid: 14607719].
212 Yoo SH, Choi JY, Jang JW, et al. Gd-EOB-DTPA-enhanced MRI is better than MDCT in decision making of curative treatment for hepatocellular carcinoma. Ann Surg Oncol. 2013;20(9):2893-900. [pmid: 23649931].
213 Yu Y, He N, Sun K, et al. Differentiating hepatocellular carcinoma from angiomyolipoma of the liver with CT spectral imaging: A preliminary study. Clin Radiol. 2013;68(9):e491-e7. [pmid: 23702491].
214 Yu Y, Lin X, Chen K, et al. Hepatocellular carcinoma and focal nodular hyperplasia of the liver: differentiation with CT spectral imaging. Eur Radiol. Jun. 2013;23(6):1660-8. Epub 2013 Jan 10. [pmid: 23306709].
215 Yukisawa S, Okugawa H, Masuya Y, et al. Multidetector helical CT plus superparamagnetic iron oxide-enhanced MR imaging for focal hepatic lesions in cirrhotic liver: a comparison with multi-phase CT during hepatic arteriography. Eur J Radiol. Feb. 2007;61(2):279-89. [pmid: 17070663].
216 Zacherl J, Pokieser P, Wrba F, et al. Accuracy of multiphasic helical computed tomography and intraoperative sonography in patients undergoing orthotopic liver transplantation for hepatoma: what is the truth?. Ann Surg. Apr. 2002;235(4):528-32. [pmid: 11923609].
217 Zhao H, Yao JL, Han MJ, et al. Multiphase hepatic scans with multirow-detector helical CT in detection of hypervascular hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. May. 2004;3(2):204-8. [pmid: 15138110].
218 Zhao H, Yao J-L, Wang Y, et al. Detection of small hepatocellular carcinoma: comparison of dynamic enhancement magnetic resonance imaging and multiphase multirow-detector helical CT scanning. World J Gastroenterol. Feb. 28. 2007;13(8):1252-6. [pmid: 17451209].
219 Zhao H, Zhou K-R, Yan F-H. Role of multiphase scans by multirow-detector helical CT in detecting small hepatocellular carcinoma. World J Gastroenterol. Oct. 2003;9(10):2198-201. [pmid: 14562377].
220 Zheng X-H, Guan Y-S, Zhou X-P, et al. Detection of hypervascular hepatocellular carcinoma: Comparison of multi-detector CT with digital subtraction angiography and Lipiodol CT. World J Gastroenterol. Jan. 14. 2005;11(2):200-3. [pmid: 15633215].
221 Ahn SS, Kim M-J, Lim JS, et al. Added value of gadoxetic acid-enhanced hepatobiliary phase MR imaging in the diagnosis of hepatocellular carcinoma. Radiology. May. 2010;255(2):459-66. [pmid: 20413759].
222 An C, Park MS, Kim D, et al. Added value of subtraction imaging in detecting arterial enhancement in small (<3 cm) hepatic nodules on dynamic contrast-enhanced MRI in patients at high risk of hepatocellular carcinoma. Eur Radiol. 2013;23:924-30. [pmid: 23138382].
223 An C, Park M-S, Jeon H-M, et al. Prediction of the histopathological grade of hepatocellular carcinoma using qualitative diffusion-weighted, dynamic, and hepatobiliary phase MRI. Eur Radiol. Aug. 2012;22(8):1701-8. [pmid: 22434421].
224 Baird AJ, Amos GJ, Saad NF, et al. Retrospective audit to determine the diagnostic accuracy of Primovist-enhanced MRI in the detection of hepatocellular carcinoma in cirrhosis with explant histopathology correlation. J Med Imaging Radiat Oncol. 2013;57(3):314-20. [pmid: 23721140].
225 Cereser L, Furlan A, Bagatto D, et al. Comparison of portal venous and delayed phases of gadolinium-enhanced magnetic resonance imaging study of cirrhotic liver for the detection of contrast washout of hypervascular hepatocellular carcinoma. J Comput Assist Tomogr. 2010;34(5):706-11. [pmid: 20861773].
226 Choi D, Kim SH, Lim JH, et al. Detection of hepatocellular carcinoma: combined T2-weighted and dynamic gadolinium-enhanced MRI versus combined CT during arterial portography and CT hepatic arteriography. J Comput Assist Tomogr. Sep–Oct. 2001;25(5):777-85. [pmid: 11584240].
227 Choi SH, Lee JM, Yu NC, et al. Hepatocellular carcinoma in liver transplantation candidates: detection with gadobenate dimeglumine-enhanced MRI. AJR Am J Roentgenol. Aug. 2008;191(2):529-36. [pmid: 18647927].
228 Chou C-T, Chen R-C, Chen W-T, et al. Characterization of hyperintense nodules on T1-weighted liver magnetic resonance imaging: comparison of Ferucarbotran-enhanced MRI with accumulation-phase FS-T1WI and gadolinium-enhanced MRI. J Chin Med Assoc. Feb. 2011;74(2):62-8. [pmid: 21354082].
229 Chung J, Yu J-S, Kim DJ, et al. Hypervascular hepatocellular carcinoma in the cirrhotic liver: diffusion-weighted imaging versus superparamagnetic iron oxide-enhanced MRI. Magn Reson Imaging. Nov. 2011;29(9):1235-43. [pmid: 21907517].
230 Chung S-H, Kim M-J, Choi J-Y, et al. Comparison of two different injection rates of gadoxetic acid for arterial phase MRI of the liver. J Magn Reson Imaging. Feb. 2010;31(2):365-72. [pmid: 20099350].
231 Filippone A, Cianci R, Patriarca G, et al. The Value of Gadoxetic Acid-Enhanced Hepatospecific Phase MR Imaging for Characterization of Hepatocellular Nodules in the Cirrhotic Liver. European Journal of Clinical & Medical Oncology. 2010;2(4):1-8.
232 Gatto A, De Gaetano AM, Giuga M, et al. Differentiating hepatocellular carcinoma from dysplastic nodules at gadobenate dimeglumine-enhanced hepatobiliary-phase magnetic resonance imaging. Abdom Imaging. 2013;38(4):736-44. [pmid: 22986351].
233 Goshima S, Kanematsu M, Matsuo M, et al. Nodule-in-nodule appearance of hepatocellular carcinomas: comparison of gadolinium-enhanced and ferumoxides-enhanced magnetic resonance imaging. J Magn Reson Imaging. Aug. 2004;20(2):250-5. [pmid: 15269950].
234 Guo L, Liang C, Yu T, et al. 3 T MRI of hepatocellular carcinomas in patients with cirrhosis: does T2-weighted imaging provide added value?. Clin Radiol. Apr. 2012;67(4):319-28. [pmid: 22099524].
235 Hardie AD, Kizziah MK, Boulter DJ. Diagnostic accuracy of diffusion-weighted MRI for identifying hepatocellular carcinoma with liver explant correlation. J Med Imaging Radiat Oncol. Aug. 2011;55(4):362-7. [pmid: 21843170].
236 Hardie AD, Kizziah MK, Rissing MS. Can the patient with cirrhosis be imaged for hepatocellular carcinoma without gadolinium?: Comparison of combined T2-weighted, T2*-weighted, and diffusion-weighted MRI with gadolinium-enhanced MRI using liver explantation standard. J Comput Assist Tomogr. Nov–Dec. 2011;35(6):711-5. [pmid: 22082541].
237 Hardie AD, Nance JW, Boulter DJ, et al. Assessment of the diagnostic accuracy of T2*-weighted MR imaging for identifying hepatocellular carcinoma with liver explant correlation. Eur J Radiol. Dec. 2011;80(3):e249-52. [pmid: 21112710].
238 Hecht EM, Holland AE, Israel GM, et al. Hepatocellular carcinoma in the cirrhotic liver: gadolinium-enhanced 3D T1-weighted MR imaging as a stand-alone sequence for diagnosis. Radiology. May. 2006;239(2):438-47. [pmid: 16641353].
239 Ito K, Fujita T, Shimizu A, et al. Multiarterial phase dynamic MRI of small early enhancing hepatic lesions in cirrhosis or chronic hepatitis: Differentiating between hypervascular hepatocellular carcinomas and pseudolesions. AJR Am J Roentgenol. 2004;183(3):699-705. [pmid: 15333358].
240 Jeong MG, Yu JS, Kim KW, et al. Early homogeneously enhancing hemangioma versus hepatocellular carcinoma: differentiation using quantitative analysis of multiphasic dynamic magnetic resonance imaging. Yonsei Med J. Jun. 1999;40(3):248-55. [pmid: 10412337].
241 Jeong WK, Byun JH, Lee SS, et al. Gadobenate dimeglumine-enhanced liver MR imaging in cirrhotic patients: quantitative and qualitative comparison of 1-hour and 3-hour delayed images. J Magn Reson Imaging. Apr. 2011;33(4):889-97. [pmid: 21448954].
242 Jin Y, Nah S, Lee J, et al. Utility of Adding Primovist Magnetic Resonance Imaging to Analysis of Hepatocellular Carcinoma by Liver Dynamic Computed Tomography. Clin Gastroenterol Hepatol. 2013;11(2):187-92. [pmid: 23142203].
243 Kamura T, Kimura M, Sakai K, et al. Small hypervascular hepatocellular carcinoma versus hypervascular pseudolesions: Differential diagnosis on MRI. Abdom Imaging. 2002;27(3):315-24. [pmid: 12173363].
244 Kim AY, Kim YK, Lee MW, et al. Detection of hepatocellular carcinoma in gadoxetic acid-enhanced MRI and diffusion-weighted MRI with respect to the severity of liver cirrhosis. Acta Radiol. Oct. 1. 2012;53(8):830-8. [pmid: 22847903].
245 Kim DJ, Yu JS, Kim JH, et al. Small hypervascular hepatocellular carcinomas: value of diffusion-weighted imaging compared with “washout” appearance on dynamic MRI. Br J Radiol. Oct. 2012;85(1018):e879-86. [pmid: 22573299].
246 Kim M-J, Lee M, Choi J-Y, et al. Imaging features of small hepatocellular carcinomas with microvascular invasion on gadoxetic acid-enhanced MR imaging. Eur J Radiol. Oct. 2012;81(10):2507-12. [pmid: 22137613].
247 Kim TK, Lee KH, Jang H-J, et al. Analysis of gadobenate dimeglumine-enhanced MR findings for characterizing small (1–2-cm) hepatic nodules in patients at high risk for hepatocellular carcinoma. Radiology. Jun. 2011;259(3):730-8. [pmid: 21364083].
248 Kim YK, Kim CS, Han YM, et al. Detection of liver malignancy with gadoxetic acid-enhanced MRI: is addition of diffusion-weighted MRI beneficial?. [Erratum appears in Clin Radiol. 2011 Oct;66(10):1006]. Clin Radiol. Jun. 2011;66(6):489-96. [pmid: 21367403].
249 Kim YK, Kim CS, Han YM, et al. Detection of small hepatocellular carcinoma: can gadoxetic acid-enhanced magnetic resonance imaging replace combining gadopentetate dimeglumine-enhanced and superparamagnetic iron oxide-enhanced magnetic resonance imaging?. Invest Radiol. Nov. 2010;45(11):740-6. [pmid: 20644488].
250 Kim YK, Kim CS, Han YM, et al. Comparison of gadoxetic acid-enhanced MRI and superparamagnetic iron oxide-enhanced MRI for the detection of hepatocellular carcinoma. Clin Radiol. May. 2010;65(5):358-65. [pmid: 20380933].
251 Kim YK, Kim CS, Han YM, et al. Detection of small hepatocellular carcinoma: intraindividual comparison of gadoxetic acid-enhanced MRI at 3.0 and 1.5 T. [Erratum appears in Invest Radiol. 2011 Sep;46(9):600]. Invest Radiol. Jun. 2011;46(6):383-9. [pmid: 21467946].
252 Kim YK, Kim CS, Kwak HS, et al. Three-dimensional dynamic liver MR imaging using sensitivity encoding for detection of hepatocellular carcinomas: comparison with superparamagnetic iron oxide-enhanced mr imaging. J Magn Reson Imaging. Nov. 2004;20(5):826-37. [pmid: 15503325].
253 Kim YK, Kim CS, Lee YH, et al. Comparison of superparamagnetic iron oxide-enhanced and gadobenate dimeglumine-enhanced dynamic MRI for detection of small hepatocellular carcinomas. AJR Am J Roentgenol. May. 2004;182(5):1217-23. [pmid: 15100122].
254 Kim YK, Kwak HS, Han YM, et al. Usefulness of combining sequentially acquired gadobenate dimeglumine-enhanced magnetic resonance imaging and resovist-enhanced magnetic resonance imaging for the detection of hepatocellular carcinoma: comparison with computed tomography hepatic arteriography and computed tomography arterioportography using 16-slice multidetector computed tomography. J Comput Assist Tomogr. Sep–Oct. 2007;31(5):702-11. [pmid: 17895780].
255 Kim YK, Lee YH, Kim CS, et al. Added diagnostic value of T2-weighted MR imaging to gadolinium-enhanced three-dimensional dynamic MR imaging for the detection of small hepatocellular carcinomas. Eur J Radiol. Aug. 2008;67(2):304-10. [pmid: 17714904].
256 Kim YK, Lee YH, Kim CS, et al. Double-dose 1.0-M gadobutrol versus standard-dose 0.5-M gadopentetate dimeglumine in revealing small hypervascular hepatocellular carcinomas. Eur Radiol. Jan. 2008;18(1):70-7. [pmid: 17404740].
257 Kondo H, Kanematsu M, Itoh K, et al. Does T2-weighted MR imaging improve preoperative detection of malignant hepatic tumors? Observer performance study in 49 surgically proven cases. Magn Reson Imaging. Jan. 2005;23(1):89-95. [pmid: 15733793].
258 Koushima Y, Ebara M, Fukuda H, et al. Small hepatocellular carcinoma: assessment with T1-weighted spin-echo magnetic resonance imaging with and without fat suppression. Eur J Radiol. Jan. 2002;41(1):34-41. [pmid: 11750150].
259 Krinsky GA, Lee VS, Theise ND, et al. Transplantation for hepatocellular carcinoma and cirrhosis: Sensitivity of magnetic resonance imaging. Liver Transpl. 2002;8(12):1156-64. [pmid: 12474156].
260 Krinsky GA, Lee VS, Theise ND, et al. Hepatocellular carcinoma and dysplastic nodules in patients with cirrhosis: prospective diagnosis with MR imaging and explantation correlation. Radiology. May. 2001;219(2):445-54. [pmid: 11323471].
261 Kwak H-S, Lee J-M, Kim C-S. Preoperative detection of hepatocellular carcinoma: comparison of combined contrast-enhanced MR imaging and combined CT during arterial portography and CT hepatic arteriography. Eur Radiol. Mar. 2004;14(3):447-57. [pmid: 14531005].
262 Kwak H-S, Lee J-M, Kim Y-K, et al. Detection of hepatocellular carcinoma: comparison of ferumoxides-enhanced and gadolinium-enhanced dynamic three-dimensional volume interpolated breath-hold MR imaging. Eur Radiol. Jan. 2005;15(1):140-7. [pmid: 15449000].
263 Lauenstein TC, Salman K, Morreira R, et al. Gadolinium-enhanced MRI for tumor surveillance before liver transplantation: center-based experience. AJR Am J Roentgenol. Sep. 2007;189(3):663-70. [pmid: 17715115].
264 Lee JY, Kim SH, Jeon YH, et al. Ferucarbotran-enhanced magnetic resonance imaging versus gadoxetic acid-enhanced magnetic resonance imaging for the preoperative detection of hepatocellular carcinoma: initial experience. J Comput Assist Tomogr. Jan. 2010;34(1):127-34. [pmid: 20118735].
265 Lee MH, Kim SH, Park MJ, et al. Gadoxetic acid-enhanced hepatobiliary phase MRI and high-b-value diffusion-weighted imaging to distinguish well-differentiated hepatocellular carcinomas from benign nodules in patients with chronic liver disease. AJR Am J Roentgenol. Nov. 2011;197(5):W868-75. [pmid: 22021534].
266 Marrero JA, Hussain HK, Nghiem HV, et al. Improving the prediction of hepatocellular carcinoma in cirrhotic patients with an arterially-enhancing liver mass. Liver Transpl. Mar. 2005;11(3):281-9. [pmid: 15719410].
267 Matsuo M, Kanematsu M, Itoh K, et al. Detection of malignant hepatic tumors: comparison of gadolinium-and ferumoxide-enhanced MR imaging. AJR Am J Roentgenol. Sep. 2001;177(3):637-43. [pmid: 11517061].
268 Mori K, Yoshioka H, Takahashi N, et al. Triple arterial phase dynamic MRI with sensitivity encoding for hypervascular hepatocellular carcinoma: comparison of the diagnostic accuracy among the early, middle, late, and whole triple arterial phase imaging. AJR Am J Roentgenol. Jan. 2005;184(1):63-9. [pmid: 15615952].
269 Motosugi U, Ichikawa T, Sou H, et al. Distinguishing hypervascular pseudolesions of the liver from hypervascular hepatocellular carcinomas with gadoxetic acid-enhanced MR imaging. Radiology. Jul. 2010;256(1):151-8. [pmid: 20574092].
270 Ooka Y, Kanai F, Okabe S, et al. Gadoxetic acid-enhanced MRI compared with CT during angiography in the diagnosis of hepatocellular carcinoma. Magn Reson Imaging. 2013;31(5):748-54. Epub 2012 Dec 5. [pmid: 23218794].
271 Park G, Kim YK, Kim CS, et al. Diagnostic efficacy of gadoxetic acid-enhanced MRI in the detection of hepatocellular carcinomas: comparison with gadopentetate dimeglumine. Br J Radiol. Dec. 2010;83(996):1010-6. [pmid: 20682591].
272 Park MJ, Kim YK, Lee MH, et al. Validation of diagnostic criteria using gadoxetic acid-enhanced and diffusion-weighted MR imaging for small hepatocellular carcinoma (≤ 2.0 cm) in patients with hepatitis-induced liver cirrhosis. Acta Radiol. 2013;54(2):127-36. [pmid: 23148300].
273 Park M-S, Kim S, Patel J, et al. Hepatocellular carcinoma: detection with diffusion-weighted versus contrast-enhanced magnetic resonance imaging in pretransplant patients. Hepatology. Jul. 2012;56(1):140-8. [pmid: 22370974].
274 Park Y, Kim SH, Kim SH, et al. Gadoxetic acid (Gd-EOB-DTPA)-enhanced MRI versus gadobenate dimeglumine (Gd-BOPTA)-enhanced MRI for preoperatively detecting hepatocellular carcinoma: an initial experience. Korean J Radiol. Jul–Aug. 2010;11(4):433-40. [pmid: 20592927].
275 Pauleit D, Textor J, Bachmann R, et al. Hepatocellular carcinoma: detection with gadolinium- and ferumoxides-enhanced MR imaging of the liver. Radiology. Jan. 2002;222(1):73-80. [pmid: 11756708].
276 Petruzzi N, Mitchell D, Guglielmo F, et al. Hepatocellular carcinoma likelihood on MRI exams. Evaluation of a standardized categorization System. Acad Radiol. Jun. 2013;20(6):694-8. Epub 2013 Mar 28. [pmid: 23541479].
277 Piana G, Trinquart L, Meskine N, et al. New MR imaging criteria with a diffusion-weighted sequence for the diagnosis of hepatocellular carcinoma in chronic liver diseases. J Hepatol. Jul. 2011;55(1):126-32. [pmid: 21145857].
278 Rhee H, Kim MJ, Park MS, et al. Differentiation of early hepatocellular carcinoma from benign hepatocellular nodules on gadoxetic acid-enhanced MRI. Br J Radiol. Oct. 2012;85(1018):e837-44. [pmid: 22553295].
279 Rimola J, Forner A, Tremosini S, et al. Non-invasive diagnosis of hepatocellular carcinoma ≤ 2 cm in cirrhosis. Diagnostic accuracy assessing fat, capsule and signal intensity at dynamic MRI. J Hepatol. Jun. 2012;56(6):1317-23. [pmid: 22314420].
280 Secil M, Obuz F, Altay C, et al. The role of dynamic subtraction MRI in detection of hepatocellular carcinoma. Diagn Interv Radiol. Dec. 2008;14(4):200-4. [pmid: 19061165].
281 Simon G, Link TM, Wortler K, et al. Detection of hepatocellular carcinoma: comparison of Gd-DTPA- and ferumoxides-enhanced MR imaging. Eur Radiol. May. 2005;15(5):895-903. [pmid: 15800773].
282 Suh YJ, Kim M-J, Choi J-Y, et al. Differentiation of hepatic hyperintense lesions seen on gadoxetic acid-enhanced hepatobiliary phase MRI. AJR Am J Roentgenol. Jul. 2011;197(1):W44-52. [pmid: 21700994].
283 Tanaka O, Ito H, Yamada K, et al. Higher lesion conspicuity for SENSE dynamic MRI in detecting hypervascular hepatocellular carcinoma: analysis through the measurements of liver SNR and lesion-liver CNR comparison with conventional dynamic MRI. Eur Radiol. Dec. 2005;15(12):2427-34. [pmid: 16041592].
284 Tang Y, Yamashita Y, Arakawa A, et al. Detection of hepatocellular carcinoma arising in cirrhotic livers: comparison of gadolinium- and ferumoxides-enhanced MR imaging. AJR Am J Roentgenol. Jun. 1999;172(6):1547-54. [pmid: 10350287].
285 Tanimoto A, Yuasa Y, Jinzaki M, et al. Routine MR imaging protocol with breath-hold fast scans: diagnostic efficacy for focal liver lesions. Radiat Med. Jul–Aug. 2002;20(4):169-79. [pmid: 12296432].
286 Tsurusaki M, Semelka RC, Uotani K, et al. Prospective comparison of high- and low-spatial-resolution dynamic MR imaging with sensitivity encoding (SENSE) for hypervascular hepatocellular carcinoma. Eur Radiol. Oct. 2008;18(10):2206-12. [pmid: 18446347].
287 Vandecaveye V, De Keyzer F, Verslype C, et al. Diffusion-weighted MRI provides additional value to conventional dynamic contrast-enhanced MRI for detection of hepatocellular carcinoma. Eur Radiol. Oct. 2009;19(10):2456-66. [pmid: 19440718].
288 Xu P-J, Yan F-H, Wang J-H, et al. Added value of breathhold diffusion-weighted MRI in detection of small hepatocellular carcinoma lesions compared with dynamic contrast-enhanced MRI alone using receiver operating characteristic curve analysis. J Magn Reson Imaging. Feb. 2009;29(2):341-9. [pmid: 19161186].
289 Xu P-J, Yan F-H, Wang J-H, et al. Contribution of diffusion-weighted magnetic resonance imaging in the characterization of hepatocellular carcinomas and dysplastic nodules in cirrhotic liver. J Comput Assist Tomogr. Jul. 2010;34(4):506-12. [pmid: 20657216].
290 Yoshioka H, Takahashi N, Yamaguchi M, et al. Double arterial phase dynamic MRI with sensitivity encoding (SENSE) for hypervascular hepatocellular carcinomas. J Magn Reson Imaging. Sep. 2002;16(3):259-66. [pmid: 12205581].
291 Youk JH, Lee JM, Kim CS. MRI for detection of hepatocellular carcinoma: comparison of mangafodipir trisodium and gadopentetate dimeglumine contrast agents. AJR Am J Roentgenol. Oct. 2004;183(4):1049-54. [pmid: 15385303].
292 Yu JS, Chung JJ, Kim JH, et al. Small hypervascular hepatocellular carcinomas: value of “washout” on gadolinium-enhanced dynamic MR imaging compared to superparamagnetic iron oxide-enhanced imaging. Eur Radiol. Nov. 2009;19(11):2614-22. [pmid: 19513719].
293 Yu JS, Kim KW, Park MS, et al. Transient peritumoral enhancement during dynamic MRI of the liver: Cavernous hemangioma versus hepatocellular carcinoma. J Comput Assist Tomogr. May–Jun. 2002;26(3):411-7. [pmid: 12016371].
294 Yu JS, Lee JH, Chung JJ, et al. Small hypervascular hepatocellular carcinoma: limited value of portal and delayed phases on dynamic magnetic resonance imaging. Acta Radiol. Sep. 2008;49(7):735-43. [pmid: 18608015].
295 Yu MH, Kim JH, Yoon JH, et al. Role of C-arm CT for transcatheter arterial chemoembolization of hepatocellular carcinoma: Diagnostic performance and predictive value for therapeutic response compared with gadoxetic acid-enhanced MRI. AJR Am J Roentgenol. 2013;201(3):675-83. [pmid: 23971463].
296 Chen Y-K, Hsieh D-S, Liao C-S, et al. Utility of FDG-PET for investigating unexplained serum AFP elevation in patients with suspected hepatocellular carcinoma recurrence. Anticancer Res. Nov–Dec. 2005;25(6C):4719-25. [pmid: 16334166].
297 Cheung TT, Chan SC, Ho CL, et al. Can positron emission tomography with the dual tracers [11 C]acetate and [18 F]fludeoxyglucose predict microvascular invasion in hepatocellular carcinoma?. Liver Transpl. Oct. 2011;17(10):1218-25. [pmid: 21688383].
298 Delbeke D, Martin WH, Sandler MP, et al. Evaluation of benign vs malignant hepatic lesions with positron emission tomography. Arch Surg. May. 1998;133(5):510-5. discussion 5–6. [pmid: 9605913].
299 Eckel F, Herrmann K, Schmidt S, et al. Imaging of proliferation in hepatocellular carcinoma with the in vivo marker 18F-fluorothymidine. J Nucl Med. Sep. 2009;50(9):1441-7. [pmid: 19690030].
300 Ho C-L, Chen S, Yeung DWC, et al. Dual-tracer PET/CT imaging in evaluation of metastatic hepatocellular carcinoma. J Nucl Med. Jun. 2007;48(6):902-9. [pmid: 17504862].
301 Ho C-L, Yu SCH, Yeung DWC. 11C-acetate PET imaging in hepatocellular carcinoma and other liver masses. J Nucl Med. Feb. 2003;44(2):213-21. [pmid: 12571212].
302 Hwang KH, Choi D-J, Lee S-Y, et al. Evaluation of patients with hepatocellular carcinomas using [(11)C]acetate and [(18)F]FDG PET/CT: A preliminary study. Appl Radiat Isot. Jul–Aug. 2009;67(7–8):1195-8. [pmid: 19342249].
303 Ijichi H, Shirabe K, Taketomi A, et al. Clinical usefulness of 18F-fluorodeoxyglucose positron emission tomography/computed tomography for patients with primary liver cancer with special reference to rare histological types, hepatocellular carcinoma with sarcomatous change and combined hepatocellular and cholangiocarcinoma. Hepatol Res. 2013;43(5):481-7. [pmid: 23145869].
304 Jeng L-B, Changlai S-P, Shen Y-Y, et al. Limited value of 18F-2-deoxyglucose positron emission tomography to detect hepatocellular carcinoma in hepatitis B virus carriers. Hepatogastroenterology. Nov–Dec. 2003;50(54):2154-6. [pmid: 14696485].
305 Kim Y-K, Lee K-W, Cho SY, et al. Usefulness 18F-FDG positron emission tomography/computed tomography for detecting recurrence of hepatocellular carcinoma in posttransplant patients. Liver Transpl. Jun. 2010;16(6):767-72. [pmid: 20517911].
306 Li S, Beheshti M, Peck-Radosavljevic M, et al. Comparison of (11)C-acetate positron emission tomography and (67)Gallium citrate scintigraphy in patients with hepatocellular carcinoma. Liver Int. Oct. 2006;26(8):920-7. [pmid: 16953831].
307 Liangpunsakul S, Agarwal D, Horlander JC, et al. Positron emission tomography for detecting occult hepatocellular carcinoma in hepatitis C cirrhotics awaiting for liver transplantation. Transplant Proc. Dec. 2003;35(8):2995-7. [pmid: 14697959].
308 Lin W-Y, Tsai S-C, Hung G-U. Value of delayed 18F-FDG-PET imaging in the detection of hepatocellular carcinoma. Nucl Med Commun. Apr. 2005;26(4):315-21. [pmid: 15753790].
309 Park J-W, Kim JH, Kim SK, et al. A prospective evaluation of 18F-FDG and 11C-acetate PET/CT for detection of primary and metastatic hepatocellular carcinoma. J Nucl Med. Dec. 2008;49(12):1912-21. [pmid: 18997056].
310 Sørensen M, Frisch K, Bender D, et al. The potential use of 2-[ 18F]fluoro-2-deoxy-D-galactose as a PET/CT tracer for detection of hepatocellular carcinoma. Eur J Nucl Med Mol Imaging. 2011;38(9):1723-31. [pmid: 21553087].
311 Sugiyama M, Sakahara H, Torizuka T, et al. 18F-FDG PET in the detection of extrahepatic metastases from hepatocellular carcinoma. J Gastroenterol. 2004;39(10):961-8. [pmid: 15549449].
312 Sun L, Guan YS, Pan WM, et al. Metabolic restaging of hepatocellular carcinoma using whole-body F-FDG PET/CT. World J Hepatol. Oct. 31. 2009;1(1):90-7. [pmid: 21160970].
313 Talbot J, Fartoux L, Balogova S, et al. Detection of hepatocellular carcinoma with PET/CT: a prospective comparison of 18F-fluorocholine and 18F-FDG in patients with cirrhosis or chronic liver disease. J Nucl Med. Nov. 2010;51(11):1699-706. [pmid: 20956466].
314 Talbot J, Gutman F, Fartoux L, et al. PET/CT in patients with hepatocellular carcinoma using [(18)F]fluorocholine: preliminary comparison with [(18)F]FDG PET/CT. Eur J Nucl Med Mol Imaging. Nov. 2006;33(11):1285-9. [pmid: 16802155].
315 Verhoef C, Valkema R, de Man RA, et al. Fluorine-18 FDG imaging in hepatocellular carcinoma using positron coincidence detection and single photon emission computed tomography. Liver. Feb. 2002;22(1):51-6. [pmid: 11906619].
316 Wolfort RM, Papillion PW, Turnage RH, et al. Role of FDG-PET in the evaluation and staging of hepatocellular carcinoma with comparison of tumor size, AFP level, and histologic grade. Int Surg. Jan–Mar. 2010;95(1):67-75. [pmid: 20480845].
317 Wu H-b, Wang Q-s, Li B-y, et al. F-18 FDG in conjunction with 11C-choline PET/CT in the diagnosis of hepatocellular carcinoma. Clin Nucl Med. Dec. 2011;36(12):1092-7. [pmid: 22064078].
318 Wudel LJ Jr, Delbeke D, Morris D, et al. The role of [18F]fluorodeoxyglucose positron emission tomography imaging in the evaluation of hepatocellular carcinoma. Am Surg. Feb. 2003;69(2):117-24. discussion 24–6. [pmid: 12641351].
319 Yamamoto Y, Nishiyama Y, Kameyama R, et al. Detection of hepatocellular carcinoma using 11C-choline PET: Comparison with 18F-FDG PET. J Nucl Med. Aug. 2008;49(8):1245-8. [pmid: 18632827].
320 Yoon KT, Kim JK, Kim DY, et al. Role of 18F-fluorodeoxyglucose positron emission tomography in detecting extrahepatic metastasis in pretreatment staging of hepatocellular carcinoma. Oncology. 2007;72(Suppl 1):104-10. [pmid: 18087190].
321 Yoo HJ, Lee JM, Lee JY, et al. Additional value of SPIO-enhanced MR imaging for the noninvasive imaging diagnosis of hepatocellular carcinoma in cirrhotic liver. Invest Radiol. Dec. 2009;44(12):800-7. [pmid: 19838119].
322 Pocha C, Dieperink E, McMaken KA, et al. Surveillance for hepatocellular cancer with ultrasonography vs. computed tomography - A randomised study. Aliment Pharmacol Ther. 2013;38(3):303-12. [pmid: 23750991].
323 Chen JG, Parkin DM, Chen QG, et al. Screening for liver cancer: results of a randomised controlled trial in Qidong, China. J Med Screen. 2003;10(4):204-9. [pmid: 14738659].
324 Naaktgeboren CA, de Groot JA, van Smeden M, et al. Evaluating diagnostic accuracy in the face of multiple reference standards. Ann Intern Med. Aug. 6. 2013;159(3):195-202. [pmid: 23922065].
325 Hunt CH, Hartman RP, Hesley GK. Frequency and severity of adverse effects of iodinated and gadolinium contrast materials: retrospective review of 456,930 doses. AJR Am J Roentgenol. Oct. 2009;193(4):1124-7. [pmid: 19770337].
326 Nelson KL, Gifford LM, Lauber-Huber C, et al. Clinical safety of gadopentetate dimeglumine. Radiology. Aug. 1995;196(2):439-43. [pmid: 7617858].
327 Niendorf HP, Haustein J, Cornelius I, et al. Safety of gadolinium-DTPA: extended clinical experience. Magn Reson Med. Dec. 1991;22(2):222-8. discussion 9–32. [pmid: 1812350].
328 Katayama H, Yamaguchi K, Kozuka T, et al. Adverse reactions to ionic and nonionic contrast media. A report from the Japanese Committee on the Safety of Contrast Media. Radiology. Jun. 1990;175(3):621-8. [pmid: 2343107].
329 Micro-bubble Contrast Agents (marketed as Definity (Perflutren Lipid Microsphere) Injectable Suspension and Optison (Perflutren Protein-Type A Microspheres for Injection). Silver Spring, MD. U.S. Food and Drug Administration. 2008. http://www.fda.gov/safety/medwatch/safetyinformation/safetyalertsforhumanmedicalproducts/ucm092270.htm. Accessed on November 12, 2013.
330 Piscaglia F, Bolondi L. The safety of Sonovue in abdominal applications: retrospective analysis of 23188 investigations. Ultrasound Med Biol. Sep. 2006;32(9):1369-75. [pmid: 16965977].
331 Herzog CA. Incidence of adverse events associated with use of perflutren contrast agents for echocardiography. JAMA. May. 7. 2008;299(17):2023-5. [pmid: 18460662].
332 Patient Safety: Radiation Dose in X-Ray and CT Exams. Oak Brook, IL. Radiological Society of North America. 2013. http://www.radiologyinfo.org/en/safety/index.cfm?pg=sfty_xray. Accessed on November 13, 2013.
333 Colli A, Fraquelli M, Casazza G, et al. Accuracy of ultrasonography, spiral CT, magnetic resonance, and alpha-fetoprotein in diagnosing hepatocellular carcinoma: a systematic review. Am J Gastroenterol. Mar. 2006;101(3):513-23. [pmid: 16542288].
334 Westwood M, Joore M, Grutters J, et al. Contrast-enhanced ultrasound using SonoVue(R) (sulphur hexafluoride microbubbles) compared with contrast-enhanced computed tomography and contrast-enhanced magnetic resonance imaging for the characterisation of focal liver lesions and detection of liver metastases: a systematic review and cost-effectiveness analysis. Health Technol Assess. Apr. 2013;17(16):1-243. [pmid: 23611316].
335 Guang Y, Xie L, Ding H, et al. Diagnosis value of focal liver lesions with SonoVue-enhanced ultrasound compared with contrast-enhanced computed tomography and contrast-enhanced MRI: a meta-analysis. J Cancer Res Clin Oncol. Nov. 2011;137(11):1595-605. [pmid: 21850382].
336 Xie L, Guang Y, Ding H, et al. Diagnostic value of contrast-enhanced ultrasound, computed tomography and magnetic resonance imaging for focal liver lesions: a meta-analysis. Ultrasound Med Biol. Jun. 2011;37(6):854-61. [pmid: 21531500].
337 Chen L, Zhang L, Bao J, et al. Comparison of MRI with liver-specific contrast agents and multidetector row CT for the detection of hepatocellular carcinoma: a meta-analysis of 15 direct comparative studies. Gut. Oct. 2013;62(10):1520-1. [pmid: 23929696].
338 Lin C-Y, Chen J-H, Liang J-A, et al. 18F-FDG PET or PET/CT for detecting extrahepatic metastases or recurrent hepatocellular carcinoma: a systematic review and meta-analysis. Eur J Radiol. Sep. 2012;81(9):2417-22. [pmid: 21899970].
339 Aghoram R, Cai P, Dickinson JA. Alpha-foetoprotein and/or liver ultrasonography for screening of hepatocellular carcinoma in patients with chronic hepatitis B. Cochrane Database Syst Rev. 2012;9. [pmid: 22972059].
340 Lachs MS, Nachamkin I, Edelstein PH, et al. Spectrum bias in the evaluation of diagnostic tests: lessons from the rapid dipstick test for urinary tract infection. Ann Intern Med. Jul. 15. 1992;117(2):135-40. [pmid: 1605428].
341 Morana G, Salviato E, Guarise A. Contrast agents for hepatic MRI. Cancer Imaging. 2007;7(Spec No A):S24-7. [pmid: 17921081].
342 Lijmer JG, Bossuyt PM, Heisterkamp SH. Exploring sources of heterogeneity in systematic reviews of diagnostic tests. Stat Med. Jun. 15. 2002;21(11):1525-37. [pmid: 12111918].
343 Gatsonis C, Paliwal P. Meta-analysis of diagnostic and screening test accuracy evaluations: methodologic primer. AJR Am J Roentgenol. Aug. 2006;187(2):271-81. [pmid: 16861527].
344 Macaskill P, Gatsonis C, Deeks J, et al. Chapter 10 Analysing and Presenting Results. Deeks JJ, Bossuyt PM, Gatsonis C, editors. Cochrane Handbook for Systematic Reviews of Diagnostic Test Accuracy. Version 1.0 ed. Oxford. The Cochrane Collaboration. 2010. Available from: http://srdta.cochrane.org/.
345 Deeks JJ, Macaskill P, Irwig L. The performance of tests of publication bias and other sample size effects in systematic reviews of diagnostic test accuracy was assessed. J Clin Epidemiol. Sep. 2005;58(9):882-93. [pmid: 16085191].
346 Song F, Khan KS, Dinnes J, et al. Asymmetric funnel plots and publication bias in meta-analyses of diagnostic accuracy. Int J Epidemiol. Feb. 2002;31(1):88-95. [pmid: 11914301].
347 Liver Imaging Reporting and Data System version 2013.1. American College of Radiology. http://www.acr.org/Quality-Safety/Resources/LIRADS/. Accessed on April 2014.