# Methods

The methods for this systematic review follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program methods guides.24,25

## Topic Refinement and Review Protocol

This topic was selected for review based on a nomination from the Tufts Evidence-Based Practice Center (EPC) topic identification project, which included a set of draft proposed Key Questions. The Key Questions and scope were further developed with input from a Technical Expert Panel (TEP). The TEP provided high-level content and methodological guidance to the review process through involvement of clinicians and researchers with expertise in the diagnosis and management of liver diseases and cancers, radiologists, hepatologists, clinical outcomes researchers, and patient and payer representatives. TEP members disclosed all financial and other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the panel members had no conflicts of interest that precluded participation.

The protocol for this comparative effectiveness review (CER) was posted on the Agency for Healthcare Research and Quality (AHRQ) Web site on July 25, 2013.^26^ The protocol was also registered in the PROSPERO international database of prospectively registered systematic reviews.27

## Searching for the Evidence

For the primary literature, we searched Ovid MEDLINE^®^, Scopus, Evidence-Based Medicine Reviews (Ovid), the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and the Health Technology Assessment Database from 1998 to December 2013 (see Table 4 for search strategy). We searched for unpublished studies in clinical trial registries (ClinicalTrials.gov, Current Controlled Trials, ClinicalStudyResults.org, and the World Health Organization International Clinical Trials Registry Platform), regulatory documents (U.S. Food and Drug Administration Medical Devices Registration and Listing), and individual product Web sites. Scientific information packets (SIPs) were solicited via a notice published in the Federal Register that invited interested parties to submit relevant published and unpublished studies using the publicly accessible AHRQ Effective Health Care online SIP portal.28 One SIP response was received, but it yielded no additional relevant studies. We also hand-searched the reference lists of relevant studies and previous systematic reviews for additional studies.

Table 4 Search strategy—Ovid MEDLINE^®^ (1998–2013)

1. Carcinoma, Hepatocellular/; 2. Liver Neoplasms/; 3. (“hepatocellular cancer” or “hepatocellular carcinoma” or “HCC”).ti,ab.; 4. Diagnostic Imaging/; 5. Ultrasonography/; 6. Magnetic Resonance Imaging/; 7. exp Tomography, Emission-Computed/ or exp Positron-Emission Tomography/ or exp Tomography, Spiral Computed/; 8. (“CT” or “dynamic multidetector computed tomography” or “MDCT” or “spiral CT” or “dual source CT” or “contrast CT” or “MRI” or “FDG-PET”).ti,ab.; 9. or/1–3; 10. or/4–8; 11. 9 and 10; 12. “Sensitivity and Specificity”/; 13. “Predictive Value of Tests”/; 14. ROC Curve/; 15. “Reproducibility of Results”/; 16. (sensitiv$ or “predictive value” or accurac$).ti,ab.; 17. or/12–16; 18. 11 and 17; 19. limit 18 to yr=“1998 – 2013”

### Populations and Conditions of Interest

The populations and conditions of interest for each key question are described in Table 5.

Table 5 Inclusion and exclusion criteria by Key Question

| Inclusion Criteria | Exclusion Criteria
All Key Questions
Interventions | - Ultrasound (with or without contrast); - Contrast-enhanced spiral CT (including nonmultidetector or multidetector CT, and CT using dual energy and spectral methods); - Contrast-enhanced MRI using a 1.5 or 3.0 T scanner; - Diffusion-weighted MRI; - PET or PET/CT (including use of ^18^F-fluorodeoxyglucose, ^18^F-fluorothymidine, ^11^C-acetate, and ^11^C-choline tracers) | - Outdated imaging techniques (e.g., conventional, nonspiral/nonmultidetector CT, MRI using a ≤1.0 T scanner); - CT and MRI without contrast, with the exception of studies of diffusion-weighted MRI without contrast; - CT arterial portography and CT hepatic arteriography; - C-arm CT; - Intraoperative ultrasound; - MRI with ferucarbotran, ferumoxides, or mangafodipir contrast
Comparisons | For studies of diagnostic accuracy (comparative test performance):; - Reference standard comparators: Histopathology (based on explanted liver specimens or biopsy), clinical followup, and imaging followup; - Imaging comparators: Alternative imaging tests or strategies.; For studies of comparative effectiveness:; - No imaging or an alternative imaging strategy | Does not meet inclusion criteria
Timing | No restrictions | None
Setting | All care settings (e.g., primary and secondary care) | None
Study Designs | - Controlled randomized and nonrandomized trials; - Cohort studies on effects of imaging on diagnostic thinking or clinical decisionmaking; - Studies of diagnostic accuracy | - Studies of diagnostic accuracy that did not report the reference standard used, or in which the reference standard included the results of the test being investigated; - Case reports, case series, letters to the editor, and nonsystematic reviews; - Studies published prior to 1998 or in which imaging was performed prior to 1995, unless technical details were reported and studies met minimum technical criteria as described in the Interventions section above
Key Questions 1 and 2
Populations | Key Question 1; - Patients at high risk for HCC undergoing surveillance, including: Asian male HBV carriers over age 40, Asian female HBV carriers over age 50, HBV carriers with a family history of HCC, African/North American black HBV carriers, all individuals with cirrhosis (including alcoholic cirrhosis), HBV or HCV carriers with cirrhosis, and patients with stage 4 primary biliary cirrhosis; - Other high-risk patients undergoing surveillance as defined by the primary studies; - Patients enrolled in studies designed to determine detection rates of imaging for HCC, including patients who underwent liver transplantation or surgery for HCC or other reasons.; Key Question 2; - Patients in whom a suspicious lesion(s) for HCC has been detected by surveillance or by other means, including patients who underwent liver transplantation for HCC or other reasons; - Patients enrolled in studies designed to distinguish HCC from another type of liver lesion (benign or malignant). | - Patients with cholangiocarcinoma, unless they comprised <10% of the study population; - Patients with nonprimary (metastatic) lesions to the liver; - Patients undergoing imaging to evaluate response to ablative or other treatments; - Children.
Outcomes | - Diagnostic outcomes: test performance, types of HCC lesions detected; - Intermediate outcomes: effects on diagnostic thinking, effects on clinical decisionmaking.; - Clinical and patient-centered outcomes: overall mortality or survival, recurrence of HCC, including rates of seeding by fine-needle aspiration; quality of life as measured with scales such as the Short-Form Health Survey or EuroQol 5D; and psychosocial effects of diagnostic testing on patients, patients’ caregivers, and other family members; - Resource utilization and patient burden (e.g., costs associated with the imaging procedure, the number of imaging procedures, and other procedures conducted); - Harms: adverse effects or harms associated with the imaging techniques (e.g., test-related anxiety, adverse events secondary to venipuncture, contrast allergy, exposure to radiation) and adverse effects or harms associated with test-associated diagnostic workup (e.g., harms of biopsy or harms associated with workup of other incidental tumors discovered on imaging). | - Nonclinical and nondiagnostic outcomes.
Key Question 3
Populations | - Patients diagnosed with HCC undergoing staging before initial treatment. | - Patients with cholangiocarcinoma, unless they comprised <10% of the study population; - Patients with nonprimary (metastatic) lesions to the liver; - Patients undergoing imaging to evaluate response to ablative or other treatments; - Children.
Outcomes | - Measures of stage-specific accuracy of imaging (e.g., proportion correctly staged, understaged, and overstaged); - Intermediate and clinical outcomes as described for Key Questions 1 and 2. | - Nonclinical and nondiagnostic outcomes.

CT = computed tomography; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; MRI = magnetic resonance imaging; PET = positron emission tomography

### Study Selection

We developed criteria for inclusion and exclusion of studies based on the Key Questions and the populations, interventions, comparators, outcomes, timing, and setting (PICOTS) approach (Table 5). Papers were selected for full review if they were about imaging for HCC, were relevant to one or more Key Questions, and met the predefined inclusion criteria. We excluded studies published only as conference abstracts, restricted inclusion to English language articles, and excluded studies of nonhuman subjects. Studies had to report original data to be included.

Each abstract was reviewed for inclusion. Full-text articles were obtained for all studies that investigators identified as potentially meeting inclusion criteria. Two investigators independently reviewed all full-text articles for final inclusion or exclusion. Discrepancies were resolved through discussion and consensus.

We selected studies of adults without HCC undergoing surveillance (Key Question 1), imaging for further evaluation of a focal liver lesion or to distinguish HCC from another type of hepatic lesion (Key Question 2), and staging of HCC (Key Question 3). For Key Question 1, we also included studies on diagnostic accuracy of imaging for detection of HCC in nonsurveillance settings. These included series of patients undergoing treatments for HCC (e.g., liver transplantation, hepatic resection, or ablative therapy) or patients with a known prevalence of HCC who were undergoing imaging for purposes other than surveillance. These studies were reviewed under Key Question 1 because they provide information about the test performance of imaging modalities for detecting HCC lesions, rather than to further characterize or assess a previously identified lesion (Key Question 2). We excluded studies that reported diagnostic accuracy of imaging for non-HCC malignant lesions, including metastatic lesions to the liver. We included studies that reported diagnostic accuracy for HCC and cholangiocarcinoma together if the proportion of patients with cholangiocarcinoma was <10 percent.

We selected studies of US (with or without contrast enhancement), contrast-enhanced CT (nonmultidetector or multidetector spiral CT, and dual energy or spectral CT), contrast-enhanced MRI, and PET or PET/CT using various tracers. We excluded studies of nonspiral CT and MRI using machines ≤1.0 T, as these are considered outdated techniques.15 We excluded studies published prior to 1998 and also excluded studies in which imaging commenced prior to 1995, unless those studies reported use of imaging meeting minimum technical criteria (defined as nonmultidetector or multidetector spiral CT and MRI with a 1.5 or 3.0 T machine). We excluded studies that evaluated MRI with contrast agents that are no longer produced commercially and are unavailable for clinical use—for example, superparamagnetic iron oxide (ferumoxides or ferucarbotran) or mangafodipir contrast—unless results based on gadolinium-enhanced imaging phases were reported separately. Although US microbubble contrast agents are not approved by the U.S. Food and Drug Administration (FDA) for evaluation of liver lesions, we included such studies because these agents are available commercially outside the United States, US with contrast is commonly performed in other countries, and efforts to obtain FDA approval are on going.29–31 We excluded studies of CT arterial portography and CT hepatic angiography, which are invasive techniques not typically utilized in the United States for diagnosis and staging of HCC. We also excluded studies of intraoperative US.

For studies of test performance (e.g., sensitivity, specificity, and likelihood ratios), we included studies that evaluated one or more imaging methods against a reference standard. Reference standards were histopathology (based on explanted liver or nonexplant histological specimen from surgery or percutaneous biopsy), imaging plus clinical followup (e.g., lesion growth), or some combination of these standards. We excluded studies in which the reference standard involved one of the imaging tests under evaluation and that did not perform clinical followup, and we also excluded studies that had no reference standard (i.e., reported the number of lesions identified with an imaging technique, but did not evaluate accuracy against another reference technique).

To assess comparative effects of imaging on clinical outcomes (e.g., mortality, HCC recurrence, quality of life, and harms), we included randomized controlled trials that compared different imaging modalities or strategies. A systematic review funded by the Department of Veterans Affairs Evidence Synthesis program on effects of screening for HCC on clinical outcomes is forthcoming and will include comparative observational studies.32

To assess comparative effects of imaging on intermediate outcomes related to clinical decisionmaking (e.g., subsequent diagnostic testing, treatments, or resource utilization), we included randomized trials and cohort studies that compared different imaging modalities or strategies.

### Data Abstraction and Data Management

We extracted the following data from included studies into evidence tables using Excel spreadsheets: study design, year, setting, country, sample size, method of data collection (retrospective or prospective), eligibility criteria, population and clinical characteristics (including age, sex, race, underlying cause of liver disease, proportion of patients in sample with HCC, HCC lesion size, and proportion with cirrhosis), the number of imaging readers, criteria used for a positive test, and the reference standard used. We abstracted results for diagnostic accuracy, intermediate outcomes, and clinical outcomes, including results stratified according to patient, lesion, and imaging characteristics. Technical information for different imaging tests was abstracted as follows:15

- Ultrasound
  ○ Use of contrast
  ○ Type of contrast
  ○ Ultrasound operator (technician, physician, or other)
  ○ Transducer frequency
  ○ Use of Doppler
- Computed tomography
  ○ Use of multidetector scanner and the number of rows
  ○ Imaging sequences with timing
  ○ Contrast rate
  ○ Section thickness for contrast-enhanced images
  ○ Use of dual energy or spectral CT techniques
- Magnetic resonance imaging
  ○ MRI unit type (number of Teslas)
  ○ Imaging sequences with timing
  ○ Type of contrast
  ○ Section thickness
  ○ Use of diffusion-weighted imaging sequences
  ○ Spatial resolution
- Positron emission tomography
  ○ Scanner type (PET versus PET/CT)
  ○ Tracer type

Data abstraction for each study was completed by two investigators: the first abstracted the data, and the second reviewed the abstracted data for accuracy and completeness against the original articles. A team member with expertise in abdominal imaging reviewed data abstractions related to technical specifications.

## Assessment of Methodological Risk of Bias of Individual Studies

We assessed risk of bias (quality) for each study based on predefined criteria. Randomized trials and cohort studies were evaluated using criteria and methods developed by the U.S. Preventive Services Task Force.33 These criteria were applied in conjunction with the approach recommended in the Agency for Health Care Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”24 Studies of diagnostic test performance were assessed using the approach recommended in the AHRQ “Methods Guide for Medical Test Reviews,”25 which is based on methods developed by the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) group.34

Individual studies were rated as having “low,” “moderate,” or “high” risk of bias. Studies rated “low” risk of bias are generally considered valid. Randomized trials and cohort studies assessed as having low risk of bias have a valid method for allocating patients to treatment (for randomized trials); clear reporting of dropouts with low dropout rates; blinding of patients, clinicians, and/or outcome assessors to the interventions received; appropriate measurement of and analysis of confounders (for cohort studies); and appropriate measurement of outcomes. Studies of diagnostic test performance that are assessed as having low risk of bias enroll consecutive or randomly sampled patients, avoid use of a case-control design, use a credible reference standard, apply the same reference standard to all patients, use blinded interpretation of the diagnostic test as well as the reference standard, use preset criteria to define a positive test, avoid long delays between the imaging test and the reference standard, and have limited (defined for this report as <10%) loss to followup.7,12 We considered studies in which all patients had HCC as utilizing a case-control design, even if some patients also had other (non-HCC) lesions. We considered studies that utilized a histopathological reference standard or a reference standard consistent with European Association for the Study of the Liver (EASL) or AASLD criteria to be adequate, provided that the imaging test used as the reference standard was not the same as the test being evaluated. The AASLD criteria is based on tumor size, with lesions <1 cm undergoing serial imaging followup.9 Based on AASLD criteria, for lesions >1 cm, presence of a typical enhancement pattern on CT or MRI is considered diagnostic for HCC; for lesions without typical enhancement on one of these imaging tests, biopsy is required.

Studies rated as having “moderate” risk have some methodological shortcomings, but no flaw or combination of flaws judged likely to cause major bias. In some cases, the study may be missing information, making it difficult to assess its methods or potential limitations. The moderate risk of bias category is broad, and studies with this rating will vary in their strengths and weaknesses; the results of some studies assessed to have moderate risk of bias are likely to be valid, while others may be only possibly valid.

Studies rated as having “high” risk of bias have significant flaws that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; or serious discrepancies in reporting. The results of these studies are at least as likely to reflect flaws in the study design as the differences between the compared interventions. We did not exclude studies rated as having high risk of bias a priori, but they were considered the least reliable when synthesizing the evidence, particularly when discrepancies between studies were present.

## Data Synthesis

We performed meta-analyses on measures of test performance in order to help summarize data and obtain more precise estimates.35 All quantitative analyses were conducted using SAS^®^ 9.3 (SAS Institute Inc., Cary, NC). We only pooled studies that were clinically comparable and could provide a meaningful combined estimate (based on the variability among studies in design, patient population, imaging methods, and outcomes) and magnitude of effect size. We conducted separate analyses for each imaging modality, stratified according to the unit of analysis used (patients with HCC, HCC lesions, or liver segments with HCC), and analyzed studies of US with contrast separately from studies of US without contrast. For studies that used multiple readers, we averaged results across readers using the binomial specification of Proc NLMIXED on SAS. For Key Question 1, we also stratified analyses according to whether imaging was performed for surveillance or if imaging was performed in a series of patients for some other reason. For Key Question 2, we separately analyzed studies that evaluated further imaging of a focal liver lesion identified on previous imaging and studies evaluating the ability of imaging tests to distinguish between HCC and another specific non-HCC lesion. For Key Question 3, we separately analyzed studies on test performance of imaging for identifying metastatic HCC and accuracy of imaging for staging based on tumor, node, metastasis staging (TNM), Barcelona Liver Cancer Clinic (BLCC), and other criteria.

We evaluated a number of potential sources of heterogeneity (see below) and modifiers of diagnostic accuracy. We performed analyses stratified according to the reference standard used and on domains related to risk of bias, aspects of study design (retrospective or prospective, use of a confidence rating scale), setting (based on country in which imaging was performed), and technical factors (such as scanner types, type of contrast or tracer used, use of recommended imaging phases, timing of delayed phase imaging, and section thickness). We also evaluated diagnostic accuracy in subgroups stratified according to HCC lesion size, degree of tumor differentiation, and tumor location, as well as patient characteristics such as severity of underlying liver disease, underlying cause of liver disease, and body mass index. For analyzing effects of tumor size and degree of differentiation on estimates of accuracy, we analyzed studies on surveillance and diagnosis together. Because of the effects of lesion size on estimates of diagnostic accuracy, subgroup analyses for each imaging modality were performed on the subgroup of studies that were not restricted to small (<2–3 cm) HCC lesions.

We performed separate analyses on the subset of studies that directly compared two or more imaging modalities or techniques in the same population against a common reference standard. Research indicates that results based on such direct comparisons differ from results based on noncomparative studies, and may be better suited for evaluating comparative diagnostic test performance.36

We did not perform meta-analysis on staging accuracy and intermediate or clinical outcomes due to the small number of studies. Rather, we synthesized these studies qualitatively, using the methods described below for assessing the strength of evidence.

### Approaches to Data Analysis

We conducted meta-analysis to quantitatively synthesize data and obtain summary estimates of test performance. We used a bivariate logistic mixed effects model37 to analyze sensitivity and specificity, incorporating the correlation between sensitivity and specificity. We assumed random effects across studies with a bivariate normal distribution for sensitivity and specificity, and heterogeneity among the studies was measured based on the random effect variance (t^2^). The advantage of using a logistic mixed effects model is that it handles sparse data better and does not need to assume an ad hoc continuity correction when a study has zero events.37 When few studies were available for an analysis, we used the moment estimates of correlation between sensitivity and specificity in the bivariate model. We calculated positive likelihood ratio (LR+) and negative likelihood ratio (LR−) using the summarized sensitivity and specificity.38,39 We did not attempt to plot summary receiver operating characteristic (ROC) because many studies were missing data necessary to estimate ROC curves (due to failure to report specificity or number of true-negatives).40 In addition, the “threshold effect” assumption required for valid summary ROC curves did not appear to be met, as the estimated correlation between sensitivity and specificity was often positive. Finally, when a confidence rating scale was used to diagnose HCC, the cutoffs used in the included studies did not vary enough to demonstrate a potential threshold effect.

The data were synthesized by each imaging modality. To address possible source of heterogeneity among studies and produce meaningful summary estimates, we stratified analyses by Key Questions and the unit of analysis. We also conducted extensive subgroup and sensitivity analyses based on study-level, patient, tumor, technical, and other factors. When data were available, we performed separate meta-analyses for within-study comparisons based on technical factors, lesion size, and degree of tumor differentiation.

To assess the comparative effectiveness of alternative imaging modalities, we also conducted head-to-head comparisons between imaging modalities when data were available, using the same bivariate logistic mixed effects model as described above, but adding an indicator variable for imaging modalities (equivalent to a meta-regression approach). These analyses only included studies that directly compared two imaging modalities, in order to restrict the comparison to direct evidence. Again we stratified the comparisons by Key Questions and unit of analysis, and we conducted subgroup analyses by methodological and lesion characteristics when the data allowed. All analyses were conducted using SAS 9.3 (SAS institute Inc., Cary, NC).

## Grading the Strength of Evidence for Individual Comparisons and Outcomes

The strength of evidence for each Key Question was assessed by one researcher for each outcome described in the PICOTS using the approach described in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”24 The strength of evidence pertains to the overall quality of each body of evidence, and is based on the risk of bias (graded low, moderate, or high); the consistency of results between studies (graded consistent, inconsistent, or unknown/not applicable when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); and the precision of the estimate of effect, based on the number and size of studies and confidence intervals for the estimates (graded precise or imprecise). We did not downgrade a body of evidence for directness that evaluated an intermediate outcome, if the intermediate outcome (such as diagnostic accuracy or effects on clinical decisionmaking) was the specific focus of the Key Question. We did not grade supplemental domains for cohort studies evaluating intermediate and clinical outcomes because too few studies were available for these factors to impact the strength of evidence grades. We did not assess studies of diagnostic test performance for publication bias using graphical or statistical methods because research indicates that such methods can be misleading. Rather, we searched for unpublished studies through searches of clinical trials registries and regulatory documents and by soliciting SIPs.

We graded the strength of evidence for each Key Question using the four key categories recommended in the AHRQ Methods Guide.24 A “high” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion.

## Assessing Applicability

We recorded factors important for understanding the applicability of studies, such as whether the publication adequately described the study population, the country in which the study was conducted, the prevalence of HCC in the patients who underwent imaging, the magnitude of differences in measures of diagnostic accuracy and clinical outcomes, and whether the imaging techniques were reasonably representative of standard practice.41 We also recorded the funding source and role of the sponsor. We did not assign a rating of applicability (such as high or low) because applicability may differ based on the user of the report.

## Peer Review and Public Commentary

Experts in gastroenterology, hepatology, and radiology, along with individuals representing stakeholder and user communities, were invited to provide external peer review of the draft report; AHRQ and an EPC associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. All comments were reviewed and addressed in a disposition of comments report that will be made available 3 months after the Agency posts the final report of the systematic review on the AHRQ Web site.