# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Mark Ghany, M.D.
  National Institute of Diabetes and Digestive and Kidney Diseases
  Bethesda, MD
- Devan Kansagara, M.D.
  Portland Veterans Affairs Evidence-based Synthesis Program
  Portland, OR
- Tom Oliver, B.A., C.R.A.
  American Society of Clinical Oncology
  Alexandria, VA
- Mark Russo, M.D., M.P.H.
  Carolinas Medical Center and HealthCare System
  Charlotte, NC
- Morris Sherman, M.B., B.Ch., Ph.D.
  University of Toronto
  Toronto, Ontario, Canada
- Mark Somerfield, Ph.D.
  American Society of Clinical Oncology
  Alexandria, VA
- Christoph Wald, M.D., Ph.D.
  Tufts University Medical School
  Boston, MA
- Stephanie Wilson, M.D., FRCPC
  University of Calgary
  Calgary, Alberta, Canada