# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- James Adamson, M.D.
  Arkansas Blue Cross and Blue Shield
  Little Rock, AR
- Jeffrey W. Clark, M.D.
  Dana-Farber/Harvard Cancer Center
  Massachusetts General Hospital
  Boston, MA
- Adrian Di Bisceglie, M.D., FACP
  American Association for the Study of Liver Diseases
  Saint Louis University School of Medicine
  St. Louis, MO
- Darla McCloskey, R.N., B.S.N., P.H.N.
  Indian Health Service
  Winnebago, NE
- Morris Sherman, M.B., B.Ch., Ph.D.
  University of Toronto
  Toronto, Ontario, Canada
- Jeffrey C. Weinreb, M.D., FACR, FISMRM, FSCBT/MR
  American College of Radiology
  Yale School of Medicine
  New Haven, CT

A patient representative and a patient advocate (family member) also served as Key Informants.