# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tracy Dana, M.L.S., for assistance with literature search strategy development; Leah Williams, B.S., for editorial support; our Task Order Officer, Nahed El-Kassar, M.D., Ph.D., for her support and guidance in developing this report; and our Associate Editor, Issa Dahabreh, M.D., M.S., for his review of the report and helpful comments.