# Discussion

## Key Findings and Strength of Evidence

The key findings of this review, including strength of evidence grades, are summarized in Tables 23–40. Details about factors assessed to determine the overall strength of evidence grades are shown in Appendix J. No body of evidence was rated high strength of evidence, due to methodological shortcomings, imprecision, and/or inconsistency. Moderate strength of evidence ratings were primarily limited to estimates of diagnostic accuracy for CT and MRI, and some direct comparisons involving US versus CT or MRI.

Table 23 Summary of evidence for Key Question 1.a (detection): Test performance

Subquestion | Imaging Modality or Comparison | Strength of Evidence | Summary
Surveillance settings Unit of analysis: patients with HCC | US without contrast | Sensitivity: Low Specificity: Low | Sensitivity was 0.78 (95% CI, 0.60 to 0.89; 4 studies) and specificity 0.89 (95% CI, 0.80 to 0.94; 3 studies), for an LR+ of 6.8 (95% CI, 4.2 to 11) and LR− of 0.25 (95% CI, 0.13 to −0.46).
Surveillance settings Unit of analysis: patients with HCC | CT | Sensitivity: Low Specificity: Low | Sensitivity was 0.84 (95% CI, 0.59 to 0.95; 2 studies) and specificity 0.999 (95% CI, 0.86 to 0.99; 2 studies), for an LR+ of 60 (95% CI, 5.9 to 622) and LR− of 0.16 (95% CI, 0.06 to 0.47).
Surveillance settings Unit of analysis: patients with HCC | MRI or PET | Insufficient | No evidence
Surveillance settings Unit of analysis: HCC lesions | US without contrast | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.60 (95% CI, 0.24 to 0.87; 1 study); specificity was not reported.
Surveillance settings Unit of analysis: HCC lesions | CT | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.62 (95% CI, 0.46 to 0.76; 1 study).
Surveillance settings Unit of analysis: HCC lesions | MRI or PET | Insufficient | No evidence
Nonsurveillance settings Unit of analysis: patients with HCC | US without contrast | Sensitivity: Low Specificity: Low | Sensitivity was 0.73 (95% CI, 0.46 to 0.90; 8 studies) and specificity 0.93 (95% CI, 0.85 to 0.97; 6 studies), for an LR+ of 11 (95% CI, 5.4 to 21) and LR− of 0.29 (95% CI, 0.13 to 0.65).
Nonsurveillance settings Unit of analysis: patients with HCC | CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.83 (95% CI, 0.75 to 0.89; 16 studies) and specificity 0.92 (95% CI, 0.86 to 0.96; 11 studies), for an LR+ of 11 (95% CI, 5.6 to 20) and LR− of 0.19 (95% CI, 0.12 to 0.28).
Nonsurveillance settings Unit of analysis: patients with HCC | MRI | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.85 (95% CI, 0.76 to 0.91; 10 studies) and specificity 0.90 (95% CI, 0.81 to 0.94; 8 studies), for an LR+ of 8.1 (95% CI, 4.3 to 15) and LR− of 0.17 (95% CI, 0.10 to 0.28).
Nonsurveillance settings Unit of analysis: patients with HCC | PET | Sensitivity: Moderate Specificity: Low | For FDG PET, sensitivity was 0.52 (95% CI, 0.39 to 0.66; 15 studies) and specificity was 0.95 (95% CI, 0.82 to 0.99; 5 studies), for an LR+ of 11 (95% CI, 2.6 to 49) and LR− of 0.50 (95% CI, 0.37 to 0.68). For ^11^C-acetate PET or PET/CT, sensitivity was 0.85 (95% CI, 0.67 to 0.94; 4 studies); specificity was not reported.
Nonsurveillance settings Unit of analysis: HCC lesions | US without contrast | Sensitivity: Moderate Specificity: Low | Sensitivity was 0.59 (95% CI, 0.42 to 0.74; 11 studies). Only 2 studies reported specificity, with inconsistent results (0.63; 95% CI, 0.53 to 0.73, and 0.95; 95% CI, 0.85 to 0.99).
Nonsurveillance settings Unit of analysis: HCC lesions | US with contrast | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.73 (95% CI, 0.52 to 0.87; 8 studies). No study evaluated specificity.
Nonsurveillance settings Unit of analysis: HCC lesions | CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.77 (95% CI, 0.72 to 0.80; 79 studies) and specificity 0.89 (95% CI, 0.84 to 0.93; 21 studies), for an LR+ of 7.1 (95% CI, 4.7 to 11) and LR− of 0.26 (95% CI, 0.22 to 0.31).
Nonsurveillance settings Unit of analysis: HCC lesions | MRI | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.82 (95% CI, 0.79 to 0.85; 75 studies) and specificity 0.87 (95% CI, 0.77 to −0.93; 16 studies), for an LR+ of 6.4 (95% CI, 3.5 to 12) and LR− of 0.20 (95% CI, 0.16 to 0.25).
Nonsurveillance settings Unit of analysis: HCC lesions | PET | Sensitivity: Moderate Specificity: Low | For FDG PET, sensitivity was 0.53 (95% CI, 0.41 to 0.65; 5 studies) and specificity 0.91 (95% CI, 0.76 to 0.98; 1 study). For ^11^C-acetate PET, sensitivity was 0.78 (95% CI, 0.61 to 0.89; 4 studies); specificity was not reported.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.68 (95% CI, 0.54 to 0.80) vs. 0.80 (95% CI, 0.68 to 0.88), for a difference of −0.12 (95% CI, −0.20 to −0.03), based on 6 studies. Two studies were performed in surveillance settings. (Low strength of evidence for sensitivity and specificity.)
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. MRI | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.61 (95% CI, 0.48 to 0.74) vs. 0.81 (95% CI, 0.69 to 0.89), for a difference of −0.19 (95% CI, −0.30 to −0.08), based on 3 studies, none of which were performed in surveillance settings.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | MRI vs. CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.88 (95% CI, 0.53 to 0.98) vs. 0.82 (95% CI, 0.41 to 0.97), for a difference of 0.06 (95% CI, −0.05 to 0.17), based on 4 studies, none of which were performed in surveillance settings.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US without contrast vs. CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.55 (95% CI, 0.43 to 0.66) vs. 0.66 (95% CI, 0.54 to 0.76), for a difference of −0.11 (95% CI, −0.18 to −0.04), based on 3 studies, none of which were performed in surveillance settings.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US without contrast vs. MRI | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.57 (95% CI, 0.42 to 0.71) vs. 0.79 (95% CI, 0.67 to 0.88), for a difference of −0.22 (95% CI, −0.31 to 0.14), based on 3 studies, none of which were performed in surveillance settings.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. CT | Sensitivity: Moderate Specificity: Insufficient | Sensitivity was 0.51 (95% CI, 0.29 to 0.74) vs. 0.61 (95% CI, 0.38 to 0.81), for a difference of −0.10 (95% CI, −0.20 to −0.00), based on 4 studies, none of which were performed in surveillance settings.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. MRI | Sensitivity: Moderate Specificity: Insufficient | Sensitivity was 0.65 (95% CI, 0.41 to 0.84) vs. 0.73 (95% CI, 0.50 to 0.88), for a difference of −0.08 (95% CI, −0.19 to 0.02), based on 3 studies, none of which were performed in surveillance settings.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | MRI vs. CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.81 (95% CI, 0.76 to 0.84) vs. 0.71 (95% CI, 0.66 to 0.76), for a difference of 0.09 (95% CI, 0.07 to 0.12), based on 31 studies, none of which were performed in surveillance settings. Findings were similar when studies were stratified according to use of nonhepatic-specific or hepatic-specific contrast and when the analysis was restricted to HCC lesions <2–3 cm. For HCC lesions <2–3 cm, the difference in sensitivity was greater for studies of hepatic-specific MRI contrast (0.23; 95% CI, 0.17 to 0.29; 12 studies) than for studies of nonhepatic-specific MRI contrast (0.06; 95% CI, −0.01 to 0.13; 6 studies).
Multiple imaging modalities | Various combinations | Sensitivity: Insufficient Specificity: Insufficient | One study found sensitivity of imaging with various combinations of 2 imaging modalities was similar or lower than with single-modality imaging, based on concordant positive findings on 2 imaging modalities. The other study reported higher sensitivity with multiple imaging modalities than with single-modality imaging, but criteria for positive results based on multiple imaging modalities were unclear.

CI = confidence interval; CT = computed tomography; FDG = ^18^F-fluorodeoxyglucose; HCC = hepatocellular carcinoma; LR+ = positive likelihood ratio; LR− = negative likelihood ratio; MRI = magnetic resonance imaging; PET = positron emission tomography; US = ultrasound.

Table 24 Summary of evidence for Key Question 1.a.i (detection): Effects of reference standard on test performance (based on HCC lesions as the unit of analysis)

Imaging Modality or Comparison | Strength of Evidence | Summary
US without contrast | Sensitivity: Moderate Specificity: Insufficient | Using HCC lesions as the unit of analysis, sensitivity was 0.34 (95% CI, 0.22 to 0.47) in 5 studies that used explanted liver as the reference standard and ranged from 0.72 to 0.75 in studies that used other reference standards.
US with contrast | Sensitivity: Low Specificity: Insufficient | No study using HCC lesions as the unit of analysis used an explanted liver reference standard. Sensitivity was 0.58 (95% CI, 0.39 to 0.75) using a nonexplant histopathological reference standard and 0.98 (95% CI, 0.88 to 0.997) using a mixed reference standard.
CT | Sensitivity: Moderate Specificity: Moderate | Using HCC lesions as the unit of analysis, sensitivity was 0.67 (95% CI, 0.59 to 0.75) in 23 studies that used explanted liver as the reference standard and ranged from 0.65 to 0.86 in studies that used other reference standards.
MRI | Sensitivity: Moderate Specificity: Moderate | Using HCC lesions as the unit of analysis, sensitivity was 0.69 (95% CI, 0.59 to 0.77) in 15 studies that used explanted liver as the reference standard and ranged from 0.85 to 0.88 in studies that used a nonexplant histopathological reference standard or mixed reference standard; only 3 studies evaluated an imaging/clinical reference standard (sensitivity, 0.65; 95% CI, 0.43 to 0.83).
PET | Sensitivity: Low Specificity: Insufficient | No study of FDG PET used an explanted liver reference standard. Four of the 5 studies that used HCC lesions as the unit of analysis used a nonexplant histological reference standard (sensitivity, 0.49; 95% CI, 0.37 to 0.61).

CI = confidence interval; CT = computed tomography; FDG = ^18^F-fluorodeoxyglucose; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; PET = positron emission tomography; US = ultrasound.

Table 25 Summary of evidence for Key Question 1.a.ii (detection): Effects of patient, tumor, technical, and other factors on test performance

Subquestion | Imaging Modality or Comparison | Strength of Evidence | Summary
Lesion size | US without contrast | Sensitivity: Moderate Specificity: Low | Sensitivity was 0.82 (95% CI, 0.68 to 0.91) for lesions ≥2 cm and 0.34 (95% CI, 0.19 to 0.53) for lesions <2 cm, for a difference of 0.48 (95% CI, 0.39 to 0.57). Sensitivity was 0.09 (95% CI, 0.02 to 0.29; 4 studies) for lesions <10 mm, to 0.50 (95% CI, 0.23 to 0.78; 4 studies) for lesions 10–20 mm and 0.88 (95% CI, 0.66 to 0.96; 4 studies) for lesions >20 mm, for a difference of 0.37 (95% CI, 0.18 to 0.57) for lesions >20 mm vs. 10–20 mm and 0.41 (95% CI, 0.19 to 0.63) for lesions 10–20 mm vs. <10 mm.
Lesion size | US with contrast | Sensitivity: Low Specificity: Low | Sensitivity was 0.94 (95% CI, 0.83 to 0.98) for lesions ≥>2 cm and 0.77 (95% CI, 0.53 to 0.91) for lesions <2 cm, for a difference of 0.17 (95% CI, 0.03 to 0.32), based on 5 studies. Three studies found sensitivity of 0.64 (95% CI, 0.33 to 0.87) for lesions 10–20 mm and 0.91 (95% CI, 0.71 to 0.98) for lesions >20 mm, for a difference of 0.26 (95% CI, 0.04 to 0.48).
Lesion size | CT | Sensitivity: Moderate Specificity: Low | Sensitivity was 0.94 (95% CI, 0.92 to 0.95) for lesions ≥2 cm and 0.63 (95% CI, 0.57 to 0.69) for lesions <2 cm, for an absolute difference in sensitivity of 0.31 (95% CI, 0.26 to 0.36), based on 34 studies. Sensitivity was 0.32 (95% CI, 0.25 to 0.41; 21 studies) for lesions <10 mm, 0.74 (95% CI, 0.67 to 0.80; 23 studies) for lesions 10–20 mm, and 0.95 (95% CI, 0.92 to 0.97; 20 studies), for a difference of 0.21 (95% CI, 0.15 to 0.26) for lesions >20 vs. 10–20 mm and 0.42 (95% CI, 0.36 to 0.48) for lesions 10–20 vs. <10 mm.
Lesion size | MRI | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.96 (95% CI, 0.93 to 0.97) for lesions ≥2 cm and 0.66 (95% CI, 0.58 to 0.74) for lesions <2 cm, for an absolute difference in sensitivity of 0.29 (95% CI, 0.23 to 0.36), based on 29 studies. Sensitivity was 0.45 (95% CI, 0.34 to 0.56; 20 studies) for lesions <10 mm, 0.78 (95% CI, 0.69 to 0.85; 21 studies) for lesions 10–20 mm, and 0.97 (95% CI, 0.94 to 0.98, 14 studies) for lesions >20 mm (95% CI, 0.94 to 0.98; 18 studies), for a difference of 0.19 (95% CI, 0.12 to 0.26) for >20 vs. 10–20 mm and 0.33 (95% CI, 0.26 to 0.40) for 10–20 vs. <10 mm.
Lesion size | PET | Sensitivity: Low Specificity: Insufficient | For FDG PET, sensitivity was consistently higher for larger lesions, based on 5 studies. Data were not pooled due to differences in the tumor size categories evaluated. Two studies of ^11^C-acetate PET found inconsistent effects of lesion size on sensitivity.
Degree of tumor differentiation | US with contrast | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.83 (95% CI, 0.55 to 0.95) for moderately or poorly differentiated HCC lesions and 0.43 (95% CI, 0.15 to 0.76) for well differentiated lesions, for an absolute difference in sensitivity of 0.40 (95% CI, 0.17 to 0.64), based on 3 studies.
Degree of tumor differentiation | CT | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.82 (95% CI, 0.66 to 0.91) for moderately or poorly differentiated HCC lesions and 0.50 (95% CI, 0.29 to 0.70) for well differentiated lesions, for an absolute difference in sensitivity of 0.32 (95% CI, 0.19 to 0.45), based on 5 studies.
Degree of tumor differentiation | MRI | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.68 (95% CI, 0.44 to 0.86) for moderately or poorly differentiated HCC lesions and 0.37 (95% CI, 0.17 to 0.62) for well differentiated lesions, for an absolute difference in sensitivity of 0.31 (95% CI, 0.13 to 0.49), based on 3 studies.
Degree of tumor differentiation | PET | Sensitivity: Low Specificity: Insufficient | For FDG PET, sensitivity was 0.72 (95% CI, 0.59 to 0.83) for moderately or poorly differentiated HCC lesions and 0.39 (95% CI, 0.26 to 0.55) for well differentiated lesions, for an absolute difference in sensitivity of 0.33 (95% CI, 0.20 to 0.46), based on 6 studies. In 3 studies of ^11^C-acetate PET and 1 study of ^18^F-fluorochorine PET, sensitivity for more well differentiated lesions was not lower than for more poorly differentiated lesions.
Other factors | US | Low | In 2 studies that directly compared US with vs. without contrast, there was no clear difference in sensitivity (−0.04; 95% CI, −0.11 to 0.04). One study that directly compared use of Doppler vs. no Doppler showed no clear effect on estimates of sensitivity. Lesion depth and body mass index had no effect on estimates of sensitivity.
Other factors | CT | Low | Using patients with HCC as the unit of analysis, studies with a contrast rate ≥3 ml/s reported a higher sensitivity (0.87; 95% CI, 0.77 to 0.93; 8 studies) than studies with a contrast rate <3 ml/s (0.71; 95% CI, 0.50 to −0.85; 4 studies). Studies with delayed phase imaging reported somewhat higher sensitivity (0.89; 95% CI, 0.81 to 0.94; 7 studies) than studies without delayed phase imaging (0.74; 95% CI, 0.66 to 0.87; 7 studies). However, neither of these technical parameters had clear effects in studies that used HCC lesions as the unit of analysis.
Other factors | MRI | Low | There were no clear differences in estimates of diagnostic accuracy when studies were stratified according to MRI scanner type (1.5 vs. 3.0 T), imaging phases evaluated (with or without delayed phase imaging), timing of delayed phase imaging (≥120 seconds vs. <120 seconds), section thickness (≤5 mm for enhanced images vs. >5 mm), or use of diffusion-weighted imaging. In studies that directly compared diagnostic accuracy with different types of contrast, hepatic-specific contrast agents were associated with slightly higher sensitivity than nonhepatic-specific contrast agents (0.83; 95% CI, 0.75 to 0.90, vs. 0.74; 95% CI, 0.62 to 0.83; difference 0.10; 95% CI, 0.04 to 0.15; 6 studies).
Other factors | PET | Low | FDG PET was associated with lower sensitivity that ^11^C-acetate PET when either patients (0.58 vs. 0.81, for a difference of −0.23; 95% CI, −0.34 to −0.13; 3 studies) or HCC lesions (0.52 vs. 0.79, for a difference of −0.27; 95% CI, −0.36 to −0.17; 3 studies) were the unit of analysis. FDG PET was also associated with lower sensitivity that dual tracer PET with FDG and ^11^C-acetate or ^18^F-choline PET, but evidence was limited to 1 or 2 studies for each of these comparisons. Using patients as the unit of analysis, sensitivity of FDG PET (0.39; 95% CI, 0.24 to 0.56; 8 studies) was lower than sensitivity of FDG PET/CT (0.65; 95% CI, 0.50 to 0.78; 7 studies).

CI = confidence interval; CT = computed tomography; FDG = ^18^F-fluorodeoxyglucose; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; PET = positron emission tomography; US = ultrasound.

Table 26 Summary of evidence for Key Question 1.b (detection): Clinical decisionmaking

Imaging Modality or Comparison | Strength of Evidence | Summary
Effects of different imaging modalities or strategies on clinical decisionmaking | Low | One randomized controlled trial (n = 163) found no clear differences between surveillance with US without contrast vs. CT in HCC detection rates, subsequent imaging, or cost per HCC detected.

CT = computed tomography; HCC = hepatocellular carcinoma; US = ultrasound.

Table 27 Summary of evidence for Key Question 1.c (detection): Clinical and patient-centered outcomes

Imaging Modality or Comparison | Strength of Evidence | Summary
US plus serum AFP | Low | One cluster randomized controlled trial (n = 18,816) conducted in China found screening every 6 months with noncontrast US plus serum AFP vs. no screening in persons 35 to 79 years of age (mean, 42 years) with HBV infection or chronic hepatitis without HBV infection to be associated with lower risk of HCC-related mortality (32 vs. 54 deaths; rate ratio, 0.63; 95% CI, 0.41 to 0.98) at 5-year followup, but was rated high risk of bias due to multiple methodological shortcomings.
US screening at different intervals, mortality | Moderate | Two trials (n = 2,022) found no clear differences in mortality with US screening at 4- vs. 12-month intervals, or at 3- vs. 6-month intervals. One trial (n = 163) found no difference in HCC mortality between surveillance with US without contrast vs. CT, but was underpowered to detect differences.

AFP = alpha-fetoprotein; CI = confidence interval; CT = computed tomography; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; US = ultrasound.

Table 28 Summary of evidence for Key Question 1.d (detection): Harms

Imaging Modality or Comparison | Strength of Evidence | Summary
MRI, CT, US | Insufficient | One study reported no serious adverse events associated with administration of gadoxetic acid for MRI, and 1 study reported no clear differences in adverse events between CT with contrast at 3 ml/s vs. 5 ml/s. No study reported rates of adverse events associated with use of microbubble contrast agents in US, and harms were not reported in randomized trials of screening with imaging.

CT = computed tomography; MRI = magnetic resonance imaging; US = ultrasound.

Table 29 Summary of evidence for Key Question 2.a (evaluation of focal liver lesions): Test performance

Subquestion | Imaging Modality or Comparison | Strength of Evidence | Summary
Evaluation of focal liver lesion Unit of analysis: patients with HCC | US with contrast | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.87 (95% CI, 0.79 to 0.92; 12 studies) and specificity 0.91 (95% CI, 0.83 to 0.95; 8 studies), for an LR+ of 9.6 (95% CI, 5.1 to 18) and LR− of 0.14 (95% CI, 0.09 to 0.23).
Evaluation of focal liver lesion Unit of analysis: patients with HCC | US without contrast | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.78 (95% CI, 0.69 to 0.86) in 1 study; specificity was not reported.
Evaluation of focal liver lesion Unit of analysis: patients with HCC | CT | Sensitivity: Moderate Specificity: Low | Sensitivity was 0.86 (95% CI, 0.75 to 0.92; 8 studies) and specificity 0.88 (95% CI, 0.76 to 0.95; 5 studies), for an LR+ of 7.4 (95% CI, 3.3 to 17) and LR− of 0.16 (95% CI, 0.09 to 0.30).
Evaluation of focal liver lesion Unit of analysis: patients with HCC | MRI | Sensitivity: Low Specificity: Low | Sensitivity was 0.77 (95% CI, 0.66 to 0.84; 4 studies) and specificity was 0.81 (95% CI, 0.52 to 0.94; 4 studies), for an LR+ of 4.0 (95% CI, 1.4 to 12) and LR− of 0.29 (95% CI, 0.21 to 0.39).
Evaluation of focal liver lesion Unit of analysis: HCC lesions | US with contrast | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.87 (95% CI, 0.80 to 0.92; 21 studies) and specificity 0.91 (95% CI, 0.85 to 0.95; 10 studies) for an LR+ of 9.8 (95% CI, 5.7 to 17) and LR− of 0.14 (95% CI, 0.09 to 0.23).
Evaluation of focal liver lesion Unit of analysis: HCC lesions | CT | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.79 (95% CI, 0.67 to 0.87; 13 studies) and specificity 0.90 (95% CI, 0.37 to 0.99; 6 studies), for an LR+ of 7.7 (95% CI, 0.71 to 84) and LR− of 0.24 (95% CI, 0.15 to 0.38).
Evaluation of focal liver lesion Unit of analysis: HCC lesions | MRI | Sensitivity: Moderate Specificity: Moderate | Sensitivity was 0.81 (95% CI, 0.72 to 0.87; 14 studies) and specificity 0.93 (95% CI, 0.80 to 0.98; 11 studies), for an LR+ of 12 (95% CI, 3.8 to 39) and LR− of 0.21 (95% CI, 0.15 to 0.30).
Evaluation of focal liver lesion Unit of analysis: HCC lesions | PET | Sensitivity: Low Specificity: Low | Sensitivity was 0.56 to 0.57 and specificity 1.0 in 2 studies of FDG PET.
For distinguishing HCC lesions from non-HCC hepatic lesions | US with contrast | Sensitivity: Low Specificity: Low | One study found US with sulfur hexafluoride contrast associated with a sensitivity of 0.94 (62/66) and a specificity of 0.68 (23/34) for distinguishing hypervascular HCC from focal nodular hyperplasia using quantitative methods, and 1 study found US with perflubutane contrast associated with a sensitivity of 0.59 (32/54) and specificity of 1.0 (13/13) for distinguishing small (<3 cm) well differentiated HCC lesions from regenerative nodules.
For distinguishing HCC lesions from non-HCC hepatic lesions | CT | Sensitivity: Low Specificity: Low | Five studies evaluated accuracy of CT for distinguishing HCC from non-HCC lesions, but the non-HCC lesions varied in the studies, precluding strong conclusions.
For distinguishing HCC lesions from non-HCC hepatic lesions | MRI | Sensitivity: Moderate Specificity: Moderate | Four studies reported inconsistent results for distinguishing small (<2 to 3 cm) hypervascular HCC lesions from hypervascular pseudolesions, with sensitivity 0.47 and 0.52 in 2 studies, and 0.91 and 0.92 in the other 2. Specificity was 0.93 or higher in all 4 studies. Eight other studies evaluated accuracy of MRI for distinguishing HCC from non-HCC lesions, but the non-HCC hepatic lesions varied in the studies.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. CT | Sensitivity: Low Specificity: Insufficient | Sensitivity was 0.78 (95% CI, 0.70 to 0.85) vs. 0.89 (95% CI, 0.84 to 0.95), for a difference of −0.12 (95% CI, −0.21 to −0.02), based on 1 study.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US with contrast vs. CT | Sensitivity: Moderate Specificity: Low | Sensitivity was 0.91 (95% CI, 0.85 to 0.94) vs. 0.88 (95% CI, 0.81 to 0.92), for a difference of 0.03 (95% CI, −0.02 to 0.08), based on 5 studies.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | MRI vs. CT | Sensitivity: Low Specificity: Low | Sensitivity was 0.81 (95% CI, 0.70 to 0.92) vs. 0.74 (95% CI, 0.62 to 0.87), for a difference of 0.06 (−0.10 to 0.23), based on 1 study.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. CT | Sensitivity: Moderate Specificity: Insufficient | Sensitivity was 0.92 (95% CI, 0.88 to 0.96) vs. 0.89 (95% CI, 0.83 to 0.93), for a difference of 0.04 (95% CI, −0.02 to 0.09), based on 4 studies.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. MRI | Sensitivity: Low Specificity: Low | Sensitivity was 0.79 (95% CI, 0.65 to 0.94) vs. 0.83 (95% CI, 0.69 to 0.97), for a difference of −0.03 (95% CI, −0.24 to 0.17), based on 1 study.
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | MRI vs. CT | Sensitivity: Low Specificity: Low | One study found MRI associated with higher sensitivity (0.84; 95% CI, 0.76 to 0.92 vs. 0.62; 95% CI, 0.52 to 0.72, for a difference of 0.22; 95% CI, 0.09 to 0.35) but lower specificity (0.36; 95% CI, 0.20 to 0.52 vs. 0.72; 95% CI, 0.58 to 0.87, for a difference of −0.36; 95% CI, −0.58 to −0.15) than CT.
Multiple imaging modalities | Various combinations | Moderate | In 4 studies in which positive results with multiple modality imaging were defined as concordant typical findings for HCC on 2 imaging modalities, sensitivity was lower than with a single modality (difference in sensitivity ranged from 0.09 to 0.27), with no clear difference in specificity. In 3 studies in which positive results with multiple modality imaging were defined as typical findings for HCC on at least 1 of the imaging techniques, sensitivity was higher than with a single modality (increase in sensitivity ranged from 0.09 to 0.25), with no clear difference in specificity. One study found that a sequential imaging strategy in which a second imaging test was performed only for indeterminate results on initial CT increased sensitivity for HCC from 0.53 to 0.74 to 0.79.

CI = confidence interval; CT = computed tomography; FDG = ^18^F-fluorodeoxyglucose;; LR+ = positive likelihood ratio; LR− = negative likelihood ratio; MRI = magnetic resonance imaging; PET = positron emission tomography; US = ultrasound.

Table 30 Summary of evidence for Key Question 2.a.i (evaluation of focal liver lesions): Effects of reference standard on test performance (based on HCC lesions as the unit of analysis)

Imaging Modality or Comparison | Strength of Evidence | Summary
All | Sensitivity: Moderate Specificity: Moderate | No study used explanted liver as the reference standard. There were no clear differences across imaging modalities in estimates of diagnostic accuracy in analyses stratified by use of different nonexplant reference standards.

HCC = hepatocellular carcinoma.

Table 31 Summary of evidence for Key Question 2.a.ii (evaluation of focal liver lesions): Effects of patient, tumor, technical, and other factors on test performance

Subquestion | Imaging Modality or Comparison | Strength of Evidence | Summary
Other factors | US | Low | In 2 studies that directly compared US with vs. without contrast, US with contrast was associated with sensitivity of 0.89 (95% CI, 0.83 to 0.93) and US without contrast with a sensitivity of 0.39 (95% CI, 0.32 to 0.47), for a difference in sensitivity of 0.50 (95% CI, 0.41 to 0.58). Based on across-study comparisons, there were no clear differences in sensitivity between different US contrast agents; no study directly compared different contrast agents. There were no differences in sensitivity of US based on lesion depth (3 studies) or body mass index (2 studies).
Other factors | CT | Low | Evidence on effects of technical parameters (type of CT scanner, use of delayed phase imaging, section thickness) was limited by small numbers of studies with wide CIs and methodological limitations, precluding reliable conclusions. Two studies found no clear difference in sensitivity of CT for HCC in patients with vs. without cirrhosis.
Other factors | MRI | Low | There were no clear differences in estimates of sensitivity based on the type of MRI machine (3.0 T vs. 1.5 T), type of contrast, use of delayed phase imaging, timing of delayed phase imaging, and section thickness. Estimates were similar when studies that used diffusion-weighted imaging were excluded.

CI = confidence interval; CT = computed tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; US = ultrasound.

Table 32 Summary of evidence for Key Question 2.b (evaluation of focal liver lesions): Clinical decisionmaking

Imaging Modality or Comparison | Strength of Evidence | Summary
All | Insufficient | No evidence

Table 33 Summary of evidence for Key Question 2.c (evaluation of focal liver lesions): Clinical and patient-centered outcomes

Imaging Modality or Comparison | Strength of Evidence | Summary
All | Insufficient | No evidence

Table 34 Summary of evidence for Key Question 2.d (evaluation of focal liver lesions): Harms

Imaging Modality or Comparison | Strength of Evidence | Summary
US and CT | Insufficient | One study of US (with and without contrast) and CT reported harms, but did not stratify results by imaging technique. The overall rate of adverse drug-related events was 10%, with all events classified as mild.

CT = computed tomography; US = ultrasound.

Table 35 Summary of evidence for Key Question 3.a (staging): Test performance

Subquestion | Imaging Modality or Comparison | Strength of Evidence | Summary
Staging accuracy, using TNM criteria | CT | Moderate | The proportion correctly staged using TNM or BCLC criteria ranged from 28% to 58%, the proportion overstaged from 2% to 27%, and the proportion understaged from 25% to 52%, based on 6 studies.
Staging accuracy, using TNM criteria | MRI | Low | The proportion correctly staged ranged from 40% to 75%, the proportion overstaged from 3.1% to 31%, and the proportion understaged from 19% to 31%, based on 3 studies.
Staging accuracy, using TNM criteria | PET | Low | One study found 26% of patients were correctly staged with FDG PET and 91% with ^11^C-choline PET.
Staging accuracy, using TNM criteria | MRI vs. CT | Low | Two studies reported similar staging accuracy.
Identification of metastatic disease Unit of analysis: patients with metastatic HCC | PET | Sensitivity: Low Specificity: Low | Sensitivity of FDG PET was 0.85 (95% CI, 0.71 to 0.93; 6 studies) and specificity 0.93 (95% CI, 0.89 to 0.95; 5 studies), for an LR+ of 11 (95% CI, 7.8 to 17) and LR− of 0.16 (95% CI, 0.08 to 0.33). One study that directly compared sensitivity of FDG PET vs. ^11^C-acetate PET reported comparable sensitivity (0.79 vs. 0.71), although sensitivity was higher when both tracers were used (0.98).
Identification of metastatic disease Unit of analysis: patients with metastatic HCC | PET/CT vs. CT | Low | Three studies found no difference in sensitivity (0.82; 95% CI, 0.61 to 0.93 vs. 0.85; 95% CI, 0.66 to 0.95).
Identification of metastatic disease Unit of analysis: metastatic HCC lesions | PET | Sensivity: Low Specificity: Insufficient | Sensitivity of FDG PET was 0.82 (95% CI, 0.72 to 0.90; 5 studies). One study that directly compared sensitivity of FDG vs. ^11^C-acetate PET reported comparable sensitivity (0.86 vs. 0.77).

BCLC = Barcelona Clinic Liver Cancer; CI = confidence interval; CT = computed tomography; FDG = ^18^F-fluorodeoxyglucose; HCC = hepatocellular carcinoma; LR+ = positive likelihood ratio; LR− = negative likelihood ratio; MRI = magnetic resonance imaging; PET = positron emission tomography; TNM = tumor, node, metastasis staging.

Table 36 Summary of evidence for Key Question 3.a.i (staging): Effects of reference standard on test performance

Imaging Modality or Comparison | Strength of Evidence | Summary
CT, MRI, PET | Sensitivity: Insufficient Specificity: Insufficient | Evidence was insufficient to determine effects of different reference standards on accuracy of staging using TNM criteria or accuracy of PET for identifying metastatic HCC because few studies evaluated alternative reference standards.

CT = computed tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; PET = positron emission tomography; TNM = tumor, node, metastasis staging.

Table 37 Summary of evidence for Key Question 3.a.ii (staging): Effects of patient, tumor, and technical factors on test performance

Imaging Modality or Comparison | Strength of Evidence | Summary
CT, MRI, PET | Insufficient | For accuracy of staging using TNM criteria, no study evaluated effects of patient-level characteristics or other factors on accuracy of imaging techniques for staging.
PET | Low | In 1 study that directly compared sensitivity of PET vs. PET/CT for identifying metastatic HCC lesions, there was no clear difference in sensitivity. Four studies of FDG PET found sensitivity increased as lesion size increased, but the number of lesions <1 cm was small (total of 20). Eight studies generally found sensitivity of FDG PET higher for lymph and bone metastasis than for lung metastasis, but samples were small, precluding strong conclusions.

CT = computed tomography; FDG = ^18^F-fluorodeoxyglucose; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; PET = positron emission tomography; TNM = tumor, node, metastasis staging.

Table 38 Summary of evidence for Key Question 3.b (staging): Clinical decisionmaking

Subquestion | Imaging Modality or Comparison | Strength of Evidence | Summary
Transplant eligibility, using Milan criteria | CT | Moderate | The proportion correctly assessed for transplant eligibility ranged from 40% to 96%. The proportion of patients who met transplant criteria based on CT but exceeded criteria based on the reference standard was 3.5% to 7.8%, based on 3 studies. Two studies found that 2.3% and 16% of patients who underwent transplantation based on Milan criteria had no HCC lesions on examination of explanted livers.
Transplant eligibility, using Milan criteria | CT vs. MRI | Low | One study reported similar accuracy.
Transplant eligibility, using Milan criteria | PET vs. CT | Low | One study found ^11^C-choline PET more accurate than CT (95% vs. 40%).
Use of resection and ablative therapies | MRI vs. CT | Low | One study reported that the proportion of decisions to perform resection or ablative therapies that were classified as correct were similar for MRI (90% and 90%, respectively) and CT (80% and 77%, respectively).

CT = computed tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; PET = positron emission tomography.

Table 39 Summary of evidence for Key Question 3.c (staging): Clinical and patient-centered outcomes

Imaging Modality or Comparison | Strength of Evidence | Summary
US with contrast vs. US without contrast plus CT | Low | One cohort study found that contrast-enhanced US identified more small (≤2 cm) HCC lesions than noncontrast US plus CT (36 vs. 31) and was associated with a higher complete necrosis rate following ablation (92%, or 106/115, vs. 83%, or 93/112 lesions; p = 0.036) but was rated high risk of bias. Another study that appeared to be performed in the same series of patients found US with contrast prior to radiofrequency ablation associated with lower local tumor progression rate (7.2% vs. 18%; rate ratio, 0.40; 95% CI, 0.16 to 0.87) and longer tumor-free survival (38 vs. 26 months), but was also rated high risk of bias.

CI = confidence interval; CT = computed tomography; HCC = hepatocellular carcinoma; US = ultrasound.

Table 40 Summary of evidence for Key Question 3.d (staging): Harms

Imaging Modality or Comparison | Strength of Evidence | Summary
All | Insufficient | No evidence

The great preponderance of evidence on imaging for HCC addressed diagnostic test performance. However, few studies evaluated test performance of imaging for HCC in true surveillance settings (i.e., in patients at high risk for but without a prior diagnosis of HCC), resulting in low strength of evidence ratings. Among the limited evidence available in this setting, two studies that directly compared sensitivity of US without contrast and CT did report lower sensitivity with US for detection of patients with HCC (low strength of evidence). 54,112

Many more studies evaluated test performance of imaging for detection of HCC in nonsurveillance settings, such as populations of patients undergoing treatment such as liver transplantation, hepatic resection, or ablation therapy, or in series of patients previously diagnosed with HCC who underwent additional imaging. Although these patients were known to have HCC lesions, the purpose of these studies was not to further characterize previously identified HCC lesions. Rather, their purpose was to evaluate test performance for detection of HCC lesions. We analyzed these studies separately from studies conducted in true surveillance settings, given the differences in the reason for imaging and the populations evaluated (including a generally much higher prevalence of HCC—some studies were restricted to only patients with HCC). In these studies, sensitivity was lower for US without contrast than for CT or MRI, with a difference in sensitivity based on within-study (direct) comparisons of 0.11 to 0.22, using HCC lesions as unit of analysis (moderate strength of evidence). MRI and CT performed similarly when patients with HCC were the unit of analysis, but sensitivity of MRI was higher than CT when HCC lesions were the unit of analysis (pooled difference 0.09. 95% CI 0.07 to 12) (moderate strength of evidence).

Ultrasound with contrast did not perform better than ultrasound without contrast for detection of HCC (low strength of evidence).67,79 This is probably related to the short duration in which microbubble contrast is present within the liver, such that it is not possible to perform a comprehensive contrast-enhanced examination of the liver.20 Rather, the main use of ultrasound with contrast appears to be for evaluation of previously identified focal liver lesions.

For characterization of previously identified lesions, we found no clear differences in sensitivity between US with contrast, CT, and MRI (moderate strength of evidence). Although some evidence was available on the accuracy of imaging modalities for distinguishing between HCC and other (non-HCC) liver lesions, it was not possible to draw strong conclusions due to variability in the types of non-HCC lesions evaluated (regenerative nodules, dysplastic nodules, hypervascular pseudolesions, hemangiomas, etc.), small numbers of studies, and some inconsistency in findings.

Several factors appeared to affect estimates of test performance across different imaging modalities. Studies of patients with HCC were generally associated with somewhat higher sensitivity than studies that used HCC lesions as the unit of analysis. In addition, use of multiple reference standards poses a challenge to assessment of diagnostic accuracy.324 Studies that used explanted livers as the reference standard reported lower sensitivity than studies that used a nonexplant reference standard (moderate strength of evidence). The explanted liver reference standard is probably associated with lower sensitivity because additional lesions not detectable on imaging—and therefore not targets for percutaneous or surgical biopsy—are identified on examination of the entire liver. However, explanted livers are also an imperfect reference standard, as lesions may still be missed. In addition, the clinical significance of small lesions seen on explant but not by other methods is unclear. Across imaging modalities, sensitivity was markedly lower for HCC lesions <2 cm versus those ≥2 cm (differences in sensitivity ranged from 0.30 to 0.39), and further declined for lesions <10 mm in diameter (moderate strength of evidence). Evidence also consistently indicated substantially lower sensitivity for well-differentiated lesions than moderately- or poorly-differentiated lesions (low strength of evidence).

Evidence on the effects of other patient, tumor, and technical factors on test performance was more limited (low strength of evidence). For US, there was no clear effect of use of Doppler, lesion depth, or body mass index on test performance. For CT, limited evidence indicated higher sensitivity for studies that used a contrast rate of ≥3 ml/s than those with a contrast rate <3 ml/s, and for studies that used delayed phase imaging. For MRI, there were no clear effects of magnetic field strength (3.0 vs. 1.5 T), use of delayed phase imaging, type of contrast (hepatic specific vs. non-hepatic specific), timing of delayed phase imaging (≥120 seconds after administration of contrast of <120 s), section thickness (≤5 mm vs. >5 mm), or use of diffusion-weighted imaging. For identification of intrahepatic HCC lesions, limited evidence found PET with ^11^C-acetate and other alternative tracers such as ^18^F-fluorocholine and ^18^F-fluorothymidine associated with substantially higher sensitivity than FDG PET. Sensitivity of FDG PET was lower than sensitivity of FDG PET/CT.

Few studies evaluated the comparative test performance of multiple imaging modalities, either in combination or sequentially as part of a diagnostic algorithm. The available evidence suggests that using multiple imaging tests and defining a positive test as typical imaging findings on at least one imaging modality increases sensitivity without substantively reducing specificity (moderate strength of evidence).

Conclusions were generally robust on sensitivity and stratified analyses based on study factors such as setting (Asia vs. United States or Europe), prospective collection of data, interpretation of imaging findings blinded to results of the reference standard, avoidance of case-control design, and overall risk of bias.

Across analyses, specificity was generally high, with most pooled estimates around 0.85 or higher, and few clear differences between imaging modalities. However, many studies did not report specificity and pooled estimates were frequently imprecise, precluding strong conclusions regarding comparative test performance. Since likelihood ratios are sensitive to small changes in estimates when the specificity is high, it was also difficult to draw strong conclusions regarding comparative diagnostic test performance based on differences in positive or negative likelihood ratios. Most likelihood ratio estimates fell into or near the “moderately useful” range (positive likelihood ratio of 5 to 10 and negative likelihood ratio of 0.1 to 0.2), with the exception of FDG PET for identification of intrahepatic HCC lesions, which was associated with a negative likelihood ratio of 0.50.

Evidence regarding the accuracy of imaging modalities for staging was primarily limited to CT, with 28 to 58 percent of patients correctly staged based on TNM criteria and somewhat more understaging (25% to 52%) than overstaging (2% to 27%) (moderate strength of evidence). Studies on the accuracy of imaging for identifying metastatic HCC disease were primarily limited to FDG PET or PET/CT, with a pooled sensitivity of 0.82 to 0.85 (low strength of evidence).

Evidence on the comparative effectiveness of imaging for HCC on clinical decisionmaking (including use of subsequent tests, procedures, or interventions) was extremely limited. In studies that compared the accuracy of transplant decisions based on CT against primarily explanted livers as the reference standard, the proportion correctly assessed for transplant eligibility based on Milan criteria ranged from 40 to 96 percent (moderate strength of evidence). Evidence on the effects of surveillance with imaging versus no surveillance on clinical outcomes was limited to a single randomized trial50 (low strength of evidence). Although it found an association between surveillance with US and AFP and decreased liver-specific mortality, it had important methodological shortcomings, and the trial was conducted in China, potentially limiting applicability to screening to the United States. The trial primarily enrolled patients with HBV infection, who are more likely to develop HCC in the absence of cirrhosis and therefore more likely to be candidates for surgical resection, potentially overestimating survival benefits compared to a United States population.

Evidence on comparative harms associated with imaging was also extremely limited, with no study measuring downstream harms related to false-positive tests or subsequent workup, or potential harms related to labeling or psychological effects. A handful of studies reported low rates of serious direct harms (e.g., allergic reactions) associated with imaging. However, evidence on administration of contrast for radiological procedures in general also suggests a low rate of serious adverse events. For example, a retrospective analysis of over 450,000 doses of low-osmolar iodinated or gadolinium contrast administered at a single center identified a total of 522 adverse events (0.11% of total), with the most frequent adverse events being urticaria (52%) and nausea (18%).325 Fewer than 100 of the events required further treatment, with use of epinephrine in nine instances. The rate of adverse events was 0.15 percent for iodinated contrast and 0.04 percent for gadolinium, consistent with estimates from other studies.326–328

No study of US with contrast reported harms. Potential harms associated with use of microbubble contrast agents were highlighted when the FDA issued a black box warning in 2007 regarding use of perflutren microbubble contrast for cardiac imaging, due to reports of four fatalities due to cardiopulmonary events within 30 minutes of perflutren administration and 11 fatalities within 12 hours.329 Other studies have attempted to quantify rates of harms associated with microbubble contrast. One study of sulfur hexafluoride contrast for various abdominal applications (23,188 imaging studies) reported 29 adverse events, with two rated serious (0.01%); there were no deaths.330 A study of 16,025 patients who received perflutren contrast in cardiac imaging reported an overall adverse event rate of 0.12 percent, with a rate of serious adverse events of 0.04 percent and no deaths.331

Although PET and CT are associated with risk of radiation exposure, no study of imaging for HCC was designed to evaluate potential long-term clinical outcomes associated with radiation exposure. According to the Radiological Society of North American and the American College of Radiology, abdominal CT with and without contrast is associated with an approximate effective radiation dose of 20 mSv and PET/CT with 25 mSV.332

## Findings in Relationship to What Is Already Known

Unlike our review, several previously published reviews on detection of HCC and evaluation of focal liver lesions found no clear differences in test performance between US, CT, and MRI for HCC.333–336 Factors that may explain these discrepancies are: we included more studies than any prior review, separately analyzed studies based on the reason for imaging, stratified studies according to the unit of analysis, and focused on within-study (direct) comparisons of two or more imaging modalities against a common reference standard instead of relying primarily or solely on across-study (indirect) estimates of test performance. Research on meta-analyses of diagnostic tests found that conclusions based on such direct comparisons are often different from conclusions based on indirect comparisons, and may therefore be more suitable for comparing diagnostic tests.36 In fact, a recently published meta-analysis that focused on direct comparisons was consistent with our review in finding MRI with hepatic-specific contrast associated with higher sensitivity than CT.337 Our review’s findings are consistent with those of previous reviews regarding lower sensitivity of imaging for detection of small and well-differentiated HCC lesions.

Our findings regarding test performance of PET for detection of metastatic HCC are consistent with those from a recently published systematic review and meta-analysis that reported a pooled sensitivity of 0.77.^338^ Like our review, a recent systematic review found insufficient evidence to determine effects of surveillance with imaging on clinical outcomes.339 A systematic review on screening for HCC in chronic liver disease funded by the U.S. Department of Veterans Affairs was conducted at the same time as our review.32

## Applicability

A number of potential issues could impact the applicability of our findings. Over half of the studies were conducted in Asia, where the prevalence, underlying causes, course, evaluation, and management of chronic liver disease may be different than in the United States. To mitigate potential effects of study country on applicability, we excluded invasive imaging techniques not typically used in the United States such as CT arterial portography and CT hepatic arteriography, as well as imaging techniques considered inadequate in the United States (such as C-arm CT). We also performed stratified analyses focusing on studies performed in the United States and Europe to evaluate effects on estimates of diagnostic accuracy and found no clear effects on estimates.

Imaging techniques are rapidly evolving, which is another factor that could affect applicability. To mitigate effects of outdated techniques on applicability, we excluded imaging technologies considered outdated, such as MRI with magnetic field strength <1.5 T and nonspiral CT, and included only studies published since 1998. We also performed additional analyses on technical factors such as contrast rate, imaging phases evaluated, timing of imaging phases, section thickness, use of hepatobiliary contrast (for MRI), use of diffusion-weighted imaging, and newer technologies such as dual-source or spectral CT. We included studies of US with microbubble contrast even though no agent is currently approved for abdominal imaging in the United States, because efforts to obtain U.S. Food and Drug Administration approval are ongoing and this technique is commonly used in other areas of the world, including Canada and Europe.

As noted above, few studies were performed in true surveillance settings, i.e., in patients at high risk for HCC but not previously diagnosed with this condition. Rather, most studies of test performance that were not performed specifically to evaluate or characterize previously identified lesions were conducted in patients undergoing imaging for other reasons, including series of patients undergoing liver transplantation, surgical resection, or other treatments for HCC. Although such studies are likely to provide some useful findings regarding diagnostic accuracy, results may not be directly applicable to patients undergoing surveillance. In particular, the high prevalence of HCC (many studies enrolled only patients with HCC) could overestimate test performance in true surveillance settings, in which the prevalence of HCC would be much lower.340

## Implications for Clinical and Policy Decisionmaking

Our review has important potential implications for clinical and policy decisionmaking. Due to the lack of direct evidence regarding clinical benefits and downstream harms associated with different imaging tests for surveillance, diagnosis, and staging of HCC, most decisions regarding use of imaging tests must necessarily be made primarily on the basis of diagnostic test performance. Current guidelines from the AASLD recommend US without contrast for surveillance of HCC in at-risk individuals.9 Evidence from true surveillance settings to evaluate the comparative test performance of different imaging modalities was very limited. Based primarily on studies conducted in nonsurveillance settings, our study suggests that US without contrast is less sensitive than MRI or CT for detecting HCC. However, findings may not be directly applicable to clinical and policy decisions related to surveillance, as the spectrum of patients evaluated in these studies could have affected estimates of sensitivity. In addition, decisions regarding choice of diagnostic tests to use in surveillance may depend on factors other than diagnostic testing accuracy (e.g., costs) and the weight placed on any gains in sensitivity.

In patients found to have a focal liver lesion on surveillance, our review found high sensitivity and specificity of CT and MRI to further characterize lesions >1 cm in size. The AASLD guideline recommends these modalities for evaluation of focal liver lesions. Evidence is very limited but appears consistent with the sequential diagnostic imaging algorithm as outlined in the AASLD guideline, in which typical findings for HCC on sequentially performed CT or MRI are considered sufficient to make a diagnosis.

Table 41 shows estimated probabilities for HCC following US, MRI, or CT in various scenarios, based on likelihood ratios calculated from pooled sensitivities and specificities. For detection of HCC, in populations with a pre-test probability of HCC of 1 percent, the post-test probability increased to 6 to 10 percent with a positive finding on US with contrast, CT, or MRI, and decreased to 0.17 to 0.29 percent with a negative test. In settings with a pre-test probability of 5 percent, post-test probabilities ranged from 25 to 37 percent following a positive imaging test, and decreased to about 1 percent following a negative imaging test. For evaluation of focal liver lesions, based on a pre-test probability of 10 percent, the post-test probability of HCC increased to 31 to 59 percent following a positive imaging test. Based on a pre-test probability of 25 percent, the post-test probability increased to 71 to 81 percent following a positive imaging test. The post-test probability following a negative test was <3 percent when the prevalence was 10 percent, and 5 to 10 percent when the pre-test probability was 25 percent.

Table 41 Post-test probability of HCC with different imaging modalities in detection of HCC or for evaluation of focal liver lesions for HCC

Imaging Modality | Unit of Analysis | Pretest Probability | Positive Likelihood Ratio | Post-Test Probability of HCC Following a Positive Test | Negative Likelihood Ratio | Post-Test Probability of HCC Following a Negative Test
Detection of HCC
US without contrast^*^ | Patient with HCC | 1% | 6.8 (4.2 to 11) | 6.4% | 0.25 (0.13 to 0.46) | 0.25%
| | 5% | | 26% | | 1.3%
US without contrast^ | Patient with HCC | 1% | 11 (5.4 to 21) | 10% | 0.29 (0.13 to 0.65) | 0.29%
| | 5% | | 37% | | 1.5%
CT^ | Patient with HCC | 1% | 11 (5.6 to 20) | 10% | 0.19 (0.12 to 0.28) | 0.19%
| | 5% | | 37% | | 0.99%
CT^ | HCC lesion | 1% | 7.1 (4.7 to 11) | 6.7% | 0.26 (0.22 to 0.31) | 0.26%
| | 5% | | 27% | | 1.3%
MRI^ | Patient with HCC | 1% | 8.1 (4.3 to 15) | 7.6% | 0.17 (0.10 to 0.28) | 0.17%
| | 5% | | 30% | | 0.89%
MRI^ | HCC lesions | 1% | 6.5 (3.5 to 12) | 6.2% | 0.20 (0.16 to 0.25) | 0.20%
| | 5% | | 25% | | 1.0%
Evaluation of focal liver lesions
US with contrast | Patient with HCC | 10% | 9.6 (5.1 to 18) | 52% | 0.14 (0.09 to 0.23) | 1.5%
| | 25% | | 76% | | 4.5%
US with contrast | HCC lesion | 10% | 9.8 (5.7 to 17) | 52% | 0.14 (0.09 to 0.23) | 1.5%
| | 25% | | 77% | | 4.5%
CT | Patient with HCC | 10% | 7.4 (3.3 to 17) | 45% | 0.16 (0.09 to 0.30) | 1.7%
| | 25% | | 71% | | 5.1%
CT | HCC lesion | 10% | 7.7 (0.71 to 84) | 46% | 0.24 (0.15 to 0.38) | 2.6%
| | 25% | | 72% | | 7.4%
MRI | Patient with HCC | 10% | 4.0 (1.4 to 12) | 31% | 0.29 (0.21 to 0.39) | 3.1%
| | 25% | | 57% | | 8.8%
MRI | HCC lesion | 10% | 13 (3.9 to 42) | 59% | 0.22 (0.15 to 0.31) | 2.4%
| | 25% | | 81% | | 6.8%

* Based on studies conducted in surveillance settings

^ Based on studies conducted in nonsurveillance settings

Our findings also provide some support for minimal technical specifications for MRI and CT for HCC imaging as suggested in recent guidance, such as those regarding minimum contrast rates and use of delayed phase imaging.15 Evidence on the potentially superior test performance of MRI with hepatic-specific versus nonhepatic-specific contrast appears promising, although differences were relatively small. Therefore, clinical and policy decisions around use of nonhepatic-specific contrast may be impacted by additional factors other than test performance, such as cost, harms, or convenience. For example, whereas delayed phase imaging with non-hepatic specific contrast should occur within several minutes of contrast administration, maximum increase in liver parenchyma signal intensity with hepatic-specific contrast agents is not achieved until 20 minutes to hours following contrast administration.341

Although US with contrast was associated with similar test performance as MRI and CT for evaluation of focal liver lesions, no microbubble contrast agents are currently approved for use in the United States. Although the role of PET is likely to remain focused on identification of metastatic HCC and staging, additional research could help clarify the role of PET with alternative tracers for identification and evaluation of intrahepatic HCC.

Clinicians and policymakers may consider modeling studies to help estimate potential benefits and harms of screening. For models to appropriately inform decisionmaking, however, requires reliable estimates of important input parameters such as subsequent testing, interventions, and associated benefits and harms that occur as a result of imaging. Such data are not currently available.

## Limitations of the Review Process

Substantial statistical heterogeneity was present in most pooled analyses of diagnostic accuracy; this situation is common in meta-analyses of diagnostic accuracy.342–344 As noted in the Cochrane Handbook for Systematic Reviews of Diagnostic Test Accuracy, “heterogeneity is to be expected in meta-analyses of diagnostic test accuracy.”344 To address the anticipated heterogeneity, we utilized random effects models to pool studies and stratified studies according to the reason that imaging was performed and the unit of analysis used. We also performed additional stratified and sensitivity analyses based on the reference standard used, study characteristics (such as country in which the study was conducted, factors related to risk of bias), patient characteristics, and technical factors related to the imaging tests under investigation. As noted previously, results were generally robust in sensitivity analyses, despite the heterogeneity. Due to the relatively small numbers of studies, we were unable to perform meaningful meta-regression. We also focused on evaluations of comparative test performance based on within-study comparisons of imaging modalities, which tended to be associated with less heterogeneity than pooled across-study estimates. A limitation of our analysis of within-group comparisons is that we had to treat the two compared groups as independent, because we had only aggregated data. Individual patient level data would be required to take into account the paired nature of the comparisons. However, such correlations are generally positive and would be expected to result in more narrow confidence intervals. Therefore, results are likely to be informative when differences are detected.

We did not construct summary receiver operating characteristic (ROC) curves. Many of the studies were missing data necessary to construct ROC curves, because they did not report specificity or numbers of true negatives. In addition, the “threshold effect” assumption necessary for valid ROC curves did not appear to be met, as the estimated correlation between sensitivity and specificity was often positive.40 Also, most studies did not use a ratings scale to classify imaging tests as positive or negative, and the scales that were used differed across studies (e.g., 1–3, 0–4, 1–4, 1–5, and others). When a confidence rating scale was used, the cutoffs did not vary enough to demonstrate a potential threshold effect. We also did not attempt to pool summary measures of discrimination, for several reasons. Some studies reported the area under the receiver operating characteristic (AUROC) curve and others reported the alternate free response operating characteristic (AFROC) curve, and the suitability of pooling such measures is uncertain. In addition, a number of studies that reported the AUROC or AFROC did not report specificity, and it was unclear from the data provided in the studies how the measures were calculated. Finally, it was often unclear whether the AUROC or AFROC was constructed based on different cutoffs for sensitivity and specificity (representing a true area under a curve) or based on a single cutoff for sensitivity and specificity.

We excluded non-English-language articles and did not search for studies published only as abstracts. We did not formally assess for publication bias using statistical or graphical methods for assessing sample size effects, as research indicates that such methods can be seriously misleading.345,346 Although we found no evidence of unpublished studies through searches on clinical trial registries and regulatory documents, the usefulness of such methods for identifying unpublished studies of test performance is likely to be limited.

## Limitations of the Evidence Base

We identified a number of limitations of the evidence base on imaging for HCC. Only one clinical trial with important methodological shortcomings has evaluated clinical outcomes associated with surveillance for HCC in high-risk patients versus no screening,50 and no trial has compared effects of different imaging modalities for screening. Evidence on effects of imaging on subsequent clinical decisionmaking is also extremely sparse. There is almost no evidence comparing harms associated with different imaging modalities or strategies.

Despite identifying over 200 studies on test performance, we also found important limitations related to these outcomes. Only three studies were rated low risk of bias and 89 studies were rated high risk of bias. Nearly half of the studies did not avoid use of a case-control design, which can result in spectrum bias and inflated estimates of diagnostic accuracy. In addition, nearly half of the studies did not clearly report interpretation of imaging findings blinded to the results of the reference standard test. Many studies did not report specificity, particularly for lesion-based analyses of diagnostic accuracy, perhaps due to the difficulty in defining a “true negative” lesion in such situations. Estimates for pooled specificity were therefore incomplete and typically imprecise, as were likelihood ratio estimates, which are calculated from pooled sensitivity and specificity. In addition, the estimated pooled specificity and likelihood ratios could be biased if studies that did not report specificity differed systematically from those that did.

Other limitations include relatively limited numbers of direct comparisons of diagnostic accuracy between different imaging modalities and techniques (i.e., studies that perform two or more imaging techniques in the same population and evaluate diagnostic accuracy of each technique against the same reference standard). Research has shown that results from such direct comparisons are often different from results based on indirect comparisons (i.e., comparisons of different tests in across studies performed in different populations). Therefore, we focused on results from direct comparisons when possible.

We were unable to evaluate a number of potentially important technical factors in the studies, such as the type of contrast injector and use of bolus-tracking methods for CT; type of contrast injector, use of bolus-tracking methods, spatial resolution, and length of breath hold for MRI; and effects of reader experience and training and transducer frequency for US. Evidence for newer techniques such as spectral or dual-source CT was also limited to only a few studies. For evaluation of the effects of patient and tumor characteristics on measures of diagnostic accuracy, most of the evidence focused on effects of tumor size and degree of differentiation, with very little evidence on patient characteristics such as age, race, sex, severity of liver disease, or underlying cause of liver disease.

## Research Gaps

Significant research gaps limit the full understanding of the comparative effectiveness of imaging for surveillance, diagnosis, and staging of HCC. The only randomized trial of effects of surveillance for HCC with imaging on clinical outcomes had important methodological shortcomings and was performed in China, potentially limiting applicability to screening in the United States50 Although conducting a randomized trial of surveillance versus no screening in the United States could be difficult because screening is recommended in clinical practice guidelines and routinely performed in high-risk patients, randomized trials that compare screening using different imaging modalities or combinations of modalities would be helpful for understanding optimal approaches. In particular, studies assessing clinical outcomes associated with application of the AASLD algorithm versus alternative strategies would be very informative. Potential challenges in conducting such studies include the need to enroll large samples with sufficient statistical power and with lengthy followup.

In lieu of such studies, evidence on effects of alternative imaging strategies on intermediate outcomes such as clinical decisionmaking, subsequent procedures, and resource utilization could also be informative. Such studies could potentially enroll smaller samples than randomized trials to compare screening using different imaging modalities and would probably not require the extended followup needed to assess clinical outcomes.

Although many studies are available on test performance of alternative imaging modalities and strategies, important research gaps remain. Notably, few studies evaluated imaging in true surveillance settings, and evidence on accuracy of imaging for identifying HCC lesions from nonsurveillance settings may not be directly applicable to surveillance due to spectrum effects. More studies are also needed to clarify the role of promising alternative techniques, such as US with contrast, MRI with hepatic-specific contrast, and PET with alternative tracers, on estimates of accuracy. Research should focus on improving methods for identifying small or well-differentiated HCC lesions, for which imaging remains suboptimal. Two systems (the Liver Imaging Reporting and Data System and the Organ Procurement and Transplant Network/United Network for Organ Sharing Criteria) have been proposed to better standardize methods for scoring findings on CT and MRI to diagnose HCC; additional research is needed to determine how their use impacts estimates of accuracy and to identify potential opportunities for additional standardization.47,347

To be most informative it is important for studies to utilize methods for reducing bias in the conduct of studies of test performance, such as avoidance of case-control design and use of methods to insure interpretation of imaging tests blinded to results of the reference standard. Another important shortcoming of the available literature is the failure of many studies to report specificity, resulting in incomplete and less precise estimates. Given the difficulty in defining true negatives for studies that use HCC lesions as the unit of analysis, we suggest that investigators consider routinely reporting results using patients as the unit of analysis, although HCC lesion-based analyses may be reported in addition. Finally, additional studies that evaluate different imaging modalities, techniques, or strategies against a common reference standard in the same population would be more helpful for understanding comparative test performance than studies that evaluate a single imaging modality or technique.

## Conclusions

Based on estimates of test performance, several imaging modalities appear to be reasonable options for detection of HCC, evaluation of focal liver lesions for HCC, or staging of HCC. Although there are some potential differences in test performance between different imaging modalities and techniques, more research is needed to understand the effects of such differences on clinical decisionmaking and clinical outcomes.