# Appendix References

1 Addley HC, Griffin N, Shaw AS, et al. Accuracy of hepatocellular carcinoma detection on multidetector CT in a transplant liver population with explant liver correlation. Clin Radiol. Apr. 2011;66(4):349-56. [pmid: 21295772].
2 Ahn SS, Kim M-J, Lim JS, et al. Added value of gadoxetic acid-enhanced hepatobiliary phase MR imaging in the diagnosis of hepatocellular carcinoma. Radiology. May. 2010;255(2):459-66. [pmid: 20413759].
3 Akai H, Kiryu S, Matsuda I, et al. Detection of hepatocellular carcinoma by Gd-EOB-DTPA-enhanced liver MRI: comparison with triple phase 64 detector row helical CT. Eur J Radiol. Nov. 2011;80(2):310-5. [pmid: 20732773].
4 Alaboudy A, Inoue T, Hatanaka K, et al. Usefulness of combination of imaging modalities in the diagnosis of hepatocellular carcinoma using Sonazoid(R)-enhanced ultrasound, gadolinium diethylene-triamine-pentaacetic acid-enhanced magnetic resonance imaging, and contrast-enhanced computed tomography. Oncology. 2011;81(Suppl 1):66-72. [pmid: 22212939].
5 An C, Park MS, Kim D, et al. Added value of subtraction imaging in detecting arterial enhancement in small (<3 cm) hepatic nodules on dynamic contrast-enhanced MRI in patients at high risk of hepatocellular carcinoma. Eur Radiol. 2013;23:924-30. [pmid: 23138382].
6 An C, Park M-S, Jeon H-M, et al. Prediction of the histopathological grade of hepatocellular carcinoma using qualitative diffusion-weighted, dynamic, and hepatobiliary phase MRI. Eur Radiol. Aug. 2012;22(8):1701-8. [pmid: 22434421].
7 Baccarani U, Adani GL, Avellini C, et al. Comparison of clinical and pathological staging and long-term results of liver transplantation for hepatocellular carcinoma in a single transplant center. Transplant Proc. May. 2006;38(4):1111-3. [pmid: 16757280].
8 Baek CK, Choi JY, Kim KA, et al. Hepatocellular carcinoma in patients with chronic liver disease: a comparison of gadoxetic acid-enhanced MRI and multiphasic MDCT. Clin Radiol. Feb. 2012;67(2):148-56. [pmid: 21920517].
9 Baird AJ, Amos GJ, Saad NF, et al. Retrospective audit to determine the diagnostic accuracy of Primovist-enhanced MRI in the detection of hepatocellular carcinoma in cirrhosis with explant histopathology correlation. J Med Imaging Radiat Oncol. 2013;57(3):314-20. [pmid: 23721140].
10 Bartolozzi C, Donati F, Cioni D, et al. MnDPDP-enhanced MRI vs dual-phase spiral CT in the detection of hepatocellular carcinoma in cirrhosis. Eur Radiol. 2000;10(11):1697-702. [pmid: 11097390].
11 Bennett GL, Krinsky GA, Abitbol RJ, et al. Sonographic detection of hepatocellular carcinoma and dysplastic nodules in cirrhosis: correlation of pretransplantation sonography and liver explant pathology in 200 patients. AJR Am J Roentgenol. Jul. 2002;179(1):75-80. [pmid: 12076908].
12 Bhattacharjya S, Bhattacharjya T, Quaglia A, et al. Liver transplantation in cirrhotic patients with small hepatocellular carcinoma: an analysis of pre-operative imaging, explant histology and prognostic histologic indicators. Dig Surg. 2004;21(2):152-9. discussion 9–60. [pmid: 15166485].
13 Burrel M, Llovet JM, Ayuso C, et al. MRI angiography is superior to helical CT for detection of HCC prior to liver transplantation: an explant correlation. Hepatology. Oct. 2003;38(4):1034-42. [pmid: 14512891].
14 Catala V, Nicolau C, Vilana R, et al. Characterization of focal liver lesions: comparative study of contrast-enhanced ultrasound versus spiral computed tomography. Eur Radiol. Apr. 2007;17(4):1066-73. [pmid: 17072617].
15 Cereser L, Furlan A, Bagatto D, et al. Comparison of portal venous and delayed phases of gadolinium-enhanced magnetic resonance imaging study of cirrhotic liver for the detection of contrast washout of hypervascular hepatocellular carcinoma. J Comput Assist Tomogr. 2010;34(5):706-11. [pmid: 20861773].
16 Chalasani N, Horlander JC Sr, Said A, et al. Screening for hepatocellular carcinoma in patients with advanced cirrhosis. Am J Gastroenterol. Oct. 1999;94(10):2988-93. [pmid: 10520857].
17 Chen Y-K, Hsieh D-S, Liao C-S, et al. Utility of FDG-PET for investigating unexplained serum AFP elevation in patients with suspected hepatocellular carcinoma recurrence. Anticancer Res. Nov–Dec. 2005;25(6C):4719-25. [pmid: 16334166].
18 Cheung TT, Ho CL, Lo CM, et al. 11C-acetate and 18F-FDG PET/CT for clinical staging and selection of patients with hepatocellular carcinoma for liver transplantation on the basis of milan criteria: Surgeon’s perspective. J Nucl Med. 2013;54(2):192-200. [pmid: 23321459].
19 Cheung TT, Chan SC, Ho CL, et al. Can positron emission tomography with the dual tracers [11 C]acetate and [18 F]fludeoxyglucose predict microvascular invasion in hepatocellular carcinoma?. Liver Transpl. Oct. 2011;17(10):1218-25. [pmid: 21688383].
20 Choi SH, Lee JM, Yu NC, et al. Hepatocellular carcinoma in liver transplantation candidates: detection with gadobenate dimeglumine-enhanced MRI. AJR Am J Roentgenol. Aug. 2008;191(2):529-36. [pmid: 18647927].
21 Choi D, Kim SH, Lim JH, et al. Detection of hepatocellular carcinoma: combined T2-weighted and dynamic gadolinium-enhanced MRI versus combined CT during arterial portography and CT hepatic arteriography. J Comput Assist Tomogr. Sep–Oct. 2001;25(5):777-85. [pmid: 11584240].
22 Chou C-T, Chen R-C, Chen W-T, et al. Characterization of hyperintense nodules on T1-weighted liver magnetic resonance imaging: comparison of Ferucarbotran-enhanced MRI with accumulation-phase FS-T1WI and gadolinium-enhanced MRI. J Chin Med Assoc. Feb. 2011;74(2):62-8. [pmid: 21354082].
23 Chung J, Yu J-S, Kim DJ, et al. Hypervascular hepatocellular carcinoma in the cirrhotic liver: diffusion-weighted imaging versus superparamagnetic iron oxide-enhanced MRI. Magn Reson Imaging. Nov. 2011;29(9):1235-43. [pmid: 21907517].
24 Chung S-H, Kim M-J, Choi J-Y, et al. Comparison of two different injection rates of gadoxetic acid for arterial phase MRI of the liver. J Magn Reson Imaging. Feb. 2010;31(2):365-72. [pmid: 20099350].
25 Colagrande S, Fargnoli R, Dal Pozzo F, et al. Value of hepatic arterial phase CT versus lipiodol ultrafluid CT in the detection of hepatocellular carcinoma. J Comput Assist Tomogr. Nov–Dec. 2000;24(6):878-83. [pmid: 11105704].
26 Dai Y, Chen MH, Fan ZH, et al. Diagnosis of small hepatic nodules detected by surveillance ultrasound in patients with cirrhosis: Comparison between contrast-enhanced ultrasound and contrast-enhanced helical computed tomography. Hepatol Res. Mar. 2008;38(3):281-90. [pmid: 17908168].
27 de Ledinghen V, Laharie D, Lecesne R, et al. Detection of nodules in liver cirrhosis: spiral computed tomography or magnetic resonance imaging? A prospective study of 88 nodules in 34 patients. Eur J Gastroenterol Hepatol. Feb. 2002;14(2):159-65. [pmid: 11981340].
28 Delbeke D, Martin WH, Sandler MP, et al. Evaluation of benign vs malignant hepatic lesions with positron emission tomography. Arch Surg. May. 1998;133(5):510-5. discussion 5–6. [pmid: 9605913].
29 Denecke T, Grieser C, Froling V, et al. Multislice computed tomography using a triple-phase contrast protocol for preoperative assessment of hepatic tumor load in patients with hepatocellular carcinoma before liver transplantation. Transpl Int. Apr. 2009;22(4):395-402. [pmid: 19000231].
30 Di Martino M, De Filippis G, De Santis A, et al. Hepatocellular carcinoma in cirrhotic patients: prospective comparison of US, CT and MR imaging. Eur Radiol. 2013;23:887-96. [pmid: 23179521].
31 Di Martino M, Marin D, Guerrisi A, et al. Intraindividual comparison of gadoxetate disodium-enhanced MR imaging and 64-section multidetector CT in the Detection of hepatocellular carcinoma in patients with cirrhosis. Radiology. Sep. 2010;256(3):806-16. [pmid: 20720069].
32 D’Onofrio M, Rozzanigo U, Masinielli BM, et al. Hypoechoic focal liver lesions: characterization with contrast enhanced ultrasonography. J Clin Ultrasound. May. 2005;33(4):164-72. [pmid: 15856516].
33 Doyle DJ, O’Malley ME, Jang H-J, et al. Value of the unenhanced phase for detection of hepatocellular carcinomas 3 cm or less when performing multiphase computed tomography in patients with cirrhosis. J Comput Assist Tomogr. Jan–Feb. 2007;31(1):86-92. [pmid: 17259838].
34 Eckel F, Herrmann K, Schmidt S, et al. Imaging of proliferation in hepatocellular carcinoma with the in vivo marker 18F-fluorothymidine. J Nucl Med. Sep. 2009;50(9):1441-7. [pmid: 19690030].
35 Egger C, Goertz RS, Strobel D, et al. Dynamic contrast-enhanced ultrasound (DCE-US) for easy and rapid evaluation of hepatocellular carcinoma compared to dynamic contrast-enhanced computed tomography (DCE-CT)--a pilot study. Ultraschall Med. 2012;33(6):587-92. [pmid: 23154871].
36 Filippone A, Cianci R, Patriarca G, et al. The Value of Gadoxetic Acid-Enhanced Hepatospecific Phase MR Imaging for Characterization of Hepatocellular Nodules in the Cirrhotic Liver. European Journal of Clinical & Medical Oncology. 2010;2(4):1-8.
37 Forner A, Vilana R, Ayuso C, et al. Diagnosis of hepatic nodules 20 mm or smaller in cirrhosis: Prospective validation of the noninvasive diagnostic criteria for hepatocellular carcinoma. [Erratum appears in Hepatology. 2008 Feb;47(2):769]. Hepatology. Jan. 2008;47(1):97-104. [pmid: 18069697].
38 Fowler KJ, Karimova EJ, Arauz AR, et al. Validation of organ procurement and transplant network (OPTN)/united network for organ sharing (UNOS) criteria for imaging diagnosis of hepatocellular carcinoma. Transplantation. 2013;95(12):1506-11. [pmid: 23778569].
39 Fracanzani AL, Burdick L, Borzio M, et al. Contrast-enhanced Doppler ultrasonography in the diagnosis of hepatocellular carcinoma and premalignant lesions in patients with cirrhosis. Hepatology. Dec. 2001;34(6):1109-12. [pmid: 11731999].
40 Freeman RB, Mithoefer A, Ruthazer R, et al. Optimizing staging for hepatocellular carcinoma before liver transplantation: A retrospective analysis of the UNOS/OPTN database. Liver Transpl. Oct. 2006;12(10):1504-11. [pmid: 16952174].
41 Freeny PC, Grossholz M, Kaakaji K, et al. Significance of hyperattenuating and contrast-enhancing hepatic nodules detected in the cirrhotic liver during arterial phase helical CT in pre-liver transplant patients: radiologic-histopathologic correlation of explanted livers. Abdom Imaging. May–Jun. 2003;28(3):333-46. [pmid: 12719903].
42 Furuse J, Maru Y, Yoshino M, et al. Assessment of arterial tumor vascularity in small hepatocellular carcinoma. Comparison between color doppler ultrasonography and radiographic imagings with contrast medium: dynamic CT, angiography, and CT hepatic arteriography. Eur J Radiol. Oct. 2000;36(1):20-7. [pmid: 10996754].
43 Gaiani S, Celli N, Piscaglia F, et al. Usefulness of contrast-enhanced perfusional sonography in the assessment of hepatocellular carcinoma hypervascular at spiral computed tomography. J Hepatol. Sep. 2004;41(3):421-6. [pmid: 15336445].
44 Gambarin-Gelwan M, Wolf DC, Shapiro R, et al. Sensitivity of commonly available screening tests in detecting hepatocellular carcinoma in cirrhotic patients undergoing liver transplantation. Am J Gastroenterol. Jun. 2000;95(6):1535-8. [pmid: 10894592].
45 Gatto A, De Gaetano AM, Giuga M, et al. Differentiating hepatocellular carcinoma from dysplastic nodules at gadobenate dimeglumine-enhanced hepatobiliary-phase magnetic resonance imaging. Abdom Imaging. 2013;38(4):736-44. [pmid: 22986351].
46 Giorgio A, De Stefano G, Coppola C, et al. Contrast-enhanced sonography in the characterization of small hepatocellular carcinomas in cirrhotic patients: comparison with contrast-enhanced ultrafast magnetic resonance imaging. Anticancer Res. Nov–Dec. 2007;27(6C):4263-9. [pmid: 18214030].
47 Giorgio A, Ferraioli G, Tarantino L, et al. Contrast-enhanced sonographic appearance of hepatocellular carcinoma in patients with cirrhosis: Comparison with contrast-enhanced helical CT appearance. AJR Am J Roentgenol. 2004;183(5):1319-26. [pmid: 15505297].
48 Golfieri R, Marini E, Bazzocchi A, et al. Small (≤ 3 cm) hepatocellular carcinoma in cirrhosis: the role of double contrast agents in MR imaging vs. multidetector-row CT. Radiol Med (Torino). Dec. 2009;114(8):1239-66. [pmid: 19697104].
49 Goshima S, Kanematsu M, Matsuo M, et al. Nodule-in-nodule appearance of hepatocellular carcinomas: comparison of gadolinium-enhanced and ferumoxides-enhanced magnetic resonance imaging. J Magn Reson Imaging. Aug. 2004;20(2):250-5. [pmid: 15269950].
50 Goto E, Masuzaki R, Tateishi R, et al. Value of post-vascular phase (Kupffer imaging) by contrast-enhanced ultrasonography using Sonazoid in the detection of hepatocellular carcinoma. J Gastroenterol. 2012;47(4):477-85. [pmid: 22200940].
51 Guo L, Liang C, Yu T, et al. 3 T MRI of hepatocellular carcinomas in patients with cirrhosis: does T2-weighted imaging provide added value?. Clin Radiol. Apr. 2012;67(4):319-28. [pmid: 22099524].
52 Haradome H, Grazioli L, Tinti R, et al. Additional value of gadoxetic acid-DTPA-enhanced hepatobiliary phase MR imaging in the diagnosis of early-stage hepatocellular carcinoma: comparison with dynamic triple-phase multidetector CT imaging. J Magn Reson Imaging. Jul. 2011;34(1):69-78. [pmid: 21598343].
53 Hardie AD, Kizziah MK, Boulter DJ. Diagnostic accuracy of diffusion-weighted MRI for identifying hepatocellular carcinoma with liver explant correlation. J Med Imaging Radiat Oncol. Aug. 2011;55(4):362-7. [pmid: 21843170].
54 Hardie AD, Kizziah MK, Rissing MS. Can the patient with cirrhosis be imaged for hepatocellular carcinoma without gadolinium?: Comparison of combined T2-weighted, T2*-weighted, and diffusion-weighted MRI with gadolinium-enhanced MRI using liver explantation standard. J Comput Assist Tomogr. Nov–Dec. 2011;35(6):711-5. [pmid: 22082541].
55 Hardie AD, Nance JW, Boulter DJ, et al. Assessment of the diagnostic accuracy of T2*-weighted MR imaging for identifying hepatocellular carcinoma with liver explant correlation. Eur J Radiol. Dec. 2011;80(3):e249-52. [pmid: 21112710].
56 Hatanaka K, Kudo M, Minami Y, et al. Differential diagnosis of hepatic tumors: value of contrast-enhanced harmonic sonography using the newly developed contrast agent, Sonazoid. Intervirology. 2008;51(Suppl 1):61-9. [pmid: 18544950].
57 Hecht EM, Holland AE, Israel GM, et al. Hepatocellular carcinoma in the cirrhotic liver: gadolinium-enhanced 3D T1-weighted MR imaging as a stand-alone sequence for diagnosis. Radiology. May. 2006;239(2):438-47. [pmid: 16641353].
58 Hidaka M, Takatsuki M, Okudaira S, et al. The expression of transporter OATP2/OATP8 decreases in undetectable hepatocellular carcinoma by Gd-EOB-MRI in the explanted cirrhotic liver. Hepatology International. 2012:1-7.
59 Higashihara H, Osuga K, Onishi H, et al. Diagnostic accuracy of C-arm CT during selective transcatheter angiography for hepatocellular carcinoma: comparison with intravenous contrast-enhanced, biphasic, dynamic MDCT. Eur Radiol. Apr. 2012;22(4):872-9. [pmid: 22120061].
60 Hirakawa M, Yoshimitsu K, Irie H, et al. Performance of radiological methods in diagnosing hepatocellular carcinoma preoperatively in a recipient of living related liver transplantation: comparison with step section histopathology. Jpn J Radiol. Feb. 2011;29(2):129-37. [pmid: 21359938].
61 Ho C-L, Yu SCH, Yeung DWC. 11C-acetate PET imaging in hepatocellular carcinoma and other liver masses. J Nucl Med. Feb. 2003;44(2):213-21. [pmid: 12571212].
62 Ho C-l, Chen S, Yeung DWC, et al. Dual-tracer PET/CT imaging in evaluation of metastatic hepatocellular carcinoma. J Nucl Med. Jun. 2007;48(6):902-9. [pmid: 17504862].
63 Hori M, Murakami T, Kim T, et al. Detection of hypervascular hepatocellular carcinoma: comparison of SPIO-enhanced MRI with dynamic helical CT. J Comput Assist Tomogr. Sep–Oct. 2002;26(5):701-10. [pmid: 12439302].
64 Hori M, Murakami T, Oi H, et al. Sensitivity in detection of hypervascular hepatocellular carcinoma by helical CT with intra-arterial injection of contrast medium, and by helical CT and MR imaging with intravenous injection of contrast medium. Acta Radiol. Mar. 1998;39(2):144-51. [pmid: 9529444].
65 Hwang J, Kim SH, Lee MW, et al. Small (≤ 2 cm) hepatocellular carcinoma in patients with chronic liver disease: comparison of gadoxetic acid-enhanced 3.0 T MRI and multiphasic 64-multirow detector CT. Br J Radiol. Jul. 2012;85(1015):e314-22. [pmid: 22167508].
66 Hwang KH, Choi D-J, Lee S-Y, et al. Evaluation of patients with hepatocellular carcinomas using [(11)C]acetate and [(18)F]FDG PET/CT: A preliminary study. Appl Radiat Isot. Jul–Aug. 2009;67(7–8):1195-8. [pmid: 19342249].
67 Iannaccone R, Laghi A, Catalano C, et al. Hepatocellular carcinoma: role of unenhanced and delayed phase multi-detector row helical CT in patients with cirrhosis. Radiology. Feb. 2005;234(2):460-7. [pmid: 15671002].
68 Iavarone M, Sangiovanni A, Forzenigo LV, et al. Diagnosis of hepatocellular carcinoma in cirrhosis by dynamic contrast imaging: the importance of tumor cell differentiation. Hepatology. Nov. 2010;52(5):1723-30. [pmid: 20842697].
69 Ichikawa T, Saito K, Yoshioka N, et al. Detection and characterization of focal liver lesions: a Japanese phase III, multicenter comparison between gadoxetic acid disodium-enhanced magnetic resonance imaging and contrast-enhanced computed tomography predominantly in patients with hepatocellular carcinoma and chronic liver disease. Invest Radiol. Mar. 2010;45(3):133-41. [pmid: 20098330].
70 Ichikawa T, Kitamura T, Nakajima H, et al. Hypervascular hepatocellular carcinoma: can double arterial phase imaging with multidetector CT improve tumor depiction in the cirrhotic liver?. AJR Am J Roentgenol. Sep. 2002;179(3):751-8. [pmid: 12185057].
71 Ijichi H, Shirabe K, Taketomi A, et al. Clinical usefulness of 18F-fluorodeoxyglucose positron emission tomography/computed tomography for patients with primary liver cancer with special reference to rare histological types, hepatocellular carcinoma with sarcomatous change and combined hepatocellular and cholangiocarcinoma. Hepatol Res. 2013;43(5):481-7. [pmid: 23145869].
72 Imamura M, Shiratori Y, Shiina S, et al. Power Doppler sonography for hepatocellular carcinoma: factors affecting the power Doppler signals of the tumors. Liver. Dec. 1998;18(6):427-33. [pmid: 9869398].
73 Inoue T, Kudo M, Komuta M, et al. Assessment of Gd-EOB-DTPA-enhanced MRI for HCC and dysplastic nodules and comparison of detection sensitivity versus MDCT. J Gastroenterol. Sep. 2012;47(9):1036-47. [pmid: 22526270].
74 Inoue T, Kudo M, Maenishi O, et al. Value of liver parenchymal phase contrast-enhanced sonography to diagnose premalignant and borderline lesions and overt hepatocellular carcinoma. AJR Am J Roentgenol. Mar. 2009;192(3):698-705. [pmid: 19234266].
75 Inoue T, Kudo M, Hatanaka K, et al. Imaging of hepatocellular carcinoma: Qualitative and quantitative analysis of postvascular phase contrast-enhanced ultrasonography with sonazoid. Oncology. 2008;75(SUPPL 1):48-54. [pmid: 19092272].
76 Ito K, Fujita T, Shimizu A, et al. Multiarterial phase dynamic MRI of small early enhancing hepatic lesions in cirrhosis or chronic hepatitis: Differentiating between hypervascular hepatocellular carcinomas and pseudolesions. AJR Am J Roentgenol. 2004;183(3):699-705. [pmid: 15333358].
77 Iwazawa J, Ohue S, Hashimoto N, et al. Detection of hepatocellular carcinoma: comparison of angiographic C-arm CT and MDCT. AJR Am J Roentgenol. Oct. 2010;195(4):882-7. [pmid: 20858813].
78 Jang HJ, Lim JH, Lee SJ, et al. Hepatocellular carcinoma: are combined CT during arterial portography and CT hepatic arteriography in addition to triple-phase helical CT all necessary for preoperative evaluation?. Radiology. May. 2000;215(2):373-80. [pmid: 10796910].
79 Jang HJ, Kim TK, Khalili K, et al. Characterization of 1- to 2-cm liver nodules detected on hcc surveillance ultrasound according to the criteria of the american association for the study of liver disease: Is quadriphasic CT necessary?. AJR Am J Roentgenol. 2013;201(2):314-21. [pmid: 23883211].
80 Jang HJ, Kim TK, Wilson SR. Small nodules (1–2 cm) in liver cirrhosis: characterization with contrast-enhanced ultrasound. Eur J Radiol. Dec. 2009;72(3):418-24. [pmid: 18834687].
81 Jeng L-B, Changlai S-P, Shen Y-Y, et al. Limited value of 18F-2-deoxyglucose positron emission tomography to detect hepatocellular carcinoma in hepatitis B virus carriers. Hepatogastroenterology. Nov–Dec. 2003;50(54):2154-6. [pmid: 14696485].
82 Jeng C-M, Kung C-H, Wang Y-C, et al. Spiral biphasic contrast-enhanced computerized tomography in the diagnosis of hepatocellular carcinoma. J Formos Med Assoc. Aug. 2002;101(8):588-92. [pmid: 12440092].
83 Jeong WK, Byun JH, Lee SS, et al. Gadobenate dimeglumine-enhanced liver MR imaging in cirrhotic patients: quantitative and qualitative comparison of 1-hour and 3-hour delayed images. J Magn Reson Imaging. Apr. 2011;33(4):889-97. [pmid: 21448954].
84 Jeong MG, Yu JS, Kim KW, et al. Early homogeneously enhancing hemangioma versus hepatocellular carcinoma: differentiation using quantitative analysis of multiphasic dynamic magnetic resonance imaging. Yonsei Med J. Jun. 1999;40(3):248-55. [pmid: 10412337].
85 Jin Y, Nah S, Lee J, et al. Utility of Adding Primovist Magnetic Resonance Imaging to Analysis of Hepatocellular Carcinoma by Liver Dynamic Computed Tomography. Clin Gastroenterol Hepatol. 2013;11(2):187-92. [pmid: 23142203].
86 Kakihara D, Nishie A, Harada N, et al. Performance of gadoxetic acid-enhanced MRI for detecting hepatocellular carcinoma in recipients of living-related-liver-transplantation: Comparison with dynamic multidetector row computed tomography and angiography-assisted computed tomography. J Magn Reson Imaging. 2013. Nov. [Epub ahead of print]. [pmid: 24259437].
87 Kamura T, Kimura M, Sakai K, et al. Small hypervascular hepatocellular carcinoma versus hypervascular pseudolesions: Differential diagnosis on MRI. Abdom Imaging. 2002;27(3):315-24. [pmid: 12173363].
88 Kang BK, Lim JH, Kim SH, et al. Preoperative depiction of hepatocellular carcinoma: ferumoxides-enhanced MR imaging versus triple-phase helical CT. Radiology. Jan. 2003;226(1):79-85. [pmid: 12511672].
89 Kawada N, Ohkawa K, Tanaka S, et al. Improved diagnosis of well-differentiated hepatocellular carcinoma with gadolinium ethoxybenzyl diethylene triamine pentaacetic acid-enhanced magnetic resonance imaging and Sonazoid contrast-enhanced ultrasonography. Hepatol Res. 2010;40(9):930-6. [pmid: 20887598].
90 Kawaoka T, Aikata H, Takaki S, et al. FDG positron emission tomography/computed tomography for the detection of extrahepatic metastases from hepatocellular carcinoma. Hepatol Res. 2009;39(2):134-42. [pmid: 19208034].
91 Kawata S, Murakami T, Kim T, et al. Multidetector CT: diagnostic impact of slice thickness on detection of hypervascular hepatocellular carcinoma. AJR Am J Roentgenol. Jul. 2002;179(1):61-6. [pmid: 12076906].
92 Khalili K, Kim TK, Jang H-J, et al. Optimization of imaging diagnosis of 1–2 cm hepatocellular carcinoma: an analysis of diagnostic performance and resource utilization. J Hepatol. Apr. 2011;54(4):723-8. [pmid: 21156219].
93 Khan MA, Combs CS, Brunt EM, et al. Positron emission tomography scanning in the evaluation of hepatocellular carcinoma. J Hepatol. May. 2000;32(5):792-7. [pmid: 10845666].
94 Kim AY, Kim YK, Lee MW, et al. Detection of hepatocellular carcinoma in gadoxetic acid-enhanced MRI and diffusion-weighted MRI with respect to the severity of liver cirrhosis. Acta Radiol. Oct. 1. 2012;53(8):830-8. [pmid: 22847903].
95 Kim CK, Lim JH, Lee WJ. Detection of hepatocellular carcinomas and dysplastic nodules in cirrhotic liver: accuracy of ultrasonography in transplant patients. J Ultrasound Med. Feb. 2001;20(2):99-104. [pmid: 11211142].
96 Kim DJ, Yu JS, Kim JH, et al. Small hypervascular hepatocellular carcinomas: value of diffusion-weighted imaging compared with “washout” appearance on dynamic MRI. Br J Radiol. Oct. 2012;85(1018):e879-86. [pmid: 22573299].
97 Kim KW, Lee JM, Klotz E, et al. Quantitative CT color mapping of the arterial enhancement fraction of the liver to detect hepatocellular carcinoma. Radiology. Feb. 2009;250(2):425-34. [pmid: 19188314].
98 Kim M-J, Lee M, Choi J-Y, et al. Imaging features of small hepatocellular carcinomas with microvascular invasion on gadoxetic acid-enhanced MR imaging. Eur J Radiol. Oct. 2012;81(10):2507-12. [pmid: 22137613].
99 Kim PN, Choi D, Rhim H, et al. Planning ultrasound for percutaneous radiofrequency ablation to treat small (≤ 3 cm) hepatocellular carcinomas detected on computed tomography or magnetic resonance imaging: a multicenter prospective study to assess factors affecting ultrasound visibility. J Vasc Interv Radiol. May. 2012;23(5):627-34. [pmid: 22387030].
100 Kim SE, Lee HC, Shim JH, et al. Noninvasive diagnostic criteria for hepatocellular carcinoma in hepatic masses >2 cm in a hepatitis B virus-endemic area. Liver Int. Nov. 2011;31(10):1468-76. [pmid: 21745284].
101 Kim SH, Kim SH, Lee J, et al. Gadoxetic acid-enhanced MRI versus triple-phase MDCT for the preoperative detection of hepatocellular carcinoma. AJR Am J Roentgenol. Jun. 2009;192(6):1675-81. [pmid: 19457834].
102 Kim SH, Choi D, Kim SH, et al. Ferucarbotran-enhanced MRI versus triple-phase MDCT for the preoperative detection of hepatocellular carcinoma. AJR Am J Roentgenol. Apr. 2005;184(4):1069-76. [pmid: 15788575].
103 Kim SJ, Kim SH, Lee J, et al. Ferucarbotran-enhanced 3.0-T magnetic resonance imaging using parallel imaging technique compared with triple-phase multidetector row computed tomography for the preoperative detection of hepatocellular carcinoma. [Erratum appears in J Comput Assist Tomogr. 2008 Jul–Aug;32(4):615]. J Comput Assist Tomogr. May–Jun. 2008;32(3):379-85. [pmid: 18520541].
104 Kim SK, Lim JH, Lee WJ, et al. Detection of hepatocellular carcinoma: comparison of dynamic three-phase computed tomography images and four-phase computed tomography images using multidetector row helical computed tomography. J Comput Assist Tomogr. Sep–Oct. 2002;26(5):691-8. [pmid: 12439300].
105 Kim T, Murakami T, Hori M, et al. Small hypervascular hepatocellular carcinoma revealed by double arterial phase CT performed with single breath-hold scanning and automatic bolus tracking. AJR Am J Roentgenol. Apr. 2002;178(4):899-904. [pmid: 11906869].
106 Kim TK, Lee KH, Jang H-J, et al. Analysis of gadobenate dimeglumine-enhanced MR findings for characterizing small (1–2-cm) hepatic nodules in patients at high risk for hepatocellular carcinoma. Radiology. Jun. 2011;259(3):730-8. [pmid: 21364083].
107 Kim YK, Kim CS, Han YM, et al. Detection of small hepatocellular carcinoma: intraindividual comparison of gadoxetic acid-enhanced MRI at 3.0 and 1.5 T. [Erratum appears in Invest Radiol. 2011 Sep;46(9):600]. Invest Radiol. Jun. 2011;46(6):383-9. [pmid: 21467946].
108 Kim YK, Kim CS, Han YM, et al. Detection of liver malignancy with gadoxetic acid-enhanced MRI: is addition of diffusion-weighted MRI beneficial?. [Erratum appears in Clin Radiol. 2011 Oct;66(10):1006]. Clin Radiol. Jun. 2011;66(6):489-96. [pmid: 21367403].
109 Kim YK, Kim CS, Han YM, et al. Detection of small hepatocellular carcinoma: can gadoxetic acid-enhanced magnetic resonance imaging replace combining gadopentetate dimeglumine-enhanced and superparamagnetic iron oxide-enhanced magnetic resonance imaging?. Invest Radiol. Nov. 2010;45(11):740-6. [pmid: 20644488].
110 Kim YK, Kim CS, Han YM, et al. Comparison of gadoxetic acid-enhanced MRI and superparamagnetic iron oxide-enhanced MRI for the detection of hepatocellular carcinoma. Clin Radiol. May. 2010;65(5):358-65. [pmid: 20380933].
111 Kim Y-K, Lee K-W, Cho SY, et al. Usefulness 18F-FDG positron emission tomography/computed tomography for detecting recurrence of hepatocellular carcinoma in posttransplant patients. Liver Transpl. Jun. 2010;16(6):767-72. [pmid: 20517911].
112 Kim YK, Kim CS, Han YM, et al. Detection of hepatocellular carcinoma: gadoxetic acid-enhanced 3-dimensional magnetic resonance imaging versus multi-detector row computed tomography. J Comput Assist Tomogr. Nov–Dec. 2009;33(6):844-50. [pmid: 19940648].
113 Kim YK, Lee YH, Kim CS, et al. Added diagnostic value of T2-weighted MR imaging to gadolinium-enhanced three-dimensional dynamic MR imaging for the detection of small hepatocellular carcinomas. Eur J Radiol. Aug. 2008;67(2):304-10. [pmid: 17714904].
114 Kim YK, Lee YH, Kim CS, et al. Double-dose 1.0-M gadobutrol versus standard-dose 0.5-M gadopentetate dimeglumine in revealing small hypervascular hepatocellular carcinomas. Eur Radiol. Jan. 2008;18(1):70-7. [pmid: 17404740].
115 Kim YK, Kwak HS, Han YM, et al. Usefulness of combining sequentially acquired gadobenate dimeglumine-enhanced magnetic resonance imaging and resovist-enhanced magnetic resonance imaging for the detection of hepatocellular carcinoma: comparison with computed tomography hepatic arteriography and computed tomography arterioportography using 16-slice multidetector computed tomography. J Comput Assist Tomogr. Sep–Oct. 2007;31(5):702-11. [pmid: 17895780].
116 Kim YK, Kim CS, Chung GH, et al. Comparison of gadobenate dimeglumine-enhanced dynamic MRI and 16-MDCT for the detection of hepatocellular carcinoma. AJR Am J Roentgenol. Jan. 2006;186(1):149-57. [pmid: 16357395].
117 Kim YK, Kwak HS, Kim CS, et al. Hepatocellular carcinoma in patients with chronic liver disease: comparison of SPIO-enhanced MR imaging and 16-detector row CT. Radiology. Feb. 2006;238(2):531-41. [pmid: 16371577].
118 Kim YK, Kim CS, Kwak HS, et al. Three-dimensional dynamic liver MR imaging using sensitivity encoding for detection of hepatocellular carcinomas: comparison with superparamagnetic iron oxide-enhanced mr imaging. J Magn Reson Imaging. Nov. 2004;20(5):826-37. [pmid: 15503325].
119 Kim YK, Kim CS, Lee YH, et al. Comparison of superparamagnetic iron oxide-enhanced and gadobenate dimeglumine-enhanced dynamic MRI for detection of small hepatocellular carcinomas. AJR Am J Roentgenol. May. 2004;182(5):1217-23. [pmid: 15100122].
120 Kitamura T, Ichikawa T, Erturk SM, et al. Detection of hypervascular hepatocellular carcinoma with multidetector-row CT: single arterial-phase imaging with computer-assisted automatic bolus-tracking technique compared with double arterial-phase imaging. J Comput Assist Tomogr. Sep–Oct. 2008;32(5):724-9. [pmid: 18830101].
121 Kondo H, Kanematsu M, Itoh K, et al. Does T2-weighted MR imaging improve preoperative detection of malignant hepatic tumors? Observer performance study in 49 surgically proven cases. Magn Reson Imaging. Jan. 2005;23(1):89-95. [pmid: 15733793].
122 Korenaga K, Korenaga M, Furukawa M, et al. Usefulness of Sonazoid contrast-enhanced ultrasonography for hepatocellular carcinoma: Comparison with pathological diagnosis and superparamagnetic iron oxide magnetic resonance images. J Gastroenterol. 2009;44(7):733-41. [pmid: 19387532].
123 Koushima Y, Ebara M, Fukuda H, et al. Small hepatocellular carcinoma: assessment with T1-weighted spin-echo magnetic resonance imaging with and without fat suppression. Eur J Radiol. Jan. 2002;41(1):34-41. [pmid: 11750150].
124 Krinsky GA, Lee VS, Theise ND, et al. Transplantation for hepatocellular carcinoma and cirrhosis: Sensitivity of magnetic resonance imaging. Liver Transpl. 2002;8(12):1156-64. [pmid: 12474156].
125 Krinsky GA, Lee VS, Theise ND, et al. Hepatocellular carcinoma and dysplastic nodules in patients with cirrhosis: prospective diagnosis with MR imaging and explantation correlation. Radiology. May. 2001;219(2):445-54. [pmid: 11323471].
126 Kumano S, Uemura M, Haraikawa T, et al. Efficacy of double arterial phase dynamic magnetic resonance imaging with the sensitivity encoding technique versus dynamic multidetector-row helical computed tomography for detecting hypervascular hepatocellular carcinoma. Jpn J Radiol. Jul. 2009;27(6):229-36. [pmid: 19626408].
127 Kunishi Y, Numata K, Morimoto M, et al. Efficacy of fusion imaging combining sonography and hepatobiliary phase MRI with Gd-EOB-DTPA to detect small hepatocellular carcinoma. AJR Am J Roentgenol. Jan. 2012;198(1):106-14. [pmid: 22194485].
128 Kwak H-S, Lee J-M, Kim Y-K, et al. Detection of hepatocellular carcinoma: comparison of ferumoxides-enhanced and gadolinium-enhanced dynamic three-dimensional volume interpolated breath-hold MR imaging. Eur Radiol. Jan. 2005;15(1):140-7. [pmid: 15449000].
129 Kwak H-S, Lee J-M, Kim C-S. Preoperative detection of hepatocellular carcinoma: comparison of combined contrast-enhanced MR imaging and combined CT during arterial portography and CT hepatic arteriography. Eur Radiol. Mar. 2004;14(3):447-57. [pmid: 14531005].
130 Laghi A, Iannaccone R, Rossi P, et al. Hepatocellular carcinoma: detection with triple-phase multi-detector row helical CT in patients with chronic hepatitis. Radiology. Feb. 2003;226(2):543-9. [pmid: 12563152].
131 Lauenstein TC, Salman K, Morreira R, et al. Gadolinium-enhanced MRI for tumor surveillance before liver transplantation: center-based experience. AJR Am J Roentgenol. Sep. 2007;189(3):663-70. [pmid: 17715115].
132 Lee CH, Kim KA, Lee J, et al. Using low tube voltage (80kVp) quadruple phase liver CT for the detection of hepatocellular carcinoma: two-year experience and comparison with Gd-EOB-DTPA enhanced liver MRI. Eur J Radiol. Apr. 2012;81(4):e605-11. [pmid: 22297180].
133 Lee DH, Kim SH, Lee JM, et al. Diagnostic performance of multidetector row computed tomography, superparamagnetic iron oxide-enhanced magnetic resonance imaging, and dual-contrast magnetic resonance imaging in predicting the appropriateness of a transplant recipient based on milan criteria: correlation with histopathological findings. Invest Radiol. Jun. 2009;44(6):311-21. [pmid: 19462486].
134 Lee J, Won JL, Hyo KL, et al. Early hepatocellular carcinoma: Three-phase helical CT features of 16 patients. Korean J Radiol. 2008;9(4):325-32. [pmid: 18682670].
135 Lee JE, Jang JY, Jeong SW, et al. Diagnostic value for extrahepatic metastases of hepatocellular carcinoma in positron emission tomography/computed tomography scan. World J Gastroenterol. Jun. 21. 2012;18(23):2979-87. [pmid: 22736922].
136 Lee J-M, Kim I-H, Kwak H-S, et al. Detection of small hypervascular hepatocellular carcinomas in cirrhotic patients: comparison of superparamagnetic iron oxide-enhanced MR imaging with dual-phase spiral CT. Korean J Radiol. Jan–Mar. 2003;4(1):1-8. [pmid: 12679628].
137 Lee JY, Kim SH, Jeon YH, et al. Ferucarbotran-enhanced magnetic resonance imaging versus gadoxetic acid-enhanced magnetic resonance imaging for the preoperative detection of hepatocellular carcinoma: initial experience. J Comput Assist Tomogr. Jan. 2010;34(1):127-34. [pmid: 20118735].
138 Lee MH, Kim SH, Park MJ, et al. Gadoxetic acid-enhanced hepatobiliary phase MRI and high-b-value diffusion-weighted imaging to distinguish well-differentiated hepatocellular carcinomas from benign nodules in patients with chronic liver disease. AJR Am J Roentgenol. Nov. 2011;197(5):W868-75. [pmid: 22021534].
139 Lee MW, Kim YJ, Park HS, et al. Targeted sonography for small hepatocellular carcinoma discovered by CT or MRI: factors affecting sonographic detection. AJR Am J Roentgenol. May. 2010;194(5):W396-400. [pmid: 20410384].
140 Li R, Guo Y, Hua X, et al. Characterization of focal liver lesions: comparison of pulse-inversion harmonic contrast-enhanced sonography with contrast-enhanced CT. J Clin Ultrasound. Mar–Apr. 2007;35(3):109-17. [pmid: 17295272].
141 Li S, Beheshti M, Peck-Radosavljevic M, et al. Comparison of (11)C-acetate positron emission tomography and (67)Gallium citrate scintigraphy in patients with hepatocellular carcinoma. Liver Int. Oct. 2006;26(8):920-7. [pmid: 16953831].
142 Li CS, Chen RC, Tu HY, et al. Imaging well-differentiated hepatocellular carcinoma with dynamic triple-phase helical computed tomography. Br J Radiol. Aug. 2006;79(944):659-65. [pmid: 16641423].
143 Liangpunsakul S, Agarwal D, Horlander JC, et al. Positron emission tomography for detecting occult hepatocellular carcinoma in hepatitis C cirrhotics awaiting for liver transplantation. Transplant Proc. Dec. 2003;35(8):2995-7. [pmid: 14697959].
144 Libbrecht L, Bielen D, Verslype C, et al. Focal lesions in cirrhotic explant livers: pathological evaluation and accuracy of pretransplantation imaging examinations. Liver Transpl. Sep. 2002;8(9):749-61. [pmid: 12200773].
145 Lim JH, Kim SH, Lee WJ, et al. Ultrasonographic detection of hepatocellular carcinoma: Correlation of preoperative ultrasonography and resected liver pathology. Clin Radiol. 2006;61(2):191-7. [pmid: 16439225].
146 Lim JH, Choi D, Kim SH, et al. Detection of hepatocellular carcinoma: value of adding delayed phase imaging to dual-phase helical CT. AJR Am J Roentgenol. Jul. 2002;179(1):67-73. [pmid: 12076907].
147 Lim JH, Kim CK, Lee WJ, et al. Detection of hepatocellular carcinomas and dysplastic nodules in cirrhotic livers: accuracy of helical CT in transplant patients. AJR Am J Roentgenol. Sep. 2000;175(3):693-8. [pmid: 10954452].
148 Lin M-T, Chen C-L, Wang C-C, et al. Diagnostic sensitivity of hepatocellular carcinoma imaging and its application to non-cirrhotic patients. J Gastroenterol Hepatol. Apr. 2011;26(4):745-50. [pmid: 21418303].
149 Lin W-Y, Tsai S-C, Hung G-U. Value of delayed 18F-FDG-PET imaging in the detection of hepatocellular carcinoma. Nucl Med Commun. Apr. 2005;26(4):315-21. [pmid: 15753790].
150 Liu YI, Shin LK, Jeffrey RB, et al. Quantitatively defining washout in hepatocellular carcinoma. AJR Am J Roentgenol. Jan. 2013;200(1):84-9. [pmid: 23255745].
151 Liu YI, Kamaya A, Jeffrey RB, et al. Multidetector computed tomography triphasic evaluation of the liver before transplantation: importance of equilibrium phase washout and morphology for characterizing hypervascular lesions. J Comput Assist Tomogr. Mar–Apr. 2012;36(2):213-9. [pmid: 22446362].
152 Liu WC, Lim JH, Park CK, et al. Poor sensitivity of sonography in detection of hepatocellular carcinoma in advanced liver cirrhosis: accuracy of pretransplantation sonography in 118 patients. Eur Radiol. Jul. 2003;13(7):1693-8. [pmid: 12835987].
153 Lu CH, Chen CL, Cheng YF, et al. Correlation between imaging and pathologic findings in explanted livers of hepatocellular carcinoma cases. Transplant Proc. Apr. 2010;42(3):830-3. [pmid: 20430183].
154 Luca A, Caruso S, Milazzo M, et al. Multidetector-row computed tomography (MDCT) for the diagnosis of hepatocellular carcinoma in cirrhotic candidates for liver transplantation: prevalence of radiological vascular patterns and histological correlation with liver explants. [Erratum appears in Eur Radiol. 2011 Jul;21(7):1574 Note: Grutttadauria, Salvatore [corrected to Gruttadauria, Salvatore]]. Eur Radiol. Apr. 2010;20(4):898-907. [pmid: 19802612].
155 Luo BM, Wen YL, Yang HY, et al. Differentiation between malignant and benign nodules in the liver: use of contrast C3-MODE technology. World J Gastroenterol. Apr. 28. 2005;11(16):2402-7. [pmid: 15832408].
156 Luo W, Numata K, Kondo M, et al. Sonazoid-enhanced ultrasonography for evaluation of the enhancement patterns of focal liver tumors in the late phase by intermittent imaging with a high mechanical index. J Ultrasound Med. Apr. 2009;28(4):439-48. [pmid: 19321671].
157 Luo W, Numata K, Morimoto M, et al. Focal liver tumors: characterization with 3D perflubutane microbubble contrast agent-enhanced US versus 3D contrast-enhanced multidetector CT. Radiology. Apr. 2009;251(1):287-95. [pmid: 19221060].
158 Luo W, Numata K, Morimoto M, et al. Three-dimensional contrast-enhanced sonography of vascular patterns of focal liver tumors: pilot study of visualization methods. AJR Am J Roentgenol. Jan. 2009;192(1):165-73. [pmid: 19098197].
159 Lv P, Lin XZ, Chen K, et al. Spectral CT in patients with small HCC: investigation of image quality and diagnostic accuracy. Eur Radiol. Oct. 2012;22(10):2117-24. [pmid: 22618521].
160 Lv P, Lin XZ, Li J, et al. Differentiation of small hepatic hemangioma from small hepatocellular carcinoma: recently introduced spectral CT method. Radiology. Jun. 2011;259(3):720-9. [pmid: 21357524].
161 Maetani YS, Ueda M, Haga H, et al. Hepatocellular carcinoma in patients undergoing living-donor liver transplantation. Accuracy of multidetector computed tomography by viewing images on digital monitors. Intervirology. 2008;51(Suppl 1):46-51. [pmid: 18544948].
162 Marin D, Catalano C, De Filippis G, et al. Detection of hepatocellular carcinoma in patients with cirrhosis: added value of coronal reformations from isotropic voxels with 64-MDCT. AJR Am J Roentgenol. Jan. 2009;192(1):180-7. [pmid: 19098199].
163 Marin D, Di Martino M, Guerrisi A, et al. Hepatocellular carcinoma in patients with cirrhosis: qualitative comparison of gadobenate dimeglumine-enhanced MR imaging and multiphasic 64-section CT. Radiology. Apr. 2009;251(1):85-95. [pmid: 19332848].
164 Marrero JA, Hussain HK, Nghiem HV, et al. Improving the prediction of hepatocellular carcinoma in cirrhotic patients with an arterially-enhancing liver mass. Liver Transpl. Mar. 2005;11(3):281-9. [pmid: 15719410].
165 Matsuo M, Kanematsu M, Itoh K, et al. Detection of malignant hepatic tumors: comparison of gadolinium-and ferumoxide-enhanced MR imaging. AJR Am J Roentgenol. Sep. 2001;177(3):637-43. [pmid: 11517061].
166 Mita K, Kim SR, Kudo M, et al. Diagnostic sensitivity of imaging modalities for hepatocellular carcinoma smaller than 2 cm. World J Gastroenterol. Sep. 7. 2010;16(33):4187-92. [pmid: 20806437].
167 Mok TSK, Yu SCH, Lee C, et al. False-negative rate of abdominal sonography for detecting hepatocellular carcinoma in patients with hepatitis B and elevated serum alpha-fetoprotein levels. AJR Am J Roentgenol. Aug. 2004;183(2):453-8. [pmid: 15269040].
168 Monzawa S, Ichikawa T, Nakajima H, et al. Dynamic CT for detecting small hepatocellular carcinoma: usefulness of delayed phase imaging. AJR Am J Roentgenol. Jan. 2007;188(1):147-53. [pmid: 17179357].
169 Mori K, Yoshioka H, Takahashi N, et al. Triple arterial phase dynamic MRI with sensitivity encoding for hypervascular hepatocellular carcinoma: comparison of the diagnostic accuracy among the early, middle, late, and whole triple arterial phase imaging. AJR Am J Roentgenol. Jan. 2005;184(1):63-9. [pmid: 15615952].
170 Moriyasu F, Itoh K. Efficacy of perflubutane microbubble-enhanced ultrasound in the characterization and detection of focal liver lesions: phase 3 multicenter clinical trial. AJR Am J Roentgenol. Jul. 2009;193(1):86-95. [pmid: 19542399].
171 Mortele KJ, De Keukeleire K, Praet M, et al. Malignant focal hepatic lesions complicating underlying liver disease: dual-phase contrast-enhanced spiral CT sensitivity and specificity in orthotopic liver transplant patients. Eur Radiol. 2001;11(9):1631-8. [pmid: 11511882].
172 Motosugi U, Ichikawa T, Sou H, et al. Distinguishing hypervascular pseudolesions of the liver from hypervascular hepatocellular carcinomas with gadoxetic acid-enhanced MR imaging. Radiology. Jul. 2010;256(1):151-8. [pmid: 20574092].
173 Murakami T, Kim T, Kawata S, et al. Evaluation of optimal timing of arterial phase imaging for the detection of hypervascular hepatocellular carcinoma by using triple arterial phase imaging with multidetector-row helical computed tomography. Invest Radiol. Aug. 2003;38(8):497-503. [pmid: 12874516].
174 Murakami T, Kim T, Takamura M, et al. Hypervascular hepatocellular carcinoma: detection with double arterial phase multi-detector row helical CT. Radiology. Mar. 2001;218(3):763-7. [pmid: 11230652].
175 Nagaoka S, Itano S, Ishibashi M, et al. Value of fusing PET plus CT images in hepatocellular carcinoma and combined hepatocellular and cholangiocarcinoma patients with extrahepatic metastases: preliminary findings. Liver Int. Sep. 2006;26(7):781-8. [pmid: 16911459].
176 Nakamura Y, Tashiro H, Nambu J, et al. Detectability of hepatocellular carcinoma by gadoxetate disodium-enhanced hepatic MRI: Tumor-by-tumor analysis in explant livers. J Magn Reson Imaging. 2013;37(3):684-91. [pmid: 23055436].
177 Nakamura H, Ito N, Kotake F, et al. Tumor-detecting capacity and clinical usefulness of SPIO-MRI in patients with hepatocellular carcinoma. J Gastroenterol. 2000;35(11):849-55. [pmid: 11085494].
178 Nakayama A, Imamura H, Matsuyama Y, et al. Value of lipiodol computed tomography and digital subtraction angiography in the era of helical biphasic computed tomography as preoperative assessment of hepatocellular carcinoma. Ann Surg. Jul. 2001;234(1):56-62. [pmid: 11420483].
179 Noguchi Y, Murakami T, Kim T, et al. Detection of hepatocellular carcinoma: comparison of dynamic MR imaging with dynamic double arterial phase helical CT. AJR Am J Roentgenol. Feb. 2003;180(2):455-60. [pmid: 12540451].
180 Noguchi Y, Murakami T, Kim T, et al. Detection of hypervascular hepatocellular carcinoma by dynamic magnetic resonance imaging with double-echo chemical shift in-phase and opposed-phase gradient echo technique: comparison with dynamic helical computed tomography imaging with double arterial phase. J Comput Assist Tomogr. Nov–Dec. 2002;26(6):981-7. [pmid: 12488747].
181 Numata K, Fukuda H, Miwa H, et al. Contrast-enhanced ultrasonography findings using a perflubutane-based contrast agent in patients with early hepatocellular carcinoma. Eur J Radiol. 2014. [pmid: 24176532].
182 Onishi H, Kim T, Imai Y, et al. Hypervascular hepatocellular carcinomas: detection with gadoxetate disodium-enhanced MR imaging and multiphasic multidetector CT. Eur Radiol. Apr. 2012;22(4):845-54. [pmid: 22057248].
183 Ooi C-C, Low S-C, Schneider-Kolsky M, et al. Diagnostic accuracy of contrast-enhanced ultrasound in differentiating benign and malignant focal liver lesions: a retrospective study. J Med Imaging Radiat Oncol. Oct. 2010;54(5):421-30. [pmid: 20958940].
184 Ooka Y, Kanai F, Okabe S, et al. Gadoxetic acid-enhanced MRI compared with CT during angiography in the diagnosis of hepatocellular carcinoma. Magn Reson Imaging. 2013;31(5):748-54. Epub 2012 Dec 5. [pmid: 23218794].
185 Park MJ, Kim YK, Lee MH, et al. Validation of diagnostic criteria using gadoxetic acid-enhanced and diffusion-weighted MR imaging for small hepatocellular carcinoma (≤ 2.0 cm) in patients with hepatitis-induced liver cirrhosis. Acta Radiol. 2013;54(2):127-36. [pmid: 23148300].
186 Park M-S, Kim S, Patel J, et al. Hepatocellular carcinoma: detection with diffusion-weighted versus contrast-enhanced magnetic resonance imaging in pretransplant patients. Hepatology. Jul. 2012;56(1):140-8. [pmid: 22370974].
187 Park JH, Kim SH, Park HS, et al. Added value of 80 kVp images to averaged 120 kVp images in the detection of hepatocellular carcinomas in liver transplantation candidates using dual-source dual-energy MDCT: results of JAFROC analysis. Eur J Radiol. Nov. 2011;80(2):e76-85. [pmid: 20875937].
188 Park Y, Kim SH, Kim SH, et al. Gadoxetic acid (Gd-EOB-DTPA)-enhanced MRI versus gadobenate dimeglumine (Gd-BOPTA)-enhanced MRI for preoperatively detecting hepatocellular carcinoma: an initial experience. Korean J Radiol. Jul–Aug. 2010;11(4):433-40. [pmid: 20592927].
189 Park G, Kim YK, Kim CS, et al. Diagnostic efficacy of gadoxetic acid-enhanced MRI in the detection of hepatocellular carcinomas: comparison with gadopentetate dimeglumine. Br J Radiol. Dec. 2010;83(996):1010-6. [pmid: 20682591].
190 Park J-W, Kim JH, Kim SK, et al. A prospective evaluation of 18F-FDG and 11C-acetate PET/CT for detection of primary and metastatic hepatocellular carcinoma. J Nucl Med. Dec. 2008;49(12):1912-21. [pmid: 18997056].
191 Paul SB, Gulati MS, Sreenivas V, et al. Evaluating patients with cirrhosis for hepatocellular carcinoma: value of clinical symptomatology, imaging and alpha-fetoprotein. Oncology. 2007;72(Suppl 1):117-23. [pmid: 18087192].
192 Pauleit D, Textor J, Bachmann R, et al. Hepatocellular carcinoma: detection with gadolinium- and ferumoxides-enhanced MR imaging of the liver. Radiology. Jan. 2002;222(1):73-80. [pmid: 11756708].
193 Pei XQ, Liu LZ, Xiong YH, et al. Quantitative analysis of contrast-enhanced ultrasonography: Differentiating focal nodular hyperplasia from hepatocellular carcinoma. Br J Radiol. Mar. 2013;86(1023):20120536. Epub 2013 Feb 7. [pmid: 23392189].
194 Peterson MS, Baron RL, Marsh JW Jr, et al. Pretransplantation surveillance for possible hepatocellular carcinoma in patients with cirrhosis: epidemiology and CT-based tumor detection rate in 430 cases with surgical pathologic correlation. Radiology. Dec. 2000;217(3):743-9. [pmid: 11110938].
195 Petruzzi N, Mitchell D, Guglielmo F, et al. Hepatocellular carcinoma likelihood on MRI exams. Evaluation of a standardized categorization System. Acad Radiol. Jun. 2013;20(6):694-8. Epub 2013 Mar 28. [pmid: 23541479].
196 Piana G, Trinquart L, Meskine N, et al. New MR imaging criteria with a diffusion-weighted sequence for the diagnosis of hepatocellular carcinoma in chronic liver diseases. J Hepatol. Jul. 2011;55(1):126-32. [pmid: 21145857].
197 Pitton MB, Kloeckner R, Herber S, et al. MRI versus 64-row MDCT for diagnosis of hepatocellular carcinoma. World J Gastroenterol. Dec. 28. 2009;15(48):6044-51. [pmid: 20027676].
198 Pozzi Mucelli RM, Como G, Del Frate C, et al. Multidetector CT with double arterial phase and high-iodine-concentration contrast agent in the detection of hepatocellular carcinoma. Radiol Med (Torino). Mar. 2006;111(2):181-91. [pmid: 16671376].
199 Pugacheva O, Matsui O, Kozaka K, et al. Detection of small hypervascular hepatocellular carcinomas by EASL criteria: comparison with double-phase CT during hepatic arteriography. Eur J Radiol. Dec. 2011;80(3):e201-6. [pmid: 20855175].
200 Quaia E, Alaimo V, Baratella E, et al. The added diagnostic value of 64-row multidetector CT combined with contrast-enhanced US in the evaluation of hepatocellular nodule vascularity: implications in the diagnosis of malignancy in patients with liver cirrhosis. Eur Radiol. Mar. 2009;19(3):651-63. [pmid: 18815790].
201 Quaia E, Bertolotto M, Calderan L, et al. US characterization of focal hepatic lesions with intermittent high-acoustic-power mode and contrast material. Acad Radiol. Jul. 2003;10(7):739-50. [pmid: 12862283].
202 Rhee H, Kim MJ, Park MS, et al. Differentiation of early hepatocellular carcinoma from benign hepatocellular nodules on gadoxetic acid-enhanced MRI. Br J Radiol. Oct. 2012;85(1018):e837-44. [pmid: 22553295].
203 Rickes S, Schulze S, Neye H, et al. Improved diagnosing of small hepatocellular carcinomas by echo-enhanced power Doppler sonography in patients with cirrhosis. Eur J Gastroenterol Hepatol. Aug. 2003;15(8):893-900. [pmid: 12867800].
204 Rimola J, Forner A, Tremosini S, et al. Non-invasive diagnosis of hepatocellular carcinoma ≤ 2 cm in cirrhosis. Diagnostic accuracy assessing fat, capsule and signal intensity at dynamic MRI. J Hepatol. Jun. 2012;56(6):1317-23. [pmid: 22314420].
205 Rizvi S, Camci C, Yong Y, et al. Is post-Lipiodol CT better than i.v. contrast CT scan for early detection of HCC? A single liver transplant center experience. Transplant Proc. Nov. 2006;38(9):2993-5. [pmid: 17112883].
206 Rode A, Bancel B, Douek P, et al. Small nodule detection in cirrhotic livers: evaluation with US, spiral CT, and MRI and correlation with pathologic examination of explanted liver. J Comput Assist Tomogr. May–Jun. 2001;25(3):327-36. [pmid: 11351179].
207 Ronzoni A, Artioli D, Scardina R, et al. Role of MDCT in the diagnosis of hepatocellular carcinoma in patients with cirrhosis undergoing orthotopic liver transplantation. AJR Am J Roentgenol. Oct. 2007;189(4):792-8. [pmid: 17885047].
208 Sangiovanni A, Manini MA, Iavarone M, et al. The diagnostic and economic impact of contrast imaging techniques in the diagnosis of small hepatocellular carcinoma in cirrhosis. Gut. May. 2010;59(5):638-44. [pmid: 19951909].
209 Sano K, Ichikawa T, Motosugi U, et al. Imaging study of early hepatocellular carcinoma: usefulness of gadoxetic acid-enhanced MR imaging. Radiology. Dec. 2011;261(3):834-44. [pmid: 21998047].
210 Schima W, Hammerstingl R, Catalano C, et al. Quadruple-phase MDCT of the liver in patients with suspected hepatocellular carcinoma: Effect of contrast material flow rate. AJR Am J Roentgenol. 2006;186(6):1571-9. [pmid: 16714645].
211 Secil M, Obuz F, Altay C, et al. The role of dynamic subtraction MRI in detection of hepatocellular carcinoma. Diagn Interv Radiol. Dec. 2008;14(4):200-4. [pmid: 19061165].
212 Seitz K, Strobel D, Bernatik T, et al. Contrast-Enhanced Ultrasound (CEUS) for the characterization of focal liver lesions - prospective comparison in clinical practice: CEUS vs. CT (DEGUM multicenter trial). Parts of this manuscript were presented at the Ultrasound Dreilandertreffen 2008, Davos. Ultraschall Med. Aug. 2009;30(4):383-9. [pmid: 19688670].
213 Seitz K, Bernatik T, Strobel D, et al. Contrast-enhanced ultrasound (CEUS) for the characterization of focal liver lesions in clinical practice (DEGUM Multicenter Trial): CEUS vs. MRI--a prospective comparison in 269 patients. Ultraschall Med. Oct. 2010;31(5):492-9. [pmid: 20652854].
214 Serste T, Barrau V, Ozenne V, et al. Accuracy and disagreement of computed tomography and magnetic resonance imaging for the diagnosis of small hepatocellular carcinoma and dysplastic nodules: role of biopsy. Hepatology. Mar. 2012;55(3):800-6. [pmid: 22006503].
215 Shah SA, Tan JC, McGilvray ID, et al. Accuracy of staging as a predictor for recurrence after liver transplantation for hepatocellular carcinoma. Transplantation. Jun. 27. 2006;81(12):1633-9. [pmid: 16794527].
216 Simon G, Link TM, Wortler K, et al. Detection of hepatocellular carcinoma: comparison of Gd-DTPA- and ferumoxides-enhanced MR imaging. Eur Radiol. May. 2005;15(5):895-903. [pmid: 15800773].
217 Singh P, Erickson RA, Mukhopadhyay P, et al. EUS for detection of the hepatocellular carcinoma: results of a prospective study. Gastrointest Endosc. Aug. 2007;66(2):265-73. [pmid: 17543307].
218 Sofue K, Tsurusaki M, Kawasaki R, et al. Evaluation of hypervascular hepatocellular carcinoma in cirrhotic liver: comparison of different concentrations of contrast material with multi-detector row helical CT--a prospective randomized study. Eur J Radiol. Dec. 2011;80(3):e237-42. [pmid: 21067880].
219 Sørensen M, Frisch K, Bender D, et al. The potential use of 2-[ 18F]fluoro-2-deoxy-D-galactose as a PET/CT tracer for detection of hepatocellular carcinoma. Eur J Nucl Med Mol Imaging. 2011;38(9):1723-31. [pmid: 21553087].
220 Strobel D, Raeker S, Martus P, et al. Phase inversion harmonic imaging versus contrast-enhanced power Doppler sonography for the characterization of focal liver lesions. Int J Colorectal Dis. Jan. 2003;18(1):63-72. [pmid: 12458384].
221 Sugimoto K, Moriyasu F, Saito K, et al. Comparison of Kupffer-phase Sonazoid-enhanced sonography and hepatobiliary-phase gadoxetic acid-enhanced magnetic resonance imaging of hepatocellular carcinoma and correlation with histologic grading. J Ultrasound Med. Apr. 2012;31(4):529-38. [pmid: 22441909].
222 Sugimoto K, Moriyasu F, Shiraishi J, et al. Assessment of arterial hypervascularity of hepatocellular carcinoma: comparison of contrast-enhanced US and gadoxetate disodium-enhanced MR imaging. Eur Radiol. Jun. 2012;22(6):1205-13. [pmid: 22270142].
223 Sugiyama M, Sakahara H, Torizuka T, et al. 18F-FDG PET in the detection of extrahepatic metastases from hepatocellular carcinoma. J Gastroenterol. 2004;39(10):961-8. [pmid: 15549449].
224 Suh YJ, Kim M-J, Choi J-Y, et al. Differentiation of hepatic hyperintense lesions seen on gadoxetic acid-enhanced hepatobiliary phase MRI. AJR Am J Roentgenol. Jul. 2011;197(1):W44-52. [pmid: 21700994].
225 Sun HY, Lee JM, Shin CI, et al. Gadoxetic acid-enhanced magnetic resonance imaging for differentiating small hepatocellular carcinomas (≤ 2 cm in diameter) from arterial enhancing pseudolesions: special emphasis on hepatobiliary phase imaging. Invest Radiol. Feb. 2010;45(2):96-103. [pmid: 20057319].
226 Sun L, Guan YS, Pan WM, et al. Metabolic restaging of hepatocellular carcinoma using whole-body F-FDG PET/CT. World J Hepatol. Oct. 31. 2009;1(1):90-7. [pmid: 21160970].
227 Suzuki S, Iijima H, Moriyasu F, et al. Differential diagnosis of hepatic nodules using delayed parenchymal phase imaging of levovist contrast ultrasound: comparative study with SPIO-MRI. Hepatol Res. Jun. 2004;29(2):122-6. [pmid: 15163434].
228 Takahashi M, Maruyama H, Shimada T, et al. Characterization of hepatic lesions (≤ 30 mm) with liver-specific contrast agents: a comparison between ultrasound and magnetic resonance imaging. Eur J Radiol. 2013;82(1):75-84. [pmid: 23116806].
229 Talbot J, Fartoux L, Balogova S, et al. Detection of hepatocellular carcinoma with PET/CT: a prospective comparison of 18F-fluorocholine and 18F-FDG in patients with cirrhosis or chronic liver disease. J Nucl Med. Nov. 2010;51(11):1699-706. [pmid: 20956466].
230 Talbot J, Gutman F, Fartoux L, et al. PET/CT in patients with hepatocellular carcinoma using [(18)F]fluorocholine: preliminary comparison with [(18)F]FDG PET/CT. Eur J Nucl Med Mol Imaging. Nov. 2006;33(11):1285-9. [pmid: 16802155].
231 Tanaka O, Ito H, Yamada K, et al. Higher lesion conspicuity for SENSE dynamic MRI in detecting hypervascular hepatocellular carcinoma: analysis through the measurements of liver SNR and lesion-liver CNR comparison with conventional dynamic MRI. Eur Radiol. Dec. 2005;15(12):2427-34. [pmid: 16041592].
232 Tanaka S, Ioka T, Oshikawa O, et al. Dynamic sonography of hepatic tumors. AJR Am J Roentgenol. Oct. 2001;177(4):799-805. [pmid: 11566675].
233 Tang Y, Yamashita Y, Arakawa A, et al. Detection of hepatocellular carcinoma arising in cirrhotic livers: comparison of gadolinium- and ferumoxides-enhanced MR imaging. AJR Am J Roentgenol. Jun. 1999;172(6):1547-54. [pmid: 10350287].
234 Tanimoto A, Yuasa Y, Jinzaki M, et al. Routine MR imaging protocol with breath-hold fast scans: diagnostic efficacy for focal liver lesions. Radiat Med. Jul–Aug. 2002;20(4):169-79. [pmid: 12296432].
235 Teefey SA, Hildeboldt CC, Dehdashti F, et al. Detection of primary hepatic malignancy in liver transplant candidates: prospective comparison of CT, MR imaging, US, and PET. Radiology. Feb. 2003;226(2):533-42. [pmid: 12563151].
236 Toyota N, Nakamura Y, Hieda M, et al. Diagnostic capability of gadoxetate disodium-enhanced liver MRI for diagnosis of hepatocellular carcinoma: Comparison with multi-detector CT. Hiroshima J Med Sci. 2013;62(3):55-61. [pmid: 24279123].
237 Trojan J, Schroeder O, Raedle J, et al. Fluorine-18 FDG positron emission tomography for imaging of hepatocellular carcinoma. Am J Gastroenterol. Nov. 1999;94(11):3314-9. [pmid: 10566736].
238 Tsurusaki M, Semelka RC, Uotani K, et al. Prospective comparison of high- and low-spatial-resolution dynamic MR imaging with sensitivity encoding (SENSE) for hypervascular hepatocellular carcinoma. Eur Radiol. Oct. 2008;18(10):2206-12. [pmid: 18446347].
239 Valls C, Cos M, Figueras J, et al. Pretransplantation diagnosis and staging of hepatocellular carcinoma in patients with cirrhosis: value of dual-phase helical CT. AJR Am J Roentgenol. Apr. 2004;182(4):1011-7. [pmid: 15039179].
240 Van Thiel DH, Yong S, Li SD, et al. The development of de novo hepatocellular carcinoma in patients on a liver transplant list: frequency, size, and assessment of current screening methods. Liver Transpl. May. 2004;10(5):631-7. [pmid: 15108254].
241 Vandecaveye V, De Keyzer F, Verslype C, et al. Diffusion-weighted MRI provides additional value to conventional dynamic contrast-enhanced MRI for detection of hepatocellular carcinoma. Eur Radiol. Oct. 2009;19(10):2456-66. [pmid: 19440718].
242 Verhoef C, Valkema R, de Man RA, et al. Fluorine-18 FDG imaging in hepatocellular carcinoma using positron coincidence detection and single photon emission computed tomography. Liver. Feb. 2002;22(1):51-6. [pmid: 11906619].
243 Wagnetz U, Atri M, Massey C, et al. Intraoperative ultrasound of the liver in primary and secondary hepatic malignancies: comparison with preoperative 1.5-T MRI and 64-MDCT. AJR Am J Roentgenol. Mar. 2011;196(3):562-8. [pmid: 21343497].
244 Wang ZL, Tang J, Weskott HP, et al. Undetermined focal liver lesions on gray-scale ultrasound in patients with fatty liver: characterization with contrast-enhanced ultrasound. J Gastroenterol Hepatol. Oct. 2008;23(10):1511-9. [pmid: 18713302].
245 Wang J-H, Lu S-N, Hung C-H, et al. Small hepatic nodules (≤ 2 cm) in cirrhosis patients: characterization with contrast-enhanced ultrasonography. Liver Int. Oct. 2006;26(8):928-34. [pmid: 16953832].
246 Wolfort RM, Papillion PW, Turnage RH, et al. Role of FDG-PET in the evaluation and staging of hepatocellular carcinoma with comparison of tumor size, AFP level, and histologic grade. Int Surg. Jan–Mar. 2010;95(1):67-75. [pmid: 20480845].
247 Wu H-b, Wang Q-s, Li B-y, et al. F-18 FDG in conjunction with 11C-choline PET/CT in the diagnosis of hepatocellular carcinoma. Clin Nucl Med. Dec. 2011;36(12):1092-7. [pmid: 22064078].
248 Wudel LJ Jr, Delbeke D, Morris D, et al. The role of [18F]fluorodeoxyglucose positron emission tomography imaging in the evaluation of hepatocellular carcinoma. Am Surg. Feb. 2003;69(2):117-24. discussion 24–6. [pmid: 12641351].
249 Xiao X-g, Han X, Shan W-d, et al. Multi-slice CT angiography by triple-phase enhancement in preoperative evaluation of hepatocellular carcinoma. Chin Med J (Engl). May. 20. 2005;118(10):844-9. [pmid: 15989766].
250 Xu HX, Lu MD, Liu LN, et al. Discrimination between neoplastic and non-neoplastic lesions in cirrhotic liver using contrast-enhanced ultrasound. Br J Radiol. Oct. 2012;85(1018):1376-84. [pmid: 22553290].
251 Xu P-J, Yan F-H, Wang J-H, et al. Contribution of diffusion-weighted magnetic resonance imaging in the characterization of hepatocellular carcinomas and dysplastic nodules in cirrhotic liver. J Comput Assist Tomogr. Jul. 2010;34(4):506-12. [pmid: 20657216].
252 Xu P-J, Yan F-H, Wang J-H, et al. Added value of breathhold diffusion-weighted MRI in detection of small hepatocellular carcinoma lesions compared with dynamic contrast-enhanced MRI alone using receiver operating characteristic curve analysis. J Magn Reson Imaging. Feb. 2009;29(2):341-9. [pmid: 19161186].
253 Xu H-X, Xie X-Y, Lu M-D, et al. Contrast-enhanced sonography in the diagnosis of small hepatocellular carcinoma ≤ 2 cm. J Clin Ultrasound. Jun. 2008;36(5):257-66. [pmid: 18088056].
254 Yamamoto Y, Nishiyama Y, Kameyama R, et al. Detection of hepatocellular carcinoma using 11C-choline PET: Comparison with 18F-FDG PET. J Nucl Med. Aug. 2008;49(8):1245-8. [pmid: 18632827].
255 Yamamoto K, Shiraki K, Deguchi M, et al. Diagnosis of hepatocellular carcinoma using digital subtraction imaging with the contrast agent, Levovist: comparison with helical CT, digital subtraction angiography, and US angiography. Oncol Rep. Jul–Aug. 2002;9(4):789-92. [pmid: 12066210].
256 Yan FH, Shen JZ, Li RC, et al. Enhancement patterns of small hepatocellular carcinoma shown by dynamic MRI and CT. Hepatobiliary Pancreat Dis Int. Aug. 2002;1(3):420-4. [pmid: 14607719].
257 Yoo SH, Choi JY, Jang JW, et al. Gd-EOB-DTPA-enhanced MRI is better than MDCT in decision making of curative treatment for hepatocellular carcinoma. Ann Surg Oncol. 2013;20(9):2893-900. [pmid: 23649931].
258 Yoo HJ, Lee JM, Lee JY, et al. Additional value of SPIO-enhanced MR imaging for the noninvasive imaging diagnosis of hepatocellular carcinoma in cirrhotic liver. Invest Radiol. Dec. 2009;44(12):800-7. [pmid: 19838119].
259 Yoon KT, Kim JK, Kim DY, et al. Role of 18F-fluorodeoxyglucose positron emission tomography in detecting extrahepatic metastasis in pretreatment staging of hepatocellular carcinoma. Oncology. 2007;72(Suppl 1):104-10. [pmid: 18087190].
260 Yoshioka H, Takahashi N, Yamaguchi M, et al. Double arterial phase dynamic MRI with sensitivity encoding (SENSE) for hypervascular hepatocellular carcinomas. J Magn Reson Imaging. Sep. 2002;16(3):259-66. [pmid: 12205581].
261 Youk JH, Lee JM, Kim CS. MRI for detection of hepatocellular carcinoma: comparison of mangafodipir trisodium and gadopentetate dimeglumine contrast agents. AJR Am J Roentgenol. Oct. 2004;183(4):1049-54. [pmid: 15385303].
262 Yu Y, Lin X, Chen K, et al. Hepatocellular carcinoma and focal nodular hyperplasia of the liver: differentiation with CT spectral imaging. Eur Radiol. Jun. 2013;23(6):1660-8. Epub 2013 Jan 10. [pmid: 23306709].
263 Yu Y, He N, Sun K, et al. Differentiating hepatocellular carcinoma from angiomyolipoma of the liver with CT spectral imaging: A preliminary study. Clin Radiol. 2013;68(9):e491-e7. [pmid: 23702491].
264 Yu MH, Kim JH, Yoon JH, et al. Role of C-arm CT for transcatheter arterial chemoembolization of hepatocellular carcinoma: Diagnostic performance and predictive value for therapeutic response compared with gadoxetic acid-enhanced MRI. AJR Am J Roentgenol. 2013;201(3):675-83. [pmid: 23971463].
265 Yu NC, Chaudhari V, Raman SS, et al. CT and MRI improve detection of hepatocellular carcinoma, compared with ultrasound alone, in patients with cirrhosis. Clin Gastroenterol Hepatol. Feb. 2011;9(2):161-7. [pmid: 20920597].
266 Yu JS, Chung JJ, Kim JH, et al. Small hypervascular hepatocellular carcinomas: value of “washout” on gadolinium-enhanced dynamic MR imaging compared to superparamagnetic iron oxide-enhanced imaging. Eur Radiol. Nov. 2009;19(11):2614-22. [pmid: 19513719].
267 Yu JS, Lee JH, Chung JJ, et al. Small hypervascular hepatocellular carcinoma: limited value of portal and delayed phases on dynamic magnetic resonance imaging. Acta Radiol. Sep. 2008;49(7):735-43. [pmid: 18608015].
268 Yu JS, Kim KW, Park MS, et al. Transient peritumoral enhancement during dynamic MRI of the liver: Cavernous hemangioma versus hepatocellular carcinoma. J Comput Assist Tomogr. May–Jun. 2002;26(3):411-7. [pmid: 12016371].
269 Yukisawa S, Okugawa H, Masuya Y, et al. Multidetector helical CT plus superparamagnetic iron oxide-enhanced MR imaging for focal hepatic lesions in cirrhotic liver: a comparison with multi-phase CT during hepatic arteriography. Eur J Radiol. Feb. 2007;61(2):279-89. [pmid: 17070663].
270 Zacherl J, Pokieser P, Wrba F, et al. Accuracy of multiphasic helical computed tomography and intraoperative sonography in patients undergoing orthotopic liver transplantation for hepatoma: what is the truth?. Ann Surg. Apr. 2002;235(4):528-32. [pmid: 11923609].
271 Zhao H, Yao J-L, Wang Y, et al. Detection of small hepatocellular carcinoma: comparison of dynamic enhancement magnetic resonance imaging and multiphase multirow-detector helical CT scanning. World J Gastroenterol. Feb. 28. 2007;13(8):1252-6. [pmid: 17451209].
272 Zhao H, Yao JL, Han MJ, et al. Multiphase hepatic scans with multirow-detector helical CT in detection of hypervascular hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. May. 2004;3(2):204-8. [pmid: 15138110].
273 Zhao H, Zhou K-R, Yan F-H. Role of multiphase scans by multirow-detector helical CT in detecting small hepatocellular carcinoma. World J Gastroenterol. Oct. 2003;9(10):2198-201. [pmid: 14562377].
274 Zheng X-H, Guan Y-S, Zhou X-P, et al. Detection of hypervascular hepatocellular carcinoma: Comparison of multi-detector CT with digital subtraction angiography and Lipiodol CT. World J Gastroenterol. Jan. 14. 2005;11(2):200-3. [pmid: 15633215].
275 Zhou K-R, Yan F-H, Tu B-W. Arterial phase of biphase enhancement spiral CT in diagnosis of small hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. Feb. 2002;1(1):68-71. [pmid: 14607626].
276 Pocha C, Dieperink E, McMaken KA, et al. Surveillance for hepatocellular cancer with ultrasonography vs. computed tomography - A randomised study. Aliment Pharmacol Ther. 2013;38(3):303-12. [pmid: 23750991].
277 Trinchet JC, Chaffaut C, Bourcier V, et al. Ultrasonographic surveillance of hepatocellular carcinoma in cirrhosis: a randomized trial comparing 3- and 6-month periodicities. Hepatology. Dec. 2011;54(6):1987-97. [pmid: 22144108].
278 Wang JH, Chang KC, Kee KM, et al. Hepatocellular carcinoma surveillance at 4- vs. 12-month intervals for patients with chronic viral hepatitis: a randomized study in community. Am J Gastroenterol. Mar. 2013;108(3):416-24. [pmid: 23318478].
279 Zhang BH, Yang BH, Tang ZY. Randomized controlled trial of screening for hepatocellular carcinoma. J Cancer Res Clin Oncol. Jul. 2004;130(7):417-22. [pmid: 15042359].
280 Chen MH, Wu W, Yang W, et al. The use of contrast-enhanced ultrasonography in the selection of patients with hepatocellular carcinoma for radio frequency ablation therapy. J Ultrasound Med. 2007;26(8):1055-63. [pmid: 17646367].
281 Chen MH, Yang W, Yan K, et al. The role of contrast-enhanced ultrasound in planning treatment protocols for hepatocellular carcinoma before radiofrequency ablation. Clin Radiol. Aug. 2007;62(8):752-60. [pmid: 17604763].