# Strength of Evidence

## Key Question 1 Surveillance

Table J1 Key Question 1a: Test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
Surveillance settings Unit of analysis: patients with HCC | US without contrast | Sens: 4 Spec: 3 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 540 Spec: 488 | Sens: Low Spec: Low
Surveillance settings Unit of analysis: patients with HCC | CT | Sens: 2 Spec: 2 | Moderate | Consistent | Indirect | Imprecise | Sens: 385 Spec: 385 | Sens: Low Spec: Low
Surveillance settings Unit of analysis: patients with HCC | MRI or PET | No evidence | -- | -- | -- | -- | -- | Insufficient
Surveillance settings Unit of analysis: HCC lesions | US without contrast | Sens: 1 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 42 Spec: -- | Sens: Low Spec: Insufficient
Surveillance settings Unit of analysis: HCC lesions | CT | Sens: 1 Spec: 0 | Moderate | Sens: Single study Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 42 Spec: -- | Sens: Low Spec: Insufficient
Surveillance settings Unit of analysis: HCC lesions | MRI or PET | No evidence | -- | -- | -- | -- | -- | Insufficient
Nonsurveillance settings Unit of analysis: patients with HCC | US without contrast | Sens: 8 Spec: 6 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 975 Spec: 858 | Sens: Low Spec: Low
Nonsurveillance settings Unit of analysis: patients with HCC | CT | Sens: 16 Spec: 11 | Moderate | Inconsistent | Indirect | Precise | Sens: 1277 Spec: 1095 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: patients with HCC | MRI | Sens: 10 Spec: 8 | Moderate | Inconsistent | Indirect | Precise | Sens: 1066 Spec: 974 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: patients with HCC | PET | Sens: 15 Spec: 5 | Moderate | Inconsistent | Indirect | Sens: Precise Spec: Imprecise | Sens: 559 Spec: 144 | Sens: Moderate Spec: Low
Nonsurveillance settings Unit of analysis: HCC lesions | US without contrast | Sens: 11 Spec: 2 | Moderate | Inconsistent | Indirect | Sens: Precise Spec: Imprecise | Sens: 1996 Spec: 323 | Sens: Moderate Spec: Low
Nonsurveillance settings Unit of analysis: HCC lesions | US with contrast | Sens: 8 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 374 Spec: -- | Sens: Low Spec: Insufficient
Nonsurveillance settings Unit of analysis: HCC lesions | CT | Sens: 79 Spec: 21 | Moderate | Inconsistent | Indirect | Precise | Sens: 8090 Spec: 2893 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: HCC lesions | MRI | Sens: 75 Spec: 16 | Moderate | Inconsistent | Indirect | Precise | Sens: 6664 Spec: 1984 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: HCC lesions | PET | Sens: 9 Spec: 1 | Moderate | Sens: Inconsistent Spec: Single study | Indirect | Sens: Precise Spec: Imprecise | Sens: 674 Spec: 104 | Sens: Moderate Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. CT | Sens: 6 Spec: 5 | Moderate | Inconsistent | Direct | Precise | Sens: 899 (US) Sens: 838 (CT) Spec: 885 (US) Spec: 824 (CT) | Sens: Moderate Spec: Moderate For the 2 studies in surveillance settings, the strength of evidence is low for sensitivity and specificity.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. MRI | Sens: 3 Spec: 3 | Moderate | Consistent | Direct | Precise | Sens: 712 (US) Sens: 712 (MRI) Spec: 712 (US) Spec: 712 (MRI) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | MRI vs. CT | Sens: 4 Spec: 4 | Moderate | Inconsistent | Direct | Precise | Sens: 318 (MRI) Sens: 484 (CT) Spec: 318 (MRI) Spec: 484 (CT) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US without contrast vs. CT | Sens: 3 Spec: 2 | Moderate | Inconsistent | Direct | Precise | Sens: 535 (US) Sens: 539 (CT) Spec: 323 (US) Spec: 323 (CT) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US without contrast vs. MRI | Sens: 3 Spec: 2 | Moderate | Consistent | Direct | Precise | Sens: 660 (US) Sens: 660 (MRI) Spec: 323 (US) Spec: 323 (MRI) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. CT | Sens: 4 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Precise Spec: No studies | Sens: 217 (US) Sens: 217 (CT) Spec: -- | Sens: Moderate Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. MRI | Sens: 3 Spec: 0 | Moderate | Sens: Consistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 172 (US) Sens: 170 (MRI) Spec: -- | Sens: Moderate Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | MRI vs. CT | Sens: 31 Spec: 7 | Moderate | Inconsistent | Direct | Precise | Sens: 2947 (MRI) Sens: 3233 (CT) Spec: 819 (MRI) Spec: 787 (CT) | Sens: Moderate Spec: Moderate
Multiple imaging modalities | Various combinations | Sens: 2 Spec: -- | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 112 Spec: -- | Sens: Insufficient Spec: Insufficient

Table J2 Key Question 1a.i: Effects of reference standard on test performance (based on HCC lesions as the unit of analysis)

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
US without contrast | Sens: 9 Spec: -- | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Precise Spec: No studies | Sens: 982 Spec: -- | Sens: Moderate Spec: Insufficient
US with contrast | Sens: 5 Spec: -- | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 315 Spec: -- | Sens: Low Spec: Insufficient
CT | Sens: 72 Spec: 19 | Moderate | Inconsistent | Indirect | Precise | Sens: 7094 Spec: 2528 | Sens: Moderate Spec: Moderate
MRI | Sens: 63 Spec: 15 | Moderate | Inconsistent | Indirect | Precise | Sens: 5688 Spec: 1732 | Sens: Moderate Spec: Moderate
PET | Sens: 5 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 169 Spec: -- | Sens: Low Spec: Insufficient

Table J3 Key Question 1a.ii: Effects of patient, tumor, technical, and other factors on test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
Lesion Size | US without contrast | Sens: 9 Spec: 2 | Moderate | Inconsistent | Direct | Sens: Precise Spec: Imprecise | Sens: 1013 Spec: 323 | Sens: Moderate Spec: Low
Lesion Size | US with contrast | Sens: 5 Spec: 1 | Moderate | Sens: Inconsistent Spec: Single study | Direct | Imprecise | Sens: 553 Spec: 70 | Sens: Low Spec: Low
Lesion Size | CT | Sens: 34 Spec: 4 | Moderate | Inconsistent | Direct | Sens: Precise Spec: Imprecise | Sens: 3550 Spec: 596 | Sens: Moderate Spec: Low
Lesion Size | MRI | Sens: 29 Spec: 8 | Moderate | Inconsistent | Direct | Precise | Sens: 2723 Spec: 790 | Sens: Moderate Spec: Moderate
Lesion Size | PET | Sens: 5 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 182 Spec: -- | Sens: Low Spec: Insufficient
Degree of tumor differentiation | US with contrast | Sens: 3 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 165 Spec: -- | Sens: Low Spec: Insufficient
Degree of tumor differentiation | CT | Sens: 5 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 320 Spec: -- | Sens: Low Spec: Insufficient
Degree of tumor differentiation | MRI | Sens: 3 Spec: 0 | Moderate | Consistent Spec: No studies | Direct | Imprecise Spec: No studies | Sens: 160 Spec: -- | Sens: Low Spec: Insufficient
Degree of tumor differentiation | PET | Sens: 6 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 309 Spec: -- | Sens: Low Spec: Insufficient
Other factors | US | 1 to 3, depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low
Other factors | CT | 4–8, depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low
Other factors | MRI | 2–8, depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low
Other factors | PET | 1–8, depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low

Table J4 Key Question 1b: Clinical decisionmaking

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
All | 1 RCT | Moderate | Single study | Direct | Imprecise | 163 | Low

Table J5 Key Question 1c: Clinical and patient-centered outcomes

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
US plus serum AFP | 1 RCT | High | Single study of surveillance vs. no surveillance | Direct | Precise | 18816 | Low
US screening at different intervals, mortality | 3 RCTs | Moderate | Consistent | Direct | Precise | 2185 | Moderate

Table J6 Key Question 1d: Harms

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
MRI, CT, US | 2 | Moderate | Inconsistent | Direct | Imprecise | 248 | Insufficient

## Key Question 2 Diagnosis

Table J7 Key Question 2a: Test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
Evaluation of focal liver lesion Unit of analysis: patients with HCC | US with contrast | Sens: 12 Spec: 8 | Moderate | Inconsistent | Indirect | Precise | Sens: 836 Spec: 678 | Sens: Moderate Spec: Moderate
Evaluation of focal liver lesion Unit of analysis: patients with HCC | US without contrast | Sens: 1 Spec: 0 | Moderate | Sens: Consistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 93 Spec: -- | Sens: Low Spec: Insufficient
Evaluation of focal liver lesion Unit of analysis: patients with HCC | CT | Sens: 8 Spec: 5 | Moderate | Inconsistent | Indirect | Sens: Precise Spec: Imprecise | Sens: 656 Spec: 471 | Sens: Moderate Spec: Low
Evaluation of focal liver lesion Unit of analysis: patients with HCC | MRI | Sens: 4 Spec: 4 | Moderate | Consistent | Indirect | Imprecise | Sens: 308 Spec: 308 | Sens: Low Spec: Low
Evaluation focal liver lesion Unit of analysis: HCC lesions | US with contrast | Sens: 21 Spec: 10 | Moderate | Inconsistent | Indirect | Precise | Sens: 1652 Spec: 1175 | Sens: Moderate Spec: Moderate
Evaluation focal liver lesion Unit of analysis: HCC lesions | CT | Sens: 13 Spec: 6 | Moderate | Inconsistent | Indirect | Precise | Sens: 1196 Spec: 591 | Sens: Moderate Spec: Moderate
Evaluation focal liver lesion Unit of analysis: HCC lesions | MRI | Sens: 14 Spec: 11 | Moderate | Inconsistent | Indirect | Precise | Sens: 1185 Spec: 1014 | Sens: Moderate Spec: Moderate
Evaluation focal liver lesion Unit of analysis: HCC lesions | PET | Sens: 2 Spec: 2 | Moderate | Consistent | Indirect | Imprecise | Sens: 168 Spec: 168 | Sens: Low Spec: Low
For distinguishing HCC lesions from non-HCC hepatic lesions | US with contrast | Sens: 2 Spec: 2 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 167 Spec: 167 | Sens: Low Spec: Low
For distinguishing HCC lesions from non-HCC hepatic lesions | CT | Sens: 5 Spec: 5 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 467 Spec: 467 | Sens: Low Spec: Low
For distinguishing HCC lesions from non-HCC hepatic lesions | MRI | Sens: 12 Spec: 10 | Moderate | Inconsistent | Indirect | Precise | Sens: 1025 Spec: 908 | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: Patients with HCC | US without contrast vs. CT | Sens: 1 Spec: 0 | Moderate | Sens: Single study Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 121 Spec: 0 | Sens: Low Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: Patients with HCC | US with contrast vs. CT | Sens: 5 Spec: 2 | Moderate | Consistent | Direct | Sens: Precise Spec: Imprecise | Sens: 956 Spec: 586 | Sens: Moderate Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: Patients with HCC | MRI vs. CT | Sens: 1 Spec: 1 | Moderate | Single study | Direct | Imprecise | Sens: 74 Spec: 74 | Sens: Low Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. CT | Sens: 4 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 446 Spec: 0 | Sens: Moderate Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. MRI | Sens: 1 Spec: 1 | Moderate | Single study | Direct | Imprecise | Sens: 162 Spec: 162 | Sens: Low Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | MRI vs. CT | Sens: 1 Spec: 1 | Moderate | Single study | Direct | Imprecise | Sens: 123 Spec: 123 | Sens: Low Spec: Low
Multiple imaging modalities | Various combinations | 7 | Moderate | Consistent | Direct | Imprecise | 552 | Moderate

Table J8 Key Question 2a.i: Effects of reference standard on test performance (based on HCC lesions as the unit of analysis)

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
All | Sens: 23 (US) Spec: 11 (US) Sens: 13 (CT) Spec: 6 (CT) Sens: 14 (MRI) Spec: 11 (MRI) | Moderate | Inconsistent | Indirect | Precise | Sens: 1871 (US) Spec: 1322 (US) Sens: 1218 (CT) Spec: 294 (CT) Sens: 1064 (MRI) Spec: 908 (MRI) | Sens: Moderate Spec: Moderate

Table J9 Key Question 2a.ii: Effects of patient, tumor, technical, and other factors on test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
Other factors | US | 1–2, depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low
Other factors | CT | 1–3. depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low
Other factors | MRI | 5–8, depending on factor | Moderate | Inconsistent | Direct | Imprecise | N/A | Low

Table J10 Key Question 2b: Clinical decisionmaking

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
All | No evidence | -- | -- | -- | -- | -- | Insufficient

Table J11 Key Question 2c: Clinical and patient-centered outcomes

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
All | No evidence | -- | -- | -- | -- | -- | Insufficient

Table J12 Key Question 2d: Harms

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
US and CT | 1 | High | Single study | Direct | Imprecise | 190 | Insufficient

## Key Question 3 Staging

Table J13 Key Question 3a: Test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
Staging accuracy, using TNM criteria | CT | 6 | Moderate | Inconsistent | Indirect | Precise | 985 | Moderate
Staging accuracy, using TNM criteria | MRI | 3 | Moderate | Inconsistent | Indirect | Imprecise | 960 | Low
Staging accuracy, using TNM criteria | PET | 1 | Moderate | Single study | Indirect | Imprecise | 43 | Low
Staging accuracy, using TNM criteria | MRI vs. CT | 2 | Moderate | Inconsistent | Direct | Imprecise | 831 | Low
Identification of metastatic disease Unit of analysis: Patients with metastatic HCC | PET | Sens: 6 Spec: 5 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 375 Spec: 356 | Sens: Low Spec: Low
Identification of metastatic disease Unit of analysis: Patients with Metastatic HCC lesions | PET/CT vs. CT | 3 | Moderate | Inconsistent | Direct | Imprecise | 183 | Low
Identification of metastatic disease Unit of analysis: Metastatic HCC lesions | PET | Sens: 5 Spec: 0 | Sens: Moderate Spec: No studies | Consistent | Indirect | Sens: Imprecise Spec: No studies | Sens: 237 Spec: -- | Sens: Low Spec: Insufficient

Table J14 Key Question 3.a.i: Effects of reference standard on test performance

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
CT, MRI, PET | 6 | Moderate | Consistent | Indirect | Imprecise | Sens: 375 Spec: 356 | Sens: Insufficient Spec: Insufficient

Table J15 Key Question 3.a.ii: Effects of patient, tumor, and technical factors on test performance

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
CT, MRI, PET | No evidence | -- | -- | -- | -- | -- | Insufficient
PET | 1–8, depending on factor | Moderate | Inconsistent | Indirect | Imprecise | N/A | Low

Table J16 Key Question 3b: Clinical decisionmaking

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
Transplant eligibility, using Milan criteria | CT | 7 | Moderate | Consistent | Indirect | Imprecise | 442 | Moderate
Transplant eligibility, using Milan criteria | CT vs. MRI | 1 | Moderate | Single study | Direct | Imprecise | 57 | Low
Transplant eligibility, using Milan criteria | PET vs. CT | 1 | Moderate | Single study | Direct | Imprecise | 43 | Low
Use of resection and ablative therapies | MRI vs. CT | 1 | High | Single study | Direct | Imprecise | 50 | Low

Table J17 Key Question 3c: Clinical and patient-centered outcomes

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
US with contrast vs. US without contrast plus CT | 1 | High | Single study | Direct | Imprecise | 167 | Low

Table J18 Key Question 3d: Harms

Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects | Strength of Evidence (High, Moderate, Low, Insufficient)
All | No evidence | -- | -- | -- | -- | -- | Insufficient

AFP = alpha-fetoprotein; CT = computed axial tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; PET = positron emission tomography; RCT = randomized control trial; Sens = sensitivity; Spec = specificity; TNM = tumor, node, metastasis staging sytem; US = ultrasound; vs. = versus