# Evidence Table: Comparative Effectiveness of Imaging Strategies on Clinical Decisionmaking and Patient Outcomes (Cohort Studies)

Table I1 Characteristics of cohort studies of effectiveness of imaging strategies on clinical decisionmaking and patient outcomes