# Evidence Table: Patient Outcomes for Staging (Randomized Controlled Trials)

Table H1 Characteristics of randomized controlled trials of patient outcomes for staging