# Evidence Table: Diagnostic Accuracy Studies of Positron Emission Tomography Imaging

Table G1 Characteristics of diagnostic accuracy studies of positron emission tomography imaging