# Evidence Table: Diagnostic Accuracy Studies of Magnetic Resonance Imaging

Table F1 Characteristics of diagnostic accuracy studies of magnetic resonance imaging