# Evidence Table: Diagnostic Accuracy Studies of Computed Tomography Imaging

Table E1 Characteristics of diagnostic accuracy studies of computed tomography imaging