# Evidence Table: Diagnostic Accuracy Studies of Ultrasound Imaging

Table D1 Characteristics of diagnostic accuracy studies of ultrasound imaging