# Risk of Bias

Table C1 Risk of bias: Diagnostic studies

Table C2 Risk of bias: Randomized controlled trials

Table C3 Risk of bias: Cohort study