# Excluded Studies

Abe Y, Yamashita Y, Tang Y, Namimoto T, Takahashi M. Calculation of T2 relaxation time from ultrafast single shot sequences for differentiation of liver tumors: comparison of echo-planar, HASTE, and spin-echo sequences. Radiat Med. 2000;18(1):7-14. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10852650].
Achkar JP, Araya V, Baron RL, Marsh JW, Dvorchik I, Rakela J. Undetected hepatocellular carcinoma: clinical features and outcome after liver transplantation. Liver Transpl Surg. 1998;4(6):477-482. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9791158].
Ahn SJ, Kim M-J, Hong H-S, Kim KA, Song H-T. Distinguishing hemangiomas from malignant solid hepatic lesions: a comparison of heavily T2-weighted images obtained before and after administration of gadoxetic acid. J Magn Reson Imaging. 2011;34(2):310-317. Excluded: Wrong population. [pmid: 21598345].
Ainsworth AP, Pless T, Nielsen HO. Potential impact of adding endoscopic ultrasound to standard imaging procedures in the preoperative assessment of resectability in patients with liver tumors. Scand J Gastroenterol. 2011;46(7–8):1020-1023. Excluded: Wrong intervention. [pmid: 21504382].
Akai H, Matsuda I, Kiryu S, et al. Fate of hypointense lesions on Gd-EOB-DTPA-enhanced magnetic resonance imaging. Eur J Radiol. 2012;81(11):2973-2977. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22280873].
Altenbernd J, Heusner TA, Ringelstein A, Ladd SC, Forsting M, Antoch G. Dual-energy-CT of hypervascular liver lesions in patients with HCC: investigation of image quality and sensitivity. Eur Radiol. 2011;21(4):738-743. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20936520].
Andersson KL, Salomon JA, Goldie SJ, Chung RT. Cost effectiveness of alternative surveillance strategies for hepatocellular carcinoma in patients with cirrhosis. Clin Gastroenterol Hepatol. 2008;6(12):1418-1424. Excluded: Background. [pmid: 18848905].
Ando E, Tanaka M, Yamashita F, et al. Diagnostic clues for recurrent hepatocellular carcinoma: comparison of tumour markers and imaging studies. Eur J Gastroenterol Hepatol. 2003;15(6):641-648. Excluded: Imaging before 1995. [pmid: 12840676].
Ansari D, Keussen I, Andersson R. Positron emission tomography in malignancies of the liver, pancreas and biliary tract - indications and potential pitfalls. [Review]. Scandinavian Journal of Gastroenterology. 482013:259-265. Excluded: Wrong publication type. [pmid: 23148675].
Barone C, Koeberle D, Metselaar H, Parisi G, Sansonno D, Spinzi G. Multidisciplinary approach for HCC patients: hepatology for the oncologists. [Review]. Annals of Oncology. 242013. Excluded: Wrong publication type.
Bartolotta TV, Taibbi A, Galia M, et al. Characterization of hypoechoic focal hepatic lesions in patients with fatty liver: diagnostic performance and confidence of contrast-enhanced ultrasound. Eur Radiol. 2007;17(3):650-661. Excluded: Wrong population. [pmid: 17180328].
Bartolotta TV, Taibbi A, Midiri M, La Grutta L, De Maria M, Lagalla R. Characterisation of focal liver lesions undetermined at grey-scale US: contrast-enhanced US versus 64-row MDCT and MRI with liver-specific contrast agent. Radiol Med. 2010;115(5):714-731. Excluded: Inadequate reference standard. [pmid: 20082225].
Bartolozzi C, Battaglia V, Bargellini I, et al. Contrast-enhanced magnetic resonance imaging of 102 nodules in cirrhosis: correlation with histological findings on explanted livers. Abdom Imaging. 2013;38(2):290-296. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23053453].
Bashir MR, Gupta RT, Davenport MS, et al. Hepatocellular carcinoma in a North American population: does hepatobiliary MR imaging with Gd-EOB-DTPA improve sensitivity and confidence for diagnosis?. J Magn Reson Imaging. 2013;37(2):398-406. Excluded: Inadequate reference standard. [pmid: 23011874].
Ba-Ssalamah A, Heinz-Peer G, Schima W, et al. Detection of focal hepatic lesions: comparison of unenhanced and SHU 555 A-enhanced MR imaging versus biphasic helical CTAP. J Magn Reson Imaging. 2000;11(6):665-672. Excluded: Wrong population. [pmid: 10862066].
Beaton C, Cochlin D, Kumar N. Contrast enhanced ultrasound should be the initial radiological investigation to characterise focal liver lesions. Eur J Surg Oncol. 2010;36(1):43-46. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19709846].
Beissert M, Delorme S, Mutze S, et al. Comparison of B-mode and conventional colour/power Doppler ultrasound, contrast-enhanced Doppler ultrasound and spiral CT in the diagnosis of focal lesions of the liver: Results of a multicentre study. Ultraschall Med. 2002;23(4):245-250. Excluded: Wrong population. [pmid: 12226762].
Bharat A, Brown DB, Crippin JS, et al. Pre-liver transplantation locoregional adjuvant therapy for hepatocellular carcinoma as a strategy to improve longterm survival. J Am Coll Surg. 2006;203(4):411-420. Excluded: Wrong intervention. [pmid: 17000383].
Bhartia B, Ward J, Guthrie JA, Robinson PJ. Hepatocellular carcinoma in cirrhotic livers: double-contrast thin-section MR imaging with pathologic correlation of explanted tissue. AJR Am J Roentgenol. 2003;180(3):577-584. Excluded: Wrong intervention. [pmid: 12591657].
Bieze M, Bennink RJ, El-Massoudi Y, et al. The use of 18F-fluoromethylcholine PET/CT in differentiating focal nodular hyperplasia from hepatocellular adenoma: A prospective study of diagnostic accuracy. Nuclear Medicine Communications. 2013;34(2):146-154. Excluded: Wrong population. [pmid: 23154640].
Bieze M, van den Esschert JW, Nio CY, et al. Diagnostic accuracy of MRI in differentiating hepatocellular adenoma from focal nodular hyperplasia: prospective study of the additional value of gadoxetate disodium. AJR Am J Roentgenol. 2012;199(1):26-34. Excluded: Wrong population. [pmid: 22733890].
Bleuzen A, Huang C, Olar M, Tchuenbou J, Tranquart F. Diagnostic accuracy of contrast-enhanced ultrasound in focal lesions of the liver using cadence contrast pulse sequencing. Ultraschall Med. 2006;27(1):40-48. Excluded: Wrong population. [pmid: 16470478].
Bluemke DA, Paulson EK, Choti MA, DeSena S, Clavien PA. Detection of hepatic lesions in candidates for surgery: comparison of ferumoxides-enhanced MR imaging and dual-phase helical CT. AJR Am J Roentgenol. 2000;175(6):1653-1658. Excluded: Wrong population. [pmid: 11090399].
Bluemke DA, Weber TM, Rubin D, et al. Hepatic MR imaging with ferumoxides: multicenter study of safety and effectiveness of direct injection protocol. Radiology. 2003;228(2):457-464. Excluded: Wrong population. [pmid: 12893904].
Boeve WJ, Kok T, Haagsma EB, Slooff MJ, Sluiter WJ, Kamman RL. Superior diagnostic strength of combined contrast enhanced MR-angiography and MR-imaging compared to intra-arterial DSA in liver transplantation candidates. Magn Reson Imaging. 2001;19(5):609-622. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11672618].
Boin IFSF, Pracucho EM, Rique MC, et al. Expanded Milan criteria on pathological examination after liver transplantation: analysis of preoperative data. Transplant Proc. 2008;40(3):777-779. Excluded: Inadequate reference standard. [pmid: 18455014].
Bruegel M, Gaa J, Waldt S, et al. Diagnosis of hepatic metastasis: comparison of respiration-triggered diffusion-weighted echo-planar MRI and five t2-weighted turbo spin-echo sequences. AJR Am J Roentgenol. 2008;191(5):1421-1429. Excluded: Wrong population. [pmid: 18941080].
Bryant TH, Blomley MJ, Albrecht T, et al. Improved characterization of liver lesions with liver-phase uptake of liver-specific microbubbles: prospective multicenter study. Radiology. 2004;232(3):799-809. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15284434].
Carlos RC, Kim HM, Hussain HK, Francis IR, Nghiem HV, Fendrick AM. Developing a prediction rule to assess hepatic malignancy in patients with cirrhosis. AJR Am J Roentgenol. 2003;180(4):893-900. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12646426].
Caturelli E, Bartolucci F, Biasini E, et al. Diagnosis of liver nodules observed in chronic liver disease patients during ultrasound screening for early detection of hepatocellular carcinoma. Am J Gastroenterol. 2002;97(2):397-405. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11866279].
Cedrone A, Pompili M, Sallustio G, Lorenzelli GP, Gasbarrini G, Rapaccini GL. Comparison between color power Doppler ultrasound with echo-enhancer and spiral computed tomography in the evaluation of hepatocellular carcinoma vascularization before and after ablation procedures. Am J Gastroenterol. 2001;96(6):1854-1859. Excluded: Wrong population. [pmid: 11419839].
Cha DI, Lee MW, Kim YK, et al. Assessing patients with hepatocellular carcinoma meeting the milan criteria: Is liver 3 tesla MR with gadoxetic acid necessary in addition to liver CT?. J Magn Reson Imaging. 2013. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Cha MJ, Lee MW, Cha DI, et al. Size discrepancy between sonographic and computed tomographic/magnetic resonance imaging measurement of hepatocellular carcinoma : the necessity of tumor size measurement standardization. J Ultrasound Med. 2013;32(10):1703-1709. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 24065250].
Chami L, Lassau N, Malka D, et al. Benefits of contrast-enhanced sonography for the detection of liver lesions: comparison with histologic findings. [Erratum appears in AJR Am J Roentgenol. 2008 May;190(5):1152]. AJR Am J Roentgenol. 2008;190(3):683-690. Excluded: Wrong population. [pmid: 18287439].
Chang JM, Lee JM, Lee MW, et al. Superparamagnetic iron oxide-enhanced liver magnetic resonance imaging: comparison of 1.5 T and 3.0 T imaging for detection of focal malignant liver lesions. Invest Radiol. 2006;41(2):168-174. Excluded: Wrong population. [pmid: 16428988].
Chen HY, Ma XM, Ye M, Hou YL, Hu B, Bai YR. CT-pathologic correlation in primary hepatocellular carcinoma: An implication for target delineation. J Radiat Res (Tokyo). 2013;54(5):938-942. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23616629].
Chen JG, Parkin DM, Chen QG, et al. Screening for liver cancer: results of a randomised controlled trial in Qidong, China. J Med Screen. 2003;10(4):204-209. Excluded: Wrong intervention. [pmid: 14738659].
Chen MM, Yang W, Dai Y, Wu W. High mechanical index post-contrast ultrasonography improves tissue structural display of hepatocellular carcinoma. Chin Med J (Engl). 2005;118(24):2046-2051. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16438901].
Chen R-C, Lii J-M, Chou C-T, et al. T2-weighted and T1-weighted dynamic superparamagnetic iron oxide (ferucarbotran) enhanced MRI of hepatocellular carcinoma and hyperplastic nodules. J Formos Med Assoc. 2008;107(10):798-805. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18926947].
Chen TH-H, Chen C-J, Yen M-F, et al. Ultrasound screening and risk factors for death from hepatocellular carcinoma in a high risk group in Taiwan. Int J Cancer. 2002;98(2):257-261. Excluded: Wrong intervention. [pmid: 11857416].
Chen Z, Liang H, Zhang X, et al. Value of (18)F-FDG PET/CT and CECT in detecting postoperative recurrence and extrahepatic metastasis of hepatocellular carcinoma in patients with elevated serum alpha-fetoprotein. [Chinese]. Nan Fang Yi Ke Da Xue Xue Bao. 2012;32(11):1615-1619. Excluded: Not English language. [pmid: 23174588].
Cheung TT, Ho CL, Chen S, et al. Reply: Underestimated role of 18F-FDG PET for HCC evaluation and promise of 18F-FDG PET/MR imaging in this setting. J Nucl Med. 2013;54(8):1511-1512. Excluded: Wrong publication type. [pmid: 23833273].
Cho CS, Curran S, Schwartz LH, et al. Preoperative radiographic assessment of hepatic steatosis with histologic correlation. J Am Coll Surg. 2008;206(3):480-488. Excluded: Wrong population. [pmid: 18308219].
Choi D, Kim S, Lim J, et al. Preoperative detection of hepatocellular carcinoma: ferumoxides-enhanced mr imaging versus combined helical CT during arterial portography and CT hepatic arteriography. AJR Am J Roentgenol. 2001;176(2):475-482. Excluded: Wrong intervention. [pmid: 11159099].
Choi JS, Kim MJ, Kim JH, et al. Comparison of multi-echo and single-echo gradient-recalled echo sequences for SPIO-enhanced liver MRI at 3 T. Clin Radiol. 2010;65(11):916-923. Excluded: Wrong population. [pmid: 20933647].
Chou CT, Chen RC, Chen WT, Lii JM. Detection of hepatocellular carcinoma by ferucarbotran-enhanced magnetic resonance imaging: the efficacy of accumulation phase fat-suppressed T1-weighted imaging. Clin Radiol. 2009;64(1):22-29. Excluded: Wrong intervention. [pmid: 19070694].
Chou CT, Chen RC, Chen WT, Lii JM. Percentage of signal intensity loss for characterisation of focal liver lesions in patients with chronic liver disease using ferucarbotran-enhanced MRI. Br J Radiol. 2010;83(996):1023-1028. Excluded: Wrong population. [pmid: 20413445].
Chung YE, Kim M-J, Park M-S, et al. The impact of CT follow-up interval on stages of hepatocellular carcinomas detected during the surveillance of patients with liver cirrhosis. AJR Am J Roentgenol. 2012;199(4):816-821. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22997373].
Cieszanowski A, Anysz-Grodzicka A, Szeszkowski W, et al. Characterization of focal liver lesions using quantitative techniques: comparison of apparent diffusion coefficient values and T2 relaxation times. Eur Radiol. 2012;22(11):2514-2524. Excluded: Wrong population. [pmid: 22699872].
Coates GG, Borrello JA, McFarland EG, Mirowitz SA, Brown JJ. Hepatic T2-weighted MRI: a prospective comparison of sequences, including breath-hold, half-Fourier turbo spin echo (HASTE). J Magn Reson Imaging. 1998;8(3):642-649. Excluded: Wrong population. [pmid: 9626880].
Colagrande S, La Villa G, Bartolucci M, Lanini F, Barletta G, Villari N. Spiral computed tomography versus ultrasound in the follow-up of cirrhotic patients previously treated for hepatocellular carcinoma: a prospective study. J Hepatol. 2003;39(1):93-98. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12821049].
Colli A, Fraquelli M, Casazza G, et al. Accuracy of ultrasonography, spiral CT, magnetic resonance, and alpha-fetoprotein in diagnosing hepatocellular carcinoma: a systematic review. Am J Gastroenterol. 2006;101(3):513-523. Excluded: Systematic review; studies checked for inclusion. [pmid: 16542288].
Cruite I, Tang A, Sirlin CB. Imaging-based diagnostic systems for hepatocellular carcinoma. [Review]. AJR Am J Roentgenol. 2013;201(1):41-55. Excluded: Wrong publication type. [pmid: 23789657].
Davarpanah AH, Weinreb JC. The role of imaging in hepatocellular carcinoma: the present and future. J Clin Gastroenterol. 2013;47(10). Excluded: Wrong publication type.
De Cecco CN, Buffa V, Fedeli S, et al. Dual energy CT (DECT) of the liver: conventional versus virtual unenhanced images. Eur Radiol. 2010;20(12):2870-2875. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20623126].
Di Tommaso L, Sangiovanni A, Borzio M, Park YN, Farinati F, Roncalli M. Advanced precancerous lesions in the liver. [Review]. Baillieres Best Pract Res Clin Gastroenterol. 2013;27(2):269-284. Excluded: Wrong publication type.
Dietrich CF, Ignee A, Trojan J, Fellbaum C, Schuessler G. Improved characterisation of histologically proven liver tumours by contrast enhanced ultrasonography during the portal venous and specific late phase of SHU 508A. Gut. 2004;53(3):401-405. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 14960524].
D’Onofrio M, Faccioli N, Zamboni G, et al. Focal liver lesions in cirrhosis: value of contrast-enhanced ultrasonography compared with Doppler ultrasound and alpha-fetoprotein levels. Radiol Med (Torino). 2008;113(7):978-991. Excluded: Wrong population. [pmid: 18779929].
D’Onofrio M, Martone E, Faccioli N, Zamboni G, Malago R, Mucelli RP. Focal liver lesions: sinusoidal phase of CEUS. Abdom Imaging. 2006/06/28 ed. 2006;31:529-536. Excluded: Wrong population. [pmid: 16802201].
Dumitrescu CI, Gheonea IA, Sǎndulescu L, Surlin V, Sǎftoiu A, Dumitrescu D. Contrast enhanced ultrasound and magnetic resonance imaging in hepatocellular carcinoma diagnosis. Med. 2013;15(4):261-267. Excluded: Inadequate reference standard.
Earls JP. Comparison studies of CT and MRI in patients with hepatic metastases. Oncology (Williston). 2000;14(6 Suppl 3):21-28. Excluded: Background. [pmid: 10887648].
Earls JP, Rofsky NM, DeCorato DR, Krinsky GA, Weinreb JC. Echo-train STIR MRI of the liver: comparison of breath-hold and non-breath-hold imaging strategies. J Magn Reson Imaging. 1999;9(1):87-92. Excluded: Wrong population. [pmid: 10030655].
Efremidis SC, Hytiroglou P, Matsui O. Enhancement patterns and signal-intensity characteristics of small hepatocellular carcinoma in cirrhosis: pathologic basis and diagnostic challenges. Eur Radiol. 2007;17(11):2969-2982. Excluded: Background. [pmid: 17618439].
Efremidis SC, Vougiouklis N, Zafiriadou E, et al. Pathways of lymph node involvement in upper abdominal malignancies: evaluation with high-resolution CT. Eur Radiol. 1999;9(5):868-874. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10369981].
Eisele RM, Schumacher G, Lopez-Hanninen E, Neuhaus P. Role of B-mode ultrasound screening in detection of local tumor recurrence in the first year after radiofrequency ablation in the liver. Cancer Detect Prev. 2007;31(4):316-322. Excluded: Inadequate reference standard. [pmid: 17935909].
el-Desouki M, Mohamadiyeh M, al-Rashed R, Othman S, al-Mofleh I. Features of hepatic cavernous hemangioma on planar and SPECT Tc-99m-labeled red blood cell scintigraphy. Clin Nucl Med. 1999;24(8):583-589. Excluded: Wrong population. [pmid: 10439179].
El-Serag HB, Marrero JA, Rudolph L, Reddy KR. Diagnosis and treatment of hepatocellular carcinoma. Gastroenterology. 2008;134(6):1752-1763. Excluded: Background. [pmid: 18471552].
Erturk SM, Ichikawa T, Sano K, Motosugi U, Sou H, Araki T. Diffusion-weighted magnetic resonance imaging for characterization of focal liver masses: impact of parallel imaging (SENSE) and b value. J Comput Assist Tomogr. 2008;32(6):865-871. Excluded: Wrong population. [pmid: 19204445].
Ewertsen C, Henriksen BM, Torp-Pedersen S, Bachmann Nielsen M. Characterization by biopsy or CEUS of liver lesions guided by image fusion between ultrasonography and CT, PET/CT or MRI. Ultraschall Med. 2011;32(2):191-197. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21225564].
Fasani P, Sangiovanni A, De Fazio C, et al. High prevalence of multinodular hepatocellular carcinoma in patients with cirrhosis attributable to multiple risk factors. Hepatology. 1999;29(6):1704-1707. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10347111].
Federle M, Chezmar J, Rubin DL, et al. Efficacy and safety of mangafodipir trisodium (MnDPDP) injection for hepatic MRI in adults: results of the U.S. Multicenter phase III clinical trials. Efficacy of early imaging. J Magn Reson Imaging. 2000;12(5):689-701. Excluded: Wrong intervention. [pmid: 11050638].
Fedorov VD, Karmazanovskii GG, Kubyshkin VA, et al. Spiral computer tomography in diagnosis of hepatic diseases. Khirurgiia (Mosk). 1998;(5):9-14. Excluded: Background. [pmid: 9642951].
Fenlon HM, Tello R, deCarvalho VL, Yucel EK. Signal characteristics of focal liver lesions on double echo T2-weighted conventional spin echo MRI: observer performance versus quantitative measurements of T2 relaxation times. J Comput Assist Tomogr. 2000;24(2):204-211. Excluded: Wrong population. [pmid: 10752879].
Foroutani A, Garland AM, Berber E, et al. Laparoscopic ultrasound vs triphasic computed tomography for detecting liver tumors. Arch Surg. 2000;135(8):933-938. Excluded: Wrong population. [pmid: 10922255].
Friedrich-Rust M, Klopffleisch T, Nierhoff J, et al. Contrast-Enhanced Ultrasound for the differentiation of benign and malignant focal liver lesions: a meta-analysis. [Review]. Liver Int. 2013;33(5):739-755. Excluded: Systematic review; studies checked for inclusion. [pmid: 23432804].
Fu G-L, Du Y, Zee C-S, et al. Gadobenate dimeglumine-enhanced liver magnetic resonance imaging: value of hepatobiliary phase for the detection of focal liver lesions. J Comput Assist Tomogr. 2012;36(1):14-19. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22261765].
Fujinaga Y, Kadoya M, Kozaka K, et al. Prediction of macroscopic findings of hepatocellular carcinoma on hepatobiliary phase of gadolinium-ethoxybenzyl-diethylenetriamine pentaacetic acid-enhanced magnetic resonance imaging: Correlation with pathology. Hepatol Res. 2013;43(5):488-494. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22978417].
Fujita T, Ito K, Honjo K, Okazaki H, Matsumoto T, Matsunaga N. Detection of hepatocellular carcinoma: comparison of T2-weighted breath-hold fast spin-echo sequences and high-resolution dynamic MR imaging with a phased-array body coil. J Magn Reson Imaging. 1999;9(2):274-279. Excluded: Inadequate reference standard. [pmid: 10077024].
Fukuda H, Ito R, Ohto M, et al. US-CT 3D dual imaging by mutual display of the same sections for depicting minor changes in hepatocellular carcinoma. Eur J Radiol. 2012;81(9):2014-2019. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21676568].
Fukukura Y, Kamiyama T, Takumi K, Shindo T, Higashi R, Nakajo M. Comparison of ferucarbotran-enhanced fluid-attenuated inversion-recovery echo-planar, T2-weighted turbo spin-echo, T2*-weighted gradient-echo, and diffusion-weighted echo-planar imaging for detection of malignant liver lesions. J Magn Reson Imaging. 2010;31(3):607-616. Excluded: Wrong population. [pmid: 20187203].
Fung KTT, Li FTW, Raimondo ML, et al. Systematic review of radiological imaging for hepatocellular carcinoma in cirrhotic patients. Br J Radiol. 2004;77(920):633-640. Excluded: Background. [pmid: 15326039].
Furlan A, Marin D, Cabassa P, et al. Enhancement pattern of small hepatocellular carcinoma (HCC) at contrast-enhanced US (CEUS), MDCT, and MRI: intermodality agreement and comparison of diagnostic sensitivity between 2005 and 2010 American Association for the Study of Liver Diseases (AASLD) guidelines. Eur J Radiol. 2012;81(9):2099-2105. Excluded: Inadequate reference standard. [pmid: 21906896].
Furuichi K, Furukawa A, Takahashi M, Murata K. Role of combined CT hepatic angiography and CT during arterial portography in the management of patients with hepatocellular carcinomas and liver metastases. Hepatol Res. 2004;28(4):191-197. Excluded: Wrong intervention. [pmid: 15040959].
Gabata T, Matsui O, Kadoya M, et al. Delayed MR imaging of the liver: correlation of delayed enhancement of hepatic tumors and pathologic appearance. Abdom Imaging. 1998;23(3):309-313. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9569304].
Gehl HB, Bourne M, Grazioli L, Moller A, Lodemann KP. Off-site evaluation of liver lesion detection by Gd-BOPTA-enhanced MR imaging. Eur Radiol. 2001;11(2):187-192. Excluded: Wrong population. [pmid: 11218012].
Geng L, Lin C, Huang B, et al. Solitary necrotic nodule of the liver: MR findings in 33 pathologically proved lesions. Eur J Radiol. 2012;81(4):623-629. Excluded: Wrong population. [pmid: 21354738].
Goetti R, Reiner CS, Knuth A, et al. Quantitative perfusion analysis of malignant liver tumors: dynamic computed tomography and contrast-enhanced ultrasound. Invest Radiol. 2012;47(1):18-24. Excluded: Wrong population. [pmid: 21788906].
Golfieri R, Grazioli L, Orlando E, et al. Which is the best MRI marker of malignancy for atypical cirrhotic nodules: hypointensity in hepatobiliary phase alone or combined with other features? Classification after Gd-EOB-DTPA administration. J Magn Reson Imaging. 2012;36(3):648-657. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22592930].
Golfieri R, Renzulli M, Lucidi V, Corcioni B, Trevisani F, Bolondi L. Contribution of the hepatobiliary phase of Gd-EOB-DTPA-enhanced MRI to Dynamic MRI in the detection of hypovascular small (<= 2 cm) HCC in cirrhosis. Eur Radiol. 2011;21(6):1233-1242. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21293864].
Goshima S, Kanematsu M, Kondo H, et al. Diffusion-weighted imaging of the liver: optimizing b value for the detection and characterization of benign and malignant hepatic lesions. J Magn Reson Imaging. 2008;28(3):691-697. Excluded: Wrong population. [pmid: 18777553].
Gourtsoyianni S, Papanikolaou N, Yarmenitis S, Maris T, Karantanas A, Gourtsoyiannis N. Respiratory gated diffusion-weighted imaging of the liver: value of apparent diffusion coefficient measurements in the differentiation between most commonly encountered benign and malignant focal liver lesions. Eur Radiol. 2008;18(3):486-492. Excluded: Wrong population. [pmid: 17994317].
Granito A, Galassi M, Piscaglia F, et al. Impact of gadoxetic acid (Gd-EOB-DTPA)-enhanced magnetic resonance on the non-invasive diagnosis of small hepatocellular carcinoma: a prospective study. Aliment Pharmacol Ther. 2013;37(3):355-363. Excluded: Inadequate reference standard. [pmid: 23199022].
Grazioli L, Morana G, Kirchin MA, Schneider G. Accurate differentiation of focal nodular hyperplasia from hepatic adenoma at gadobenate dimeglumine-enhanced MR imaging: prospective study. Radiology. 2005;236(1):166-177. Excluded: Wrong population. [pmid: 15955857].
Grazioli L, Olivetti L, Fugazzola C, et al. The pseudocapsule in hepatocellular carcinoma: correlation between dynamic MR imaging and pathology. Eur Radiol. 1999;9(1):62-67. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9933382].
Guang Y, Xie L, Ding H, Cai A, Huang Y. Diagnosis value of focal liver lesions with SonoVue-enhanced ultrasound compared with contrast-enhanced computed tomography and contrast-enhanced MRI: a meta-analysis. J Cancer Res Clin Oncol. 2011;137(11):1595-1605. Excluded: Systematic review; studies checked for inclusion. [pmid: 21850382].
Guimaraes CM, Correia MM, Baldisserotto M, de Queiroz Aires EP, Coelho JF. Intraoperative ultrasonography of the liver in patients with abdominal tumors: a new approach. J Ultrasound Med. 2004;23(12):1549-1555. Excluded: Wrong population. [pmid: 15557298].
Guiu B, Loffroy R, Ben Salem D, et al. Combined SPIO-gadolinium magnetic resonance imaging in cirrhotic patients: negative predictive value and role in screening for hepatocellular carcinoma. Abdom Imaging. 2008;33(5):520-528. Excluded: Wrong intervention. [pmid: 17912584].
Hafeez S, Alam MS, Sajjad Z, Khan ZA, Akhter W, Mubarak F. Triphasic computed tomography (CT) scan in focal tumoral liver lesions. JPMA J Pak Med Assoc. 2011;61(6):571-575. Excluded: Wrong population. [pmid: 22204213].
Haider MA, Amitai MM, Rappaport DC, et al. Multi-detector row helical CT in preoperative assessment of small (< or = 1.5 cm) liver metastases: is thinner collimation better?. Radiology. 2002;225(1):137-142. Excluded: Wrong population. [pmid: 12354997].
Hammerstingl R, Adam G, Ayuso J-R, et al. Comparison of 1.0 M gadobutrol and 0.5 M gadopentetate dimeglumine-enhanced magnetic resonance imaging in five hundred seventy-two patients with known or suspected liver lesions: results of a multicenter, double-blind, interindividual, randomized clinical phase-III trial. Invest Radiol. 2009;44(3):168-176. Excluded: Wrong population. [pmid: 19169143].
Hammerstingl R, Huppertz A, Breuer J, et al. Diagnostic efficacy of gadoxetic acid (Primovist)-enhanced MRI and spiral CT for a therapeutic strategy: comparison with intraoperative and histopathologic findings in focal liver lesions. Eur Radiol. 2008;18(3):457-467. Excluded: Wrong population. [pmid: 18058107].
Hann LE, Schwartz LH, Panicek DM, Bach AM, Fong Y, Blumgart LH. Tumor involvement in hepatic veins: comparison of MR imaging and US for preoperative assessment. Radiology. 1998;206(3):651-656. Excluded: Wrong population. [pmid: 9494482].
Hanna RF, Kased N, Kwan SW, et al. Double-contrast MRI for accurate staging of hepatocellular carcinoma in patients with cirrhosis. AJR Am J Roentgenol. 2008;190(1):47-57. Excluded: Wrong intervention. [pmid: 18094293].
Hara K, Numata K, FJSUM, et al. Diagnosis of advanced hepatocellular carcinoma using contrast-enhanced harmonic gray-scale imaging with enhancement agents (Levovist): Correlation with helical CT and US angiography. Journal of Medical Ultrasonics. 2001;28(AUTUMN):127-133. Excluded: Wrong comparator/Wrong reference standard.
Haradome H, Grazioli L, Morone M, et al. T2-weighted and diffusion-weighted MRI for discriminating benign from malignant focal liver lesions: diagnostic abilities of single versus combined interpretations. J Magn Reson Imaging. 2012;35(6):1388-1396. Excluded: Wrong population. [pmid: 22246647].
Hardie AD, Romano PB. The use of T2*-weighted multi-echo GRE imaging as a novel method to diagnose hepatocellular carcinoma compared with gadolinium-enhanced MRI: a feasibility study. Magn Reson Imaging. 2010;28(2):281-285. Excluded: Inadequate reference standard. [pmid: 20071122].
Harms J, Feussner H, Baumgartner M, Schneider A, Donhauser M, Wessels G. Three-dimensional navigated laparoscopic ultrasonography: first experiences with a new minimally invasive diagnostic device. Surg Endosc. 2001;15(12):1459-1462. Excluded: Background. [pmid: 11965466].
Hatanaka K, Chung H, Kudo M, et al. Usefulness of the post-vascular phase of contrast-enhanced ultrasonography with sonazoid in the evaluation of gross types of hepatocellular carcinoma. Oncology. 2010;78(SUPPL 1):53-59. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20616585].
Hatanaka K, Kudo M, Minami Y, Maekawa K. Sonazoid-enhanced ultrasonography for diagnosis of hepatic malignancies: comparison with contrast-enhanced CT. Oncology. 2008;75(Suppl 1):42-47. Excluded: Wrong population. [pmid: 19092271].
Hayashi M, Matsui O, Ueda K, Kawamori Y, Gabata T, Kadoya M. Progression to hypervascular hepatocellular carcinoma: Correlation with intranodular blood supply evaluated with CT during intraarterial injection of contrast material. Radiology. 2002;225(1):143-149. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12354998].
Hayashida M, Ito K, Fujita T, et al. Small hepatocellular carcinomas in cirrhosis: differences in contrast enhancement effects between helical CT and MR imaging during multiphasic dynamic imaging. Magn Reson Imaging. 2008;26(1):65-71. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17566685].
Helmberger TK, Laubenberger J, Rummeny E, et al. MRI characteristics in focal hepatic disease before and after administration of MnDPDP: discriminant analysis as a diagnostic tool. Eur Radiol. 2002;12(1):62-70. Excluded: Wrong intervention. [pmid: 11868075].
Hennedige T, Venkatesh SK. Imaging of hepatocellular carcinoma: diagnosis, staging and treatment monitoring. [Review]. Cancer Imaging. 2013;12:530-547. Excluded: Background. [pmid: 23400006].
Henrion J, Libon E, De Maeght S, et al. Surveillance for hepatocellular carcinoma: compliance and results according to the aetiology of cirrhosis in a cohort of 141 patients. Acta Gastroenterol Belg. 2000;63(1):5-9. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10907311].
Herman P, Pugliese V, Machado MA, et al. Hepatic adenoma and focal nodular hyperplasia: differential diagnosis and treatment. World J Surg. 2000;24(3):372-376. Excluded: Wrong population. [pmid: 10658075].
Higashihara H, Murakami T, Kim T, et al. Differential diagnosis between metastatic tumors and nonsolid benign lesions of the liver using ferucarbotran-enhanced MR imaging. Eur J Radiol. 2010;73(1):125-130. Excluded: Wrong population. [pmid: 19019608].
Hiraoka A, Hirooka M, Ochi H, et al. Importance of screening for synchronous malignant neoplasms in patients with hepatocellular carcinoma: Impact of FDG PET/CT. Liver Int. 2013;33(7):1085-1091. Excluded: Wrong population. [pmid: 23601196].
Hohmann J, Skrok J, Basilico R, et al. Characterisation of focal liver lesions with unenhanced and contrast enhanced low MI real time ultrasound: on-site unblinded versus off-site blinded reading. Eur J Radiol. 2012;81(3):e317-324. Excluded: Wrong population. [pmid: 22100374].
Holalkere N-S, Sahani DV, Blake MA, Halpern EF, Hahn PF, Mueller PR. Characterization of small liver lesions: Added role of MR after MDCT. J Comput Assist Tomogr. 2006;30(4):591-596. Excluded: Wrong population. [pmid: 16845289].
Holzapfel K, Eiber MJ, Fingerle AA, Bruegel M, Rummeny EJ, Gaa J. Detection, classification, and characterization of focal liver lesions: Value of diffusion-weighted MR imaging, gadoxetic acid-enhanced MR imaging and the combination of both methods. Abdom Imaging. 2012;37(1):74-82. Excluded: Wrong population. [pmid: 21597893].
Honda T, Kumada T, Kiriyama S, et al. Comparison of contrast-enhanced harmonic ultrasonography and power Doppler ultrasonography for depicting vascularity of hepatocellular carcinoma identified by angiography-assisted CT. Hepatol Res. 2003;27(4):314-321. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Hori M, Murakami T, Kim T, et al. Sensitivity of double-phase helical CT during arterial portography for detection of hypervascular hepatocellular carcinoma. J Comput Assist Tomogr. 1998;22(6):861-867. Excluded: Wrong intervention. [pmid: 9843222].
Huang JS, Pan HB, Chou CP, et al. Optimizing scanning phases in detecting small (<2 cm) hepatocellular carcinoma: Whole-liver dynamic study with multidetector row CT. J Comput Assist Tomogr. 2008;32(3):341-346. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18520534].
Huang Y-L, Chen J-H, Shen W-C. Diagnosis of hepatic tumors with texture analysis in nonenhanced computed tomography images. Acad Radiol. 2006;13(6):713-720. Excluded: Wrong population. [pmid: 16679273].
Hussain SM, van den Bos IC, Dwarkasing RS, Kuiper JW, den Hollander J. Hepatocellular adenoma: Findings at state-of-the-art magnetic resonance imaging, ultrasound, computed tomography and pathologic analysis. Eur Radiol. 2006;16(9):1873-1886. Excluded: Background. [pmid: 16708218].
Hustinx R, Paulus P, Jacquet N, Jerusalem G, Bury T, Rigo P. Clinical evaluation of whole-body 18F-fluorodeoxyglucose positron emission tomography in the detection of liver metastases. Ann Oncol. 1998;9(4):397-401. Excluded: Wrong population. [pmid: 9636830].
Hwang J, Kim SH, Kim YS, et al. Gadoxetic acid-enhanced MRI versus multiphase multidetector row computed tomography for evaluating the viable tumor of hepatocellular carcinomas treated with image-guided tumor therapy. J Magn Reson Imaging. 2010;32(3):629-638. Excluded: Wrong population. [pmid: 20815061].
Iannaccone R, Piacentini F, Murakami T, et al. Hepatocellular carcinoma in patients with nonalcoholic fatty liver disease: Helical CT and MR imaging findings with clinical-pathologic comparison. Radiology. 2007;243(2):422-430. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17356175].
Iannicelli E, Di Pietropaolo M, Marignani M, et al. Gadoxetic acid-enhanced MRI for hepatocellular carcinoma and hypointense nodule observed in the hepatobiliary phase. Radiol Med (Torino). 2013:1-10. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Iavarone M, Manini MA, Sangiovanni A, et al. Contrast-enhanced computed tomography and ultrasound-guided liver biopsy to diagnose dysplastic liver nodules in cirrhosis. Dig Liver Dis. 2013;45(1):43-49. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23022425].
Ichikawa T, Federle MP, Grazioli L, Nalesnik M. Hepatocellular adenoma: Multiphasic CT and histopathologic findings in 25 patients. Radiology. 2000;214(3):861-868. Excluded: Wrong population. [pmid: 10715059].
Ichikawa T, Haradome H, Hachiya J, Nitatori T, Araki T. Diffusion-weighted MR imaging with a single-shot echoplanar sequence: detection and characterization of focal hepatic lesions. AJR Am J Roentgenol. 1998;170(2):397-402. Excluded: Wrong population. [pmid: 9456953].
Ichikawa T, Motosugi U, Morisaka H, Sano K, Ali M, Araki T. Volumetric low-tube-voltage CT imaging for evaluating hypervascular hepatocellular carcinoma; Effects on radiation exposure, image quality, and diagnostic performance. Jpn J Radiol. 2013;31(8):521-529. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23793776].
Ichikawa T, Okada M, Kondo H, et al. Recommended iodine dose for multiphasic contrast-enhanced mutidetector-row computed tomography imaging of liver for assessing hypervascular hepatocellular carcinoma: multicenter prospective study in 77 general hospitals in Japan. Acad Radiol. 2013;20(9):1130-1136. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23931427].
Imai Y, Murakami T, Hori M, et al. Hypervascular hepatocellular carcinoma: Combined dynamic MDCT and SPIO-enhanced MRI versus combined CTHA and CTAP. Hepatol Res. 2008;38(2):147-158. Excluded: Wrong intervention. [pmid: 17645518].
Inoue E, Fujita M, Hosomi N, et al. Double phase CT arteriography of the whole liver in the evaluation of hepatic tumors. J Comput Assist Tomogr. 1998;22(1):64-68. Excluded: Wrong intervention. [pmid: 9448763].
Ishigami K, Tajima T, Fujita N, et al. Hepatocellular carcinoma with marginal superparamagnetic iron oxide uptake on T2*-weighted magnetic resonance imaging: histopathologic correlation. Eur J Radiol. 2011;80(3):e293-298. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21288675].
Ishigami K, Yoshimitsu K, Nishihara Y, et al. Hepatocellular carcinoma with a pseudocapsule on gadolinium-enhanced MR images: correlation with histopathologic findings. Radiology. 2009;250(2):435-443. Excluded: Wrong population. [pmid: 19095782].
Ishikawa M, Yogita S, Miyake H, et al. Differential diagnosis of small hepatocellular carcinoma and borderline lesions and therapeutic strategy. Hepatogastroenterology. 2002;49(48):1591-1596. Excluded: Imaging before 1995. [pmid: 12397743].
Itoh S, Ikeda M, Achiwa M, Satake H, Iwano S, Ishigaki T. Late-arterial and portal-venous phase imaging of the liver with a multislice CT scanner in patients without circulatory disturbances: automatic bolus tracking or empirical scan delay?. Eur Radiol. 2004;14(9):1665-1673. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15067427].
Iwamoto S, Sanefuji H, Okuda K. Computed tomography angiographic findings in hepatocellular carcinoma less than 2 cm detected during follow-up in 29 patients. J Gastroenterol Hepatol. 2003;18(9):1076-1080. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12911666].
Iwata Y, Shiomi S, Sasaki N, et al. Clinical usefulness of positron emission tomography with fluorine-18-fluorodeoxyglucose in the diagnosis of liver tumors. Ann Nucl Med. 2000;14(2):121-126. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10830530].
Iwazawa J, Nishida N, Yamamoto A, et al. Detection of portal perfusion abnormalities: comparison of 3 ferucarbotran-enhanced magnetic resonance imaging sequences. J Comput Assist Tomogr. 2006;30(2):165-172. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16628027].
Izumi N. Diagnostic and treatment algorithm of the Japanese society of hepatology: a consensus-based practice guideline. Oncology. 2010;78(Suppl 1):78-86. Excluded: Background. [pmid: 20616588].
Jadvar H. Hepatocellular carcinoma and gastroenteropancreatic neuroendocrine tumors: Potential role of other positron emission tomography radiotracers. Semin Nucl Med. 2012;42(4):247-254. Excluded: Background. [pmid: 22681673].
Jakab Z. Investigation of the blood supply of liver tumors--ultrasonography with contrast agents. Orv Hetil. 2004;145(7 Suppl 1):378-381. Excluded: Background. [pmid: 15049055].
Jeon UB, Lee JW, Choo KS, et al. Iodized oil uptake assessment with cone-beam CT in chemoembolization of small hepatocellular carcinomas. World J Gastroenterol. 2009;15(46):5833-5837. Excluded: Wrong population. [pmid: 19998505].
Jeong HT, Kim MJ, Kim YE, Park YN, Choi GH, Choi JS. MRI features of hepatocellular carcinoma expressing progenitor cell markers. Liver Int. 2012;32(3):430-440. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22097930].
Jeong YY, Mitchell DG, Kamishima T. Small (<20 mm) enhancing hepatic nodules seen on arterial phase MR imaging of the cirrhotic liver: clinical implications. AJR Am J Roentgenol. 2002;178(6):1327-1334. Excluded: Wrong intervention. [pmid: 12034592].
Jeong YY, Yim NY, Kang HK. Hepatocellular carcinoma in the cirrhotic liver with helical CT and MRI: Imaging spectrum and pitfalls of cirrhosis-related nodules. AJR Am J Roentgenol. 2005;185(4):1024-1032. Excluded: Background. [pmid: 16177427].
Jin Y-J, Lee HC, Lee D, et al. Role of the routine use of chest computed tomography and bone scan in staging workup of hepatocellular carcinoma. J Hepatol. 2012;56(6):1324-1329. Excluded: Wrong comparator/Wrong reference standard. [pmid: 22322236].
Joo I, Kim SH, Lee JY, Lee JM, Han JK, Choi BI. Comparison of semiautomated and manual measurements for simulated hypo- and hyper-attenuating hepatic tumors on MDCT: effect of slice thickness and reconstruction increment on their accuracy. Acad Radiol. 2011;18(5):626-633. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21393028].
Jou JH, Chen P-H, Jazwinski A, Bouneva I, Smith AD, Muir AJ. Rates of surveillance and management of hepatocellular carcinoma in patients evaluated at a liver transplant center. Dig Dis Sci. 2010;55(12):3591-3596. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20683659].
Jung G, Breuer J, Poll LW, et al. Imaging characteristics of hepatocellular carcinoma using the hepatobiliary contrast agent Gd-EOB-DTPA. Acta Radiol. 2006;47(1):15-23. Excluded: Wrong intervention. [pmid: 16498928].
Junqiang L, Yinzhong W, Li Z, et al. Gadoxetic acid disodium (Gd-EOB-DTPA)-enhanced magnetic resonance imaging for the detection of hepatocellular carcinoma: A meta-analysis. J Magn Reson Imaging. 2013. Excluded: Systematic review; studies checked for inclusion.
Kaihara S, Kiuchi T, Ueda M, et al. Living-donor liver transplantation for hepatocellular carcinoma. Transplantation. 2003;75(3 Suppl):S37-40. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12589138].
Kakeda S, Korogi Y, Ohnari N, et al. Usefulness of cone-beam volume CT with flat panel detectors in conjunction with catheter angiography for transcatheter arterial embolization. J Vasc Interv Radiol. 2007;18(12):1508-1516. Excluded: Wrong intervention. [pmid: 18057285].
Kamel IR, Choti MA, Horton KM, et al. Surgically staged focal liver lesions: accuracy and reproducibility of dual-phase helical CT for detection and characterization. Radiology. 2003;227(3):752-757. Excluded: Wrong population. [pmid: 12773679].
Kamel IR, Liapi E, Fishman EK. Multidetector CT of hepatocellular carcinoma. Baillieres Best Pract Res Clin Gastroenterol. 2005;19(1):63-89. Excluded: Background. [pmid: 15757805].
Kan M, Hiraoka A, Uehara T, et al. Evaluation of contrast-enhanced ultrasonography using perfluorobutane (sonazoid®) in patients with small hepatocellular carcinoma: Comparison with dynamic computed tomography. Oncol Lett. 2010;1(3):485-488. Excluded: Inadequate reference standard. [pmid: 22966329].
Kanata N, Yoshikawa T, Ohno Y, et al. HCC-to-liver contrast on arterial-dominant phase images of EOB-enhanced MRI: Comparison with dynamic CT. Magn Reson Imaging. 2013;31(1):17-22. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22898685].
Kane SV, Ganger DR. Management of hepatocellular carcinoma: staging and treatment. Am J Ther. 1997;4(1):39-45. Excluded: Background. [pmid: 10423590].
Kanematsu M, Goshima S, Kondo H, et al. Optimizing scan delays of fixed duration contrast injection in contrast-enhanced biphasic multidetector-row CT for the liver and the detection of hypervascular hepatocellular carcinoma. J Comput Assist Tomogr. 2005;29(2):195-201. Excluded: Background. [pmid: 15772536].
Kanematsu M, Hoshi H, Murakami T, et al. Fat-suppressed T2-weighted MR imaging of hepatocellular carcinoma and metastases: comparison of conventional spin-echo, fast spin-echo, and echoplanar pulse sequences. J Magn Reson Imaging. 1999;10(1):25-32. Excluded: Wrong population. [pmid: 10398974].
Kanematsu M, Hoshi H, Murakami T, et al. Detection of hepatocellular carcinoma: comparison of low- and high-spatial-resolution dynamic MR images. AJR Am J Roentgenol. 1999;173(5):1207-1212. Excluded: Background. [pmid: 10541090].
Kanematsu M, Itoh K, Matsuo M, et al. Malignant hepatic tumor detection with ferumoxides-enhanced MR imaging with a 1.5-T system: comparison of four imaging pulse sequences. J Magn Reson Imaging. 2001;13(2):249-257. Excluded: Wrong population. [pmid: 11169831].
Karadeniz-Bilgili MY, Braga L, Birchard KR, et al. Hepatocellular carcinoma missed on gadolinium enhanced MR imaging, discovered in liver explants: retrospective evaluation. J Magn Reson Imaging. 2006;23(2):210-215. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16416439].
Karahan OI, Yikilmaz A, Artis T, Canoz O, Coskun A, Torun E. Contrast-enhanced dynamic magnetic resonance imaging findings of hepatocellular carcinoma and their correlation with histopathologic findings. Eur J Radiol. 2006;57(3):445-452. Excluded: Background. [pmid: 16337762].
Karahan OI, Yikilmaz A, Isin S, Orhan S. Characterization of hepatocellular carcinomas with triphasic CT and correlation with histopathologic findings. Acta Radiol. 2003;44(6):566-571. Excluded: Background. [pmid: 14616198].
Kaseb AO, Abaza YM, Roses RE. Multidisciplinary management of hepatocellular carcinoma. Recent Results Cancer Res. 2013;190:247-259. Excluded: Background. [pmid: 22941025].
Kashiwagi T. FDG-PET and hepatocellular carcinoma. J Gastroenterol. 2004;39(10):1017-1018. Excluded: Background. [pmid: 15549460].
Katyal S, Oliver JH 3rd, Peterson MS, Ferris JV, Carr BS, Baron RL. Extrahepatic metastases of hepatocellular carcinoma. Radiology. 2000;216(3):698-703. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10966697].
Kawada T. Receiver operating characteristic curve analysis, sensitivity comparison and individual difference. Clin Radiol. 2012;67(9):940. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22608247].
Kawamura E, Habu D, Ohfuji S, et al. Clinical role of FDG-PET for HCC: relationship of glucose metabolic indicator to Japan Integrated Staging (JIS) score. Hepatogastroenterology. 2008;55(82–83):582-586. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18613412].
Kawamura Y, Ikeda K, Seko Y, et al. Heterogeneous type 4 enhancement of hepatocellular carcinoma on dynamic CT is associated with tumor recurrence after radiofrequency ablation. AJR Am J Roentgenol. 2011;197(4):W665-673. Excluded: Background. [pmid: 21940538].
Kchaou-Ouakaa A, Belhadjbrik N, Elloumi H, et al. Surveillance for hepatocellular carcinoma: does it work?. Tunis Med. 2007;85(10):866-870. Excluded: Background. [pmid: 18236810].
Ke S, Zhang F, Wang W, et al. Multiple target-specific molecular imaging agents detect liver cancer in a preclinical model. Curr Mol Med. 2012;12(8):944-951. Excluded: Background. [pmid: 22779431].
Kehagias D, Metafa A, Hatziioannou A, et al. Comparison of CT, MRI and CT during arterial portography in the detection of malignant hepatic lesions. Hepatogastroenterology. 2000;47(35):1399-1403. Excluded: Wrong population. [pmid: 11100361].
Khalili K, Kim TK, Jang H-J, Yazdi LK, Guindi M, Sherman M. Indeterminate 1–2-cm nodules found on hepatocellular carcinoma surveillance: biopsy for all, some, or none?. Hepatology. 2011;54(6):2048-2054. Excluded: Background. [pmid: 22057624].
Khan AS, Hussain HK, Johnson TD, Weadock WJ, Pelletier SJ, Marrero JA. Value of delayed hypointensity and delayed enhancing rim in magnetic resonance imaging diagnosis of small hepatocellular carcinoma in the cirrhotic liver. J Magn Reson Imaging. 2010;32(2):360-366. Excluded: Background. [pmid: 20677263].
Kilickesmez O, Bayramoglu S, Inci E, Cimilli T. Value of apparent diffusion coefficient measurement for discrimination of focal benign and malignant hepatic masses. J Med Imaging Radiat Oncol. 2009;53(1):50-55. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19453528].
Kim AY, Lee MW, Rhim H, et al. Pretreatment evaluation with contrast-enhanced ultrasonography for percutaneous radiofrequency ablation of hepatocellular carcinomas with poor conspicuity on conventional ultrasonography. Korean J Radiol. 2013;14(5):754-763. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 24043968].
Kim BK, Han KH, Park YN, et al. Prediction of microvascular invasion before curative resection of hepatocellular carcinoma. J Surg Oncol. 2008;97(3):246-252. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18095300].
Kim BK, Kang WJ, Kim JK, et al. 18F-fluorodeoxyglucose uptake on positron emission tomography as a prognostic predictor in locally advanced hepatocellular carcinoma. Cancer. 2011;117(20):4779-4787. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21469082].
Kim CK, Lim JH, Lee WJ. Detection of hepatocellular carcinoma and dysplastic nodule in cirrhotic liver: Accuracy of ultrasonography. Ultrasound Med Biol. 2000;26(SUPPL 2). Excluded: Wrong publication type.
Kim H, Park M-S, Choi JY, et al. Can microvessel invasion of hepatocellular carcinoma be predicted by pre-operative MRI?. Eur Radiol. 2009;19(7):1744-1751. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19247666].
Kim H-C, Kim AY, Han JK, et al. Hepatic arterial and portal venous phase helical CT in patients treated with transcatheter arterial chemoembolization for hepatocellular carcinoma: added value of unenhanced images. Radiology. 2002;225(3):773-780. Excluded: Wrong population. [pmid: 12461260].
Kim HJ, Kim TK, Kim PN, et al. Assessment of the therapeutic response of hepatocellular carcinoma treated with transcatheter arterial chemoembolization: comparison of contrast-enhanced sonography and 3-phase computed tomography. J Ultrasound Med. 2006;25(4):477-486. Excluded: Wrong population. [pmid: 16567437].
Kim HO, Kim JS, Shin YM, Ryu J-S, Lee YS, Lee SG. Evaluation of metabolic characteristics and viability of lipiodolized hepatocellular carcinomas using 18F-FDG PET/CT. J Nucl Med. 2010;51(12):1849-1856. Excluded: Wrong population. [pmid: 21098794].
Kim HY, Choi JY, Kim CW, et al. Gadolinium ethoxybenzyl diethylenetriamine pentaacetic acid-enhanced magnetic resonance imaging predicts the histological grade of hepatocellular carcinoma only in patients with Child-Pugh class A cirrhosis. Liver Transpl. 2012;18(7):850-857. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22407909].
Kim I, Kim MJ. Histologic characteristics of hepatocellular carcinomas showing atypical enhancement patterns on 4-phase MDCT examination. Korean J Radiol. 2012;13(5):586-593. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22977326].
Kim J-E, Kim SH, Lee SJ, Rhim H. Hypervascular hepatocellular carcinoma 1 cm or smaller in patients with chronic liver disease: characterization with gadoxetic acid-enhanced MRI that includes diffusion-weighted imaging. AJR Am J Roentgenol. 2011;196(6):W758-765. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21606265].
Kim JH, Kim MJ, Park YN, et al. Mangafodipir trisodium-enhanced MRI of hepatocellular carcinoma: correlation with histological characteristics. Clin Radiol. 2008;63(11):1195-1204. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18929037].
Kim JY, Kim MJ, Kim KA, Jeong HT, Park YN. Hyperintense HCC on hepatobiliary phase images of gadoxetic acid-enhanced MRI: Correlation with clinical and pathological features. Eur J Radiol. 2012;81(12):3877-3882. Excluded: Background. [pmid: 22954410].
Kim K-B, Kim CW, Kim GH. Area extraction of the liver and hepatocellular carcinoma in CT scans. J Digit Imaging. 2008;21(Suppl 1):S89-103. Excluded: Background. [pmid: 17846836].
Kim MJ, Jin YC, Joon SL, et al. Optimal scan window for detection of hypervascular hepatocellular carcinomas during MDCT examination. AJR Am J Roentgenol. 2006;187(1):198-206. Excluded: Background. [pmid: 16794177].
Kim MJ, Lim HK, Choi D, Lee WJ, Rhim HC, Kim S. Sonography guided percutaneous radiofrequency ablation of hepatocellular carcinoma: effect of cooperative training on the pretreatment assessment of the operation’s feasibility. Korean J Radiol. 2008;9(1):29-37. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18253073].
Kim M-J, Choi J-Y, Chung YE, Choi SY. Magnetic resonance imaging of hepatocellular carcinoma using contrast media. Oncology. 2008;75(Suppl 1):72-82. Excluded: Background. [pmid: 19092275].
Kim M-J, Kim JH, Chung J-J, Park MS, Lim JS, Oh YT. Focal hepatic lesions: detection and characterization with combination gadolinium- and superparamagnetic iron oxide-enhanced MR imaging. Radiology. 2003;228(3):719-726. Excluded: Wrong population. [pmid: 12881583].
Kim M-J, Kim JH, Lim JS, et al. Detection and characterization of focal hepatic lesions: mangafodipir vs. superparamagnetic iron oxide-enhanced magnetic resonance imaging. J Magn Reson Imaging. 2004;20(4):612-621. Excluded: Wrong intervention. [pmid: 15390224].
Kim S, Mannelli L, Hajdu CH, et al. Hepatocellular carcinoma: assessment of response to transarterial chemoembolization with image subtraction. J Magn Reson Imaging. 2010;31(2):348-355. Excluded: Wrong population. [pmid: 20099348].
Kim SH, Choi BI, Lee JY, et al. Diagnostic accuracy of multi-/single-detector row CT and contrast-enhanced MRI in the detection of hepatocellular carcinomas meeting the milan criteria before liver transplantation. Intervirology. 2008;51(Suppl 1):52-60. Excluded: Systematic review; studies checked for inclusion. [pmid: 18544949].
Kim SH, Choi D, Lim JH, et al. Optimal pulse sequence for ferumoxides-enhanced MR imaging used in the detection of hepatocellular carcinoma: a comparative study using seven pulse sequences. Korean J Radiol. 2002;3(2):87-97. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12087198].
Kim SH, Lee JM, Lee JY, et al. Value of contrast-enhanced sonography for the characterization of focal hepatic lesions in patients with diffuse liver disease: receiver operating characteristic analysis. AJR Am J Roentgenol. 2005;184(4):1077-1084. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15788576].
Kim SH, Lee WJ, Lim HK, Park CK. SPIO-enhanced mri findings of well-differentiated hepatocellular carcinomas: correlation with MDCT findings. Korean J Radiol. 2009;10(2):112-120. Excluded: Inadequate reference standard. [pmid: 19270856].
Kim SK, Kim SH, Lee WJ, et al. Preoperative detection of hepatocellular carcinoma: ferumoxides-enhanced versus mangafodipir trisodium-enhanced MR imaging. AJR Am J Roentgenol. 2002;179(3):741-750. Excluded: Wrong intervention. [pmid: 12185056].
Kim T, Murakami T, Takahashi S, Hori M, Tsuda K, Nakamura H. Diffusion-weighted single-shot echoplanar MR imaging for liver disease. AJR Am J Roentgenol. 1999;173(2):393-398. Excluded: Wrong population. [pmid: 10430143].
Kim T, Murakami T, Takahashi S, et al. Optimal phases of dynamic CT for detecting hepatocellular carcinoma: Evaluation of unenhanced and triple-phase images. Abdom Imaging. 1999;24(5):473-480. Excluded: Wrong intervention. [pmid: 10475931].
Kim TK, Jang H-J, Wilson SR. Imaging diagnosis of hepatocellular carcinoma with differentiation from other pathology. Clin Liver Dis. 2005;9(2):253-279. Excluded: Background. [pmid: 15831272].
Kim TK, Lee KH, Khalili K, Jang H-J. Hepatocellular nodules in liver cirrhosis: contrast-enhanced ultrasound. Abdom Imaging. 2011;36(3):244-263. Excluded: Background. [pmid: 21253723].
Kim YJ, Yun M, Lee WJ, Kim KS, Lee JD. Usefulness of 18F-FDG PET in intrahepatic cholangiocarcinoma. Eur J Nucl Med Mol Imaging. 2003;30(11):1467-1472. Excluded: Wrong population. [pmid: 14579085].
Kim YK, Kim CS, Han YM. Detection of small hepatocellular carcinoma: Comparison of conventional gadolinium-enhanced MRI with gadoliniumenhanced MRI after the administration of ferucarbotran. Br J Radiol. 2009;82(978):468-474. Excluded: Inadequate reference standard. [pmid: 19124563].
Kim YK, Kwak HS, Kim CS, Han YM. Detection and characterization of focal hepatic tumors: a comparison of T2-weighted MR images before and after the administration of gadoxectic acid. J Magn Reson Imaging. 2009;30(2):437-443. Excluded: Wrong intervention. [pmid: 19629973].
Kim YK, Lee YH, Kwak HS, Kim CS, Han YM. Small malignant hepatic tumor detection in gadolinium- and ferucarbotran-enhanced magnetic resonance imaging: does combining ferucarbotran-enhanced T2*-weighted gradient echo and T2-weighted turbo spin echo images have additive efficacy?. Korean J Radiol. 2008;9(6):510-519. Excluded: Wrong intervention. [pmid: 19039267].
Klein D, Jenett M, Gassel HJ, Sandstede J, Hahn D. Quantitative dynamic contrast-enhanced sonography of hepatic tumors. Eur Radiol. 2004;14(6):1082-1091. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15108017].
Kluge R, Schmidt F, Caca K, et al. Positron emission tomography with [(18)F]fluoro-2-deoxy-D-glucose for diagnosis and staging of bile duct cancer. Hepatology. 2001;33(5):1029-1035. Excluded: Wrong population. [pmid: 11343227].
Kneteman N, Livraghi T, Madoff D, de Santibanez E, Kew M. Tools for monitoring patients with hepatocellular carcinoma on the waiting list and after liver transplantation. Liver Transpl. 2011;17(Suppl 2):S117-127. Excluded: Background. [pmid: 21584926].
Kondo H, Kanematsu M, Hoshi H, et al. Preoperative detection of malignant hepatic tumors: comparison of combined methods of MR imaging with combined methods of CT. AJR Am J Roentgenol. 2000;174(4):947-954. Excluded: Wrong population. [pmid: 10749228].
Konopke R, Bunk A, Kersting S. The role of contrast-enhanced ultrasound for focal liver lesion detection: an overview. Ultrasound Med Biol. 2007;33(10):1515-1526. Excluded: Background. [pmid: 17618038].
Korpraphong P, Leyendecker JR, Hildebolt CF, Narra V, Bae KT, Brown JJ. Serial MR imaging of small arterially-enhancing liver lesions in patients with chronic liver disease. J Med Assoc Thai. 2009;92(4):548-555. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19374308].
Kosari K, Gomes M, Hunter D, Hess DJ, Greeno E, Sielaff TD. Local, intrahepatic, and systemic recurrence patterns after radiofrequency ablation of hepatic malignancies. J Gastrointest Surg. 2002;6(2):255-263. Excluded: Wrong population. [pmid: 11992812].
Koyama K, Okamura T, Kawabe J, et al. The usefulness of 18F-FDG PET images obtained 2 hours after intravenous injection in liver tumor. Ann Nucl Med. 2002;16(3):169-176. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12126041].
Krinsky G. Imaging of dysplastic nodules and small hepatocellular carcinomas: experience with explanted livers. Intervirology. 2004;47(3–5):191-198. Excluded: Background. [pmid: 15383729].
Krinsky GA, Lee VS. MR imaging of cirrhotic nodules. Abdom Imaging. 2000;25(5):471-482. Excluded: Background. [pmid: 10931980].
Krinsky GA, Lee VS, Theise ND. Focal lesions in the cirrhotic liver: high resolution ex vivo MRI with pathologic correlation. J Comput Assist Tomogr. 2000;24(2):189-196. Excluded: Background. [pmid: 10752877].
Kubota K, Ina H, Okada Y, Irie T. Growth rate of primary single hepatocellular carcinoma: determining optimal screening interval with contrast enhanced computed tomography. Dig Dis Sci. 2003;48(3):581-586. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12757173].
Kudo M. Hepatocellular carcinoma 2009 and beyond: from the surveillance to molecular targeted therapy. Oncology. 2008;75(Suppl 1):1-12. Excluded: Background. [pmid: 19092266].
Kudo M. Real practice of hepatocellular carcinoma in Japan: conclusions of the Japan Society of Hepatology 2009 Kobe Congress. Oncology. 2010;78(Suppl 1):180-188. Excluded: Background. [pmid: 20616602].
Kudo M, Hatanaka K, Maekawa K. Newly developed novel ultrasound technique, defect reperfusion ultrasound imaging, using sonazoid in the management of hepatocellular carcinoma. Oncology. 2010;78(Suppl 1):40-45. Excluded: Inadequate reference standard. [pmid: 20616583].
Kudo M, Matsui O, Sakamoto M, et al. Role of gadolinium-ethoxybenzyl-diethylenetriamine pentaacetic acid-enhanced magnetic resonance imaging in the management of hepatocellular carcinoma: Consensus at the symposium of the 48th annual meeting of the liver cancer study group of Japan. Oncology (Switzerland). 2013;84(SUPPL 1):21-27. Excluded: Background.
Kudo M, Zheng RQ, Kim SR, et al. Diagnostic accuracy of imaging for liver cirrhosis compared to histologically proven liver cirrhosis. A multicenter collaborative study. Intervirology. 2008;51(Suppl 1):17-26. Excluded: Wrong population. [pmid: 18544944].
Kuehl H, Antoch G, Stergar H, et al. Comparison of FDG-PET, PET/CT and MRI for follow-up of colorectal liver metastases treated with radiofrequency ablation: initial results. Eur J Radiol. 2008;67(2):362-371. Excluded: Wrong population. [pmid: 18155866].
Kuehl H, Rosenbaum-Krumme S, Veit-Haibach P, et al. Impact of whole-body imaging on treatment decision to radio-frequency ablation in patients with malignant liver tumors: comparison of [18F]fluorodeoxyglucose-PET/computed tomography, PET and computed tomography. Nuclear Medicine Communications. 2008;29(7):599-606. Excluded: Wrong population. [pmid: 18528181].
Kulemann V, Schima W, Tamandl D, et al. Preoperative detection of colorectal liver metastases in fatty liver: MDCT or MRI?. Eur J Radiol. 2011;79(2):e1-6. Excluded: Wrong population. [pmid: 20392584].
Kumada T, Toyoda H, Tada T, et al. Evolution of hypointense hepatocellular nodules observed only in the hepatobiliary phase of gadoxetate disodium-enhanced MRI. AJR Am J Roentgenol. 2011;197(1):58-63. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21701011].
Lai ECH, Tang CN, Ha JPY, Tsui DKK, Li MKW. The evolving influence of laparoscopy and laparoscopic ultrasonography on patients with hepatocellular carcinoma. Am J Surg. 2008;196(5):736-740. Excluded: Wrong intervention. [pmid: 18558389].
Lam MG, Kwee TC, Basu S, Alavi A. Underestimated role of 18F-FDG PET for HCC evaluation and promise of 18F-FDG PET/MR imaging in this setting. J Nucl Med. 2013;54(8):1510-1511. Excluded: Wrong publication type. [pmid: 23781014].
Lamerz R, Runge M, Stieber P, Meissner E. Use of serum PIVKA-II (DCP) determination for differentiation between benign and malignant liver diseases. Anticancer Res. 1999;19(4A):2489-2493. Excluded: Wrong intervention. [pmid: 10470180].
Lanka B, Jang H-J, Kim TK, Burns PN, Wilson SR. Impact of contrast-enhanced ultrasonography in a tertiary clinical practice. J Ultrasound Med. 2007;26(12):1703-1714. Excluded: Wrong population. [pmid: 18029922].
Larcos G, Sorokopud H, Berry G, Farrell GC. Sonographic screening for hepatocellular carcinoma in patients with chronic hepatitis or cirrhosis: an evaluation. AJR Am J Roentgenol. 1998;171(2):433-435. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9694470].
Lee DH, Lee JM, Klotz E, et al. Detection of recurrent hepatocellular carcinoma in cirrhotic liver after transcatheter arterial chemoembolization: value of quantitative color mapping of the arterial enhancement fraction of the liver. Korean J Radiol. 2013;14(1):51-60. Excluded: Inadequate reference standard. [pmid: 23323031].
Lee JA, Jeong WK, Kim Y, et al. Dual-energy CT to detect recurrent HCC after TACE: initial experience of color-coded iodine CT imaging. Eur J Radiol. 2013;82(4):569-576. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23238365].
Lee JK, Chung Y-H, Song B-C, et al. Recurrences of hepatocellular carcinoma following initial remission by transcatheter arterial chemoembolization. J Gastroenterol Hepatol. 2002;17(1):52-58. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11895553].
Lee JM, Trevisani F, Vilgrain V, Wald C. Imaging diagnosis and staging of hepatocellular carcinoma. Liver Transpl. 2011;17(Suppl 2):S34-43. Excluded: Background. [pmid: 21739567].
Lee JM, Yoon J-H, Kim KW. Diagnosis of hepatocellular carcinoma: newer radiological tools. Semin Oncol. 2012;39(4):399-409. Excluded: Background. [pmid: 22846858].
Lee JY, Choi BI, Han JK, Lee JM, Kim SH. State-of-the-art ultrasonography of hepatocellular carcinoma. Eur J Radiol. 2006;58(2):177-185. Excluded: Background. [pmid: 16451825].
Lee KHY, O’Malley ME, Haider MA, Hanbidge A. Triple-Phase MDCT of Hepatocellular Carcinoma. AJR Am J Roentgenol. 2004;182(3):643-649. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 14975963].
Lee MH, Kim YK, Park MJ, et al. Gadoxetic acid-enhanced fat suppressed three-dimensional T1-weighted MRI using a multiecho dixon technique at 3 tesla: Emphasis on image quality and hepatocellular carcinoma detection. J Magn Reson Imaging. 2013;38(2):401-410. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23292998].
Lee MW, Rhim H, Ik Cha D, Jun Kim Y, Lim HK. Planning US for percutaneous radiofrequency ablation of small hepatocellular carcinomas (1–3 cm): Value of fusion imaging with conventional US and CT/MR Images. Journal of Vascular and Interventional Radiology. 2013;24(7):958-965. Excluded: Inadequate reference standard. [pmid: 23796082].
Lee SD, Kim SH, Kim YK, et al. 18F-FDG-PET/CT predicts early tumor recurrence in living donor liver transplantation for hepatocellular carcinoma. Transpl Int. 2013;26(1):50-60. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23106431].
Lee SW, Kim HJ, Park JH, et al. Clinical usefulness of 18F-FDG PET-CT for patients with gallbladder cancer and cholangiocarcinoma. J Gastroenterol. 2010;45(5):560-566. Excluded: Wrong population. [pmid: 20035356].
Leen E, Ceccotti P, Kalogeropoulou C, Angerson WJ, Moug SJ, Horgan PG. Prospective multicenter trial evaluating a novel method of characterizing focal liver lesions using contrast-enhanced sonography. AJR Am J Roentgenol. 2006;186(6):1551-1559. Excluded: Wrong population. [pmid: 16714643].
Lencioni R. Surveillance and early diagnosis of hepatocellular carcinoma. Dig Liver Dis. 2010;42(Suppl 3):S223-227. Excluded: Background. [pmid: 20547307].
Lencioni R, Della Pina C, Bruix J, et al. Clinical management of hepatic malignancies: ferucarbotran-enhanced magnetic resonance imaging versus contrast-enhanced spiral computed tomography. Dig Dis Sci. 2005;50(3):533-537. Excluded: Wrong population. [pmid: 15810637].
Lencioni R, Della Pina C, Crocetti L, Bozzi E, Cioni D. Clinical management of focal liver lesions: the key role of real-time contrast-enhanced US. Eur Radiol. 2007;17(Suppl 6):F73-79. Excluded: Background. [pmid: 18376460].
Lencioni R, Piscaglia F, Bolondi L. Contrast-enhanced ultrasound in the diagnosis of hepatocellular carcinoma. J Hepatol. 2008;48(5):848-857. Excluded: Background. [pmid: 18328590].
Leoni S, Piscaglia F, Golfieri R, et al. The impact of vascular and nonvascular findings on the noninvasive diagnosis of small hepatocellular carcinoma based on the EASL and AASLD criteria. Am J Gastroenterol. 2010;105(3):599-609. Excluded: Background. [pmid: 19935786].
Leoni S, Piscaglia F, Righini R, Bolondi L. Management of small hepatocellular carcinoma. Acta Gastroenterol Belg. 2006;69(2):230-235. Excluded: Background. [pmid: 16929622].
Li CS, Chen RC, Lii JM, et al. Magnetic resonance imaging appearance of well-differentiated hepatocellular carcinoma. J Comput Assist Tomogr. 2006;30(4):597-603. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16845290].
Li X-D, Li Z-G, Song X-X, Liu C-F. A variant in microRNA-196a2 is associated with susceptibility to hepatocellular carcinoma in Chinese patients with cirrhosis. Pathology. 2010;42(7):669-673. Excluded: Wrong intervention. [pmid: 21080878].
Li Y-Y, Sha W-H, Zhou Y-J, Nie Y-Q. Short and long term efficacy of high intensity focused ultrasound therapy for advanced hepatocellular carcinoma. J Gastroenterol Hepatol. 2007;22(12):2148-2154. Excluded: Wrong intervention. [pmid: 18031373].
Liang P-C, Ch’ang H-J, Hsu C, Tseng SS, Shih TTF, Wu Liu T. Dynamic MRI signals in the second week of radiotherapy relate to treatment outcomes of hepatocellular carcinoma: a preliminary result. Liver Int. 2007;27(4):516-528. Excluded: Wrong population. [pmid: 17403192].
Lim JH, Cho JM, Kim EY, Park CK. Dysplastic nodules in liver cirrhosis: evaluation of hemodynamics with CT during arterial portography and CT hepatic arteriography. Radiology. 2000;214(3):869-874. Excluded: Wrong intervention. [pmid: 10715060].
Lim JH, Choi D, Park CK, Lee WJ, Lim HK. Encapsulated hepatocellular carcinoma: CT-pathologic correlations. Eur Radiol. 2006;16(10):2326-2333. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16547706].
Lim JH, Jang HJ, Kim EY, Park CK, Joh JW, Kim YI. Early recurring hepatocellular carcinoma after partial hepatic resection: preoperative CT findings. Korean J Radiol. 2000;1(1):38-42. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11752927].
Lim KS. Diffusion-weighted MRI of hepatocellular carcinoma in cirrhosis. Clin Radiol. 2013. Excluded: Wrong publication type.
Limanond P, Raman SS, Sayre J, Lu DSK. Comparison of dynamic gadolinium-enhanced and ferumoxides-enhanced MRI of the liver on high- and low-field scanners. J Magn Reson Imaging. 2004;20(4):640-647. Excluded: Wrong population. [pmid: 15390231].
Lin C-Y, Chen J-H, Liang J-A, Lin C-C, Jeng L-B, Kao C-H. 18F-FDG PET or PET/CT for detecting extrahepatic metastases or recurrent hepatocellular carcinoma: a systematic review and meta-analysis. Eur J Radiol. 2012;81(9):2417-2422. Excluded: Systematic review; studies checked for inclusion. [pmid: 21899970].
Liu G-J, Xu H-X, Xie X-Y, et al. Does the echogenicity of focal liver lesions on baseline gray-scale ultrasound interfere with the diagnostic performance of contrast-enhanced ultrasound?. Eur Radiol. 2009;19(5):1214-1222. Excluded: Wrong population. [pmid: 19137313].
Liu J, Wang J-Z, Zhao J-D, Xu Z-Y, Jiang G-L. Use of combined maximum and minimum intensity projections to determine internal target volume in 4-dimensional CT scans for hepatic malignancies. Radiat. 2012;7:11. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22284745].
Liu Q, Chen J, Li H, Liang B, Zhang L, Hu T. Hepatocellular carcinoma with bile duct tumor thrombi: correlation of magnetic resonance imaging features to histopathologic manifestations. Eur J Radiol. 2010;76(1):103-109. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19501994].
Liu QY, Huang SQ, Chen JY, et al. Small hepatocellular carcinoma with bile duct tumor thrombi: CT and MRI findings. Abdom Imaging. 2010;35(5):537-542. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19763681].
Liu Q-Y, Zhang W-D, Chen J-Y, Li H-G, Liu C, Liang B-L. Hepatocellular carcinoma with bile duct tumor thrombus: dynamic computed tomography findings and histopathologic correlation. J Comput Assist Tomogr. 2011;35(2):187-194. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21412088].
Liu W-Y, Jin Y, Rong R-H, Ta X, Zhu X-S. Multi-phase helical CT in diagnosis of early hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. 2003;2(1):73-76. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 14607651].
Liu X, Zou L, Liu F, Zhou Y, Song B. Gadoxetic Acid Disodium-Enhanced Magnetic Resonance Imaging for the Detection of Hepatocellular Carcinoma: A Meta-Analysis. PLoS ONE. 2013;8(8). Excluded: Systematic review; studies checked for inclusion.
Liu Y, Chen Z, Liu C, Yu D, Lu Z, Zhang N. Gadolinium-loaded polymeric nanoparticles modified with Anti-VEGF as multifunctional MRI contrast agents for the diagnosis of liver cancer. Biomaterials. 2011;32(22):5167-5176. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21521627].
Lo CM, Fan ST, Liu CL, et al. Determining resectability for hepatocellular carcinoma: the role of laparoscopy and laparoscopic ultrasonography. J Hepatobiliary Pancreat Surg. 2000;7(3):260-264. Excluded: Background. [pmid: 10982624].
Loffroy R, Lin M, Rao P, et al. Comparing the detectability of hepatocellular carcinoma by C-arm dual-phase cone-beam computed tomography during hepatic arteriography with conventional contrast-enhanced magnetic resonance imaging. Cardiovasc Intervent Radiol. 2012;35(1):97-104. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21328023].
Lok AS, Sterling RK, Everhart JE, et al. Des-gamma-carboxy prothrombin and alpha-fetoprotein as biomarkers for the early detection of hepatocellular carcinoma. Gastroenterology. 2010;138(2):493-502. Excluded: Wrong population. [pmid: 19852963].
Lopez Hanninen E, Vogl TJ, Bechstein WO, et al. Biphasic spiral computed tomography for detection of hepatocellular carcinoma before resection or orthotopic liver transplantation. Invest Radiol. 1998;33(4):216-221. Excluded: Imaging before 1995. [pmid: 9556746].
Low RN. Abdominal MRI advances in the detection of liver tumours and characterisation. Lancet Oncol. 2007;8(6):525-535. Excluded: Background. [pmid: 17540304].
Loyer EM, Chin H, DuBrow RA, David CL, Eftekhari F, Charnsangavej C. Hepatocellular carcinoma and intrahepatic peripheral cholangiocarcinoma: Enhancement patterns with quadruple phase helical CT - A comparative study. Radiology. 1999;212(3):866-875. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10478259].
Lu DS, Siripongsakun S, Kyong Lee J, et al. Complete tumor encapsulation on magnetic resonance imaging: A potentially useful imaging biomarker for better survival in solitary large hepatocellular carcinoma. Liver Transpl. 2013;19(3):283-291. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23280814].
Lu Q, Luo Y, Yuan C-X, et al. Value of contrast-enhanced intraoperative ultrasound for cirrhotic patients with hepatocellular carcinoma: a report of 20 cases. World J Gastroenterol. 2008;14(25):4005-4010. Excluded: Wrong intervention. [pmid: 18609684].
Lu X, Zhao H, Yang H, et al. A prospective clinical study on early recurrence of hepatocellular carcinoma after hepatectomy. J Surg Oncol. 2009;100(6):488-493. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19653238].
Luciani A, Baranes L, Decaens T, et al. Non-invasive diagnostic imaging of hepatocellular carcinoma: Targeting cellular characterization?. J Hepatol. 2011;55(1):224-226. Excluded: Background. [pmid: 21334409].
Luke FE, Allen BC, Moshiri ST, et al. Multiphase multi-detector row computed tomography in the setting of chronic liver disease and orthotopic liver transplantation: can a series be eliminated in order to reduce radiation dose?. J Comput Assist Tomogr. 2013;37(3):408-414. Excluded: Background. [pmid: 23674013].
Luo MY, Shan H, Jiang ZB, Li LF, Huang HQ. Study on hepatocellular carcinoma-associated hepatic arteriovenous shunt using multidetector CT. World J Gastroenterol. 2003;9(11):2455-2459. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 14606075].
Luo MY, Shan H, Jiang ZB, Liang WW, Zhang JS, Li LF. Capability of multidetector CT to diagnose hepatocellular carcinoma-associated arterioportal shunt. World J Gastroenterol. 2005;11(17):2666-2669. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15849831].
Luo W, Numata K, Morimoto M, et al. Clinical utility of contrast-enhanced three-dimensional ultrasound imaging with Sonazoid: findings on hepatocellular carcinoma lesions. Eur J Radiol. 2009;72(3):425-431. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18930616].
Ma H, Liu J, Liu F. CT-guided single high-dose percutaneous acetic acid injection for small hepatocellular carcinoma: A long-term follow-up study. Eur J Radiol. 2012;81(6):1184-1186. Excluded: Wrong population. [pmid: 21511422].
Ma X, Samir AE, Holalkere N-S, Sahani DV. Optimal arterial phase imaging for detection of hypervascular hepatocellular carcinoma determined by continuous image capture on 16-MDCT. AJR Am J Roentgenol. 2008;191(3):772-777. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18716108].
Macarini L, Milillo P, Cascavilla A, et al. MR characterisation of dysplastic nodules and hepatocarcinoma in the cirrhotic liver with hepatospecific superparamagnetic contrast agents: pathological correlation in explanted livers. Radiol Med (Torino). 2009;114(8):1267-1282. Excluded: Wrong intervention. [pmid: 19902328].
Macdonald GA, Peduto AJ. Magnetic resonance imaging (MRI) and diseases of the liver and biliary tract. Part 1. Basic principles, MRI in the assessment of diffuse and focal hepatic disease. J Gastroenterol Hepatol. 2000;15(9):980-991. Excluded: Background. [pmid: 11059926].
Maciel AC, Cerski CT, Moreira RK, Resende VL, Zanotelli ML, Matiotti SB. Hepatocellular carcinoma in patients undergoing orthotopic liver transplantation: radiological findings with anatomopathological correlation in Brazil. Arq Gastroenterol. 2006;43(1):24-29. Excluded: Imaging before 1995. [pmid: 16699614].
Magini G, Farsad M, Frigerio M, et al. C-11 acetate does not enhance usefulness of F-18 FDG PET/CT in differentiating between focal nodular hyperplasia and hepatic adenoma. Clin Nucl Med. 2009;34(10):659-665. Excluded: Wrong population. [pmid: 19893396].
Makita O, Yamashita Y, Arakawa A, et al. Diffuse perfusion abnormality of the liver parenchyma on angiography-assisted helical CT in relation to cirrhosis and previous treatments: a potential diagnostic pitfall for detecting hepatocellular carcinoma. Clin Imaging. 2000;24(5):292-297. Excluded: Wrong intervention. [pmid: 11331160].
Makita O, Yamashita Y, Arakawa A, et al. Diagnostic accuracy of helical CT arterial portography and CT hepatic arteriography for hypervascular hepatocellular carcinoma in chronic liver damage. An ROC analysis. Acta Radiol. 2000;41(5):464-469. Excluded: Wrong intervention. [pmid: 11016767].
Malagari K, Koskinas J, Brountzos E, et al. CT portography and post-lipiodol CT in the preinterventional work-up of primary and secondary liver tumors. A single center experience. Hepatogastroenterology. 1999;46(29):2901-2908. Excluded: Wrong intervention. [pmid: 10576370].
Mallikarjuna Swamy CM, Arathi CA, Kodandaswamy CR. Value of ultrasonography-guided fine needle aspiration cytology in the investigative sequence of hepatic lesions with an emphasis on hepatocellular carcinoma. J Cytol. 2011;28(4):178-184. Excluded: Wrong intervention. [pmid: 22090691].
Mandai M, Koda M, Matono T, et al. Assessment of hepatocellular carcinoma by contrast-enhanced ultrasound with perfluorobutane microbubbles: comparison with dynamic CT. Br J Radiol. 2011;84(1002):499-507. Excluded: Inadequate reference standard. [pmid: 20959373].
Manichon AF, Bancel B, Durieux-Millon M, et al. Hepatocellular adenoma: Evaluation with contrast-enhanced ultrasound and MRI and correlation with pathologic and phenotypic classification in 26 lesions. HPB Surgery. 2012;2012. Excluded: Wrong population.
Mann GN, Marx HF, Lai LL, Wagman LD. Clinical and cost effectiveness of a new hepatocellular MRI contrast agent, mangafodipir trisodium, in the preoperative assessment of liver resectability. Ann Surg Oncol. 2001;8(7):573-579. Excluded: Wrong population. [pmid: 11508618].
Marchianò A, Spreafico C, Lanocita R, et al. Does iodine concentration affect the diagnostic efficacy of biphasic spiral CT in patients with hepatocellular carcinoma?. Abdom Imaging. 2005;30(3):274-280. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15654576].
Marrero JA, Welling T. Modern diagnosis and management of hepatocellular carcinoma. Clin Liver Dis. 2009;13(2):233-247. Excluded: Background. [pmid: 19442916].
Martie A, Sporea I, Popescu A, et al. Contrast enhanced ultrasound for the characterization of hepatocellular carcinoma. Med Ultrason. 2011;13(2):108-113. Excluded: Inadequate reference standard. [pmid: 21655536].
Maruyama H, Takahashi M, Ishibashi H, et al. Ultrasound-guided treatments under low acoustic power contrast harmonic imaging for hepatocellular carcinomas undetected by B-mode ultrasonography. Liver Int. 2009;29(5):708-714. Excluded: Wrong intervention. [pmid: 18803588].
Massarweh NN, Park JO, Bruix J, et al. Diagnostic imaging and biopsy use among elderly medicare beneficiaries with hepatocellular carcinoma. J Oncol Pract. 2011;7(3):155-160. Excluded: Wrong intervention. [pmid: 21886495].
Matoba M, Kitadate M, Kondou T, Yokota H, Tonami H. Depiction of hypervascular hepatocellular carcinoma with 64-MDCT: Comparison of moderate- and high-concentration contrast material with and without saline flush. AJR Am J Roentgenol. 2009;193(3):738-744. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19696287].
Matsui O, Kobayashi S, Sanada J, et al. Hepatocelluar nodules in liver cirrhosis: hemodynamic evaluation (angiography-assisted CT) with special reference to multi-step hepatocarcinogenesis. Abdom Imaging. 2011;36(3):264-272. Excluded: Wrong intervention. [pmid: 21267562].
Matsui O, Ueda K, Kobayashi S, et al. Intra- and perinodular hemodynamics of hepatocellular carcinoma: CT observation during intra-arterial contrast injection. Abdom Imaging. 2002;27(2):147-156. Excluded: Background. [pmid: 11847574].
Matsuo M, Kanematsu M, Inaba Y, et al. Pre-operative detection of malignant hepatic tumours: value of combined helical CT during arterial portography and biphasic CT during hepatic arteriography. Clin Radiol. 2001;56(2):138-145. Excluded: Wrong intervention. [pmid: 11222073].
Matsushima M, Naganawa S, Ikeda M, et al. Diagnostic value of SPIO-mediated breath-hold, black-blood, fluid-attenuated, inversion recovery (BH-BB-FLAIR) imaging in patients with hepatocellular carcinomas. Magn. 2010;9(2):49-58. Excluded: Inadequate reference standard. [pmid: 20585194].
Mejia GA, Gomez MA, Serrano J, et al. Correlation between the radiologic and histologic size of hepatocellular carcinoma in patients eligible for liver transplantation. Transplant Proc. 2006;38(5):1394-1395. Excluded: Background. [pmid: 16797313].
Mi B, Wan W, Yu C, You X, Xu Q. Sarcomatoid hepatocellular carcinoma diagnosed by FDG PET/CT. Clin Nucl Med. 2011;36(10):925-927. Excluded: Background. [pmid: 21892049].
Mikami S, Kubo S, Hirohashi K, et al. Computed tomography during arteriography and arterial portography in small hepatocellular carcinoma and dysplastic nodule: a prospective study. Jpn J Cancer Res. 2000;91(8):859-863. Excluded: Wrong intervention. [pmid: 10965029].
Mikami S, Tateishi R, Akahane M, et al. Computed tomography follow-up for the detection of hepatocellular carcinoma recurrence after initial radiofrequency ablation: a single-center experience. J Vasc Interv Radiol. 2012;23(10):1269-1275. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22999746].
Miller FH, Hammond N, Siddiqi AJ, et al. Utility of diffusion-weighted MRI in distinguishing benign and malignant hepatic lesions. J Magn Reson Imaging. 2010;32(1):138-147. Excluded: Wrong population. [pmid: 20578020].
Min YW, Gwak G-Y, Lee MW, et al. Clinical course of sub-centimeter-sized nodules detected during surveillance for hepatocellular carcinoma. World J Gastroenterol. 2012;18(21):2654-2660. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22690074].
Miyamoto N, Sakurai Y, Nishimori H, Tsuji K, Kang J-H, Maguchi H. Optimal scan timing for coronal enhancement of hypervascular hepatocellular carcinomas and correlation with tumor size: evaluation with four-phase CT hepatic arteriography. Radiat Med. 2005;23(6):456-462. Excluded: Wrong intervention. [pmid: 16389992].
Miyayama S, Matsui O, Yamashiro M, et al. Detection of hepatocellular carcinoma by CT during arterial portography using a cone-beam CT technology: Comparison with conventional CTAP. Abdom Imaging. 2009;34(4):502-506. Excluded: Wrong intervention. [pmid: 18373115].
Miyayama S, Yamashiro M, Okuda M, et al. Detection of corona enhancement of hypervascular hepatocellular carcinoma by C-arm dual-phase cone-beam CT during hepatic arteriography. Cardiovasc Intervent Radiol. 2011;34(1):81-86. Excluded: Wrong intervention. [pmid: 20333382].
Mochizuki T, Tsuda T, Sugawara Y, et al. Tc-99m PMT hepatobiliary scintigraphy in the differential diagnosis of extrahepatic metastases and hepatocellular carcinoma. Clin Nucl Med. 2000;25(12):991-995. Excluded: Wrong intervention. [pmid: 11129165].
Mody RJ, Pohlen JA, Malde S, Strouse PJ, Shulkin BL. FDG PET for the study of primary hepatic malignancies in children. Pediatr Blood Cancer. 2006;47(1):51-55. Excluded: Wrong population. [pmid: 16078228].
Mok TSK, Yeo W, Yu S, et al. An intensive surveillance program detected a high incidence of hepatocellular carcinoma among hepatitis B virus carriers with abnormal alpha-fetoprotein levels or abdominal ultrasonography results. J Clin Oncol. 2005;23(31):8041-8047. Excluded: Inadequate reference standard. [pmid: 16258102].
Montorsi M, Santambrogio R, Bianchi P, et al. Laparoscopy with laparoscopic ultrasound for pretreatment staging of hepatocellular carcinoma: a prospective study. J Gastrointest Surg. 2001;5(3):312-315. Excluded: Wrong intervention. [pmid: 11360055].
Monzawa S, Omata K, Shimazu N, Yagawa A, Hosoda K, Araki T. Well-differentiated hepatocellular carcinoma: Findings of US, CT, and MR imaging. Abdom Imaging. 1999;24(4):392-397. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10390564].
Morana G, Grazioli L, Kirchin MA, et al. Solid hypervascular liver lesions: accurate identification of true benign lesions on enhanced dynamic and hepatobiliary phase magnetic resonance imaging after gadobenate dimeglumine administration. Invest Radiol. 2011;46(4):225-239. Excluded: Wrong population. [pmid: 21102346].
Morana G, Grazioli L, Schneider G, et al. Hypervascular hepatic lesions: dynamic and late enhancement pattern with Gd-BOPTA. Acad Radiol. 2002;9(Suppl 2):S476-479. Excluded: Background. [pmid: 12188313].
Mori K, Scheidler J, Helmberger T, et al. Detection of malignant hepatic lesions before orthotopic liver transplantation: accuracy of ferumoxides-enhanced MR imaging. AJR Am J Roentgenol. 2002;179(4):1045-1051. Excluded: Wrong intervention. [pmid: 12239063].
Moribata K, Tamai H, Shingaki N, et al. Assessment of malignant potential of small hypervascular hepatocellular carcinoma using B-mode ultrasonography. Hepatol Res. 2011;41(3):233-239. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21272166].
Muhi A, Ichikawa T, Motosugi U, et al. High-b-value diffusion-weighted MR imaging of hepatocellular lesions: estimation of grade of malignancy of hepatocellular carcinoma. J Magn Reson Imaging. 2009;30(5):1005-1011. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19856432].
Murakami T, Imai Y, Okada M, et al. Ultrasonography, computed tomography and magnetic resonance imaging of hepatocellular carcinoma: toward improved treatment decisions. Oncology. 2011;81(Suppl 1):86-99. Excluded: Background. [pmid: 22212941].
Murakami T, Kim T, Hori M, Federle MP. Double Arterial Phase Multi-Detector Row Helical CT for Detection of Hypervascular Hepatocellular Carcinoma [3]. Radiology. 2003;229(3):931-932. Excluded: Background. [pmid: 14657326].
Murakami T, Okada M, Hyodo T. CT versus MR imaging of hepatocellular carcinoma: toward improved treatment decisions. Magn. 2012;11(2):75-81. Excluded: Background. [pmid: 22790293].
Murakami T, Takamura M, Kim T, et al. Double phase CT during hepatic arteriography for diagnosis of hepatocellular carcinoma. Eur J Radiol. 2005;54(2):246-252. Excluded: Wrong intervention. [pmid: 15837405].
Nakagawara H, Ogawa M, Matsumoto N, et al. Evaluation of malignancy of hepatocellular carcinoma using the ultrasonic B-mode method: Clinical significance of extracapsular invasion of hepatocellular carcinoma using ultrasonography. Journal of Medical Ultrasonics. 2007;34(2):83-91. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Nakai M, Sato M, Ikoma A, et al. Triple-phase computed tomography during arterial portography with bolus tracking for hepatic tumors. Jpn J Radiol. 2010;28(2):149-156. Excluded: Wrong intervention. [pmid: 20182850].
Nakamura Y, Toyota N, Shuji D, et al. Clinical significance of the transitional phase at gadoxetate disodium-enhanced hepatic MRI for the diagnosis of hepatocellular carcinoma: Preliminary results. J Comput Assist Tomogr. 2011;35(6):723-727. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22082543].
Nakanishi M, Chuma M, Hige S, et al. Relationship between diffusion-weighted magnetic resonance imaging and histological tumor grading of hepatocellular carcinoma. Ann Surg Oncol. 2012;19(4):1302-1309. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21927976].
Nakaura T, Awai K, Yanaga Y, et al. Detection of early enhancement of hypervascular hepatocellular carcinoma using single breath-hold 3D pixel shift dynamic subtraction MDCT. AJR Am J Roentgenol. 2008;190(1):W13-18. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18094267].
Nakayama M, Kamura T, Kimura M, Seki H, Tsukada K, Sakai K. Quantitative MRI of hepatocellular carcinoma in cirrhotic and noncirrhotic livers. Clin Imaging. 1998;22(4):280-283. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9699049].
Nakayama M, Yamashita Y, Mitsuzaki K, et al. Improved tissue characterization of focal liver lesions with ferumoxide-enhanced T1 and T2-weighted MR imaging. J Magn Reson Imaging. 2000;11(6):647-654. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10862064].
Namkung S, Zech CJ, Helmberger T, Reiser MF, Schoenberg SO. Superparamagnetic iron oxide (SPIO)-enhanced liver MRI with ferucarbotran: efficacy for characterization of focal liver lesions. J Magn Reson Imaging. 2007;25(4):755-765. Excluded: Wrong population. [pmid: 17335040].
Nanashima A, Abo T, Sakamoto I, et al. Three-dimensional fusion images of hepatic vasculature and bile duct used for preoperative simulation before hepatic surgery. Hepatogastroenterology. 2012;59(118):1748-1757. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22369745].
Negi N, Yoshikawa T, Ohno Y, et al. Hepatic CT perfusion measurements: a feasibility study for radiation dose reduction using new image reconstruction method. Eur J Radiol. 2012;81(11):3048-3054. Excluded: Wrong intervention. [pmid: 22613507].
Ng CS, Chandler AG, Wei W, et al. Effect of dual vascular input functions on CT perfusion parameter values and reproducibility in liver tumors and normal liver. J Comput Assist Tomogr. 2012;36(4):388-393. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22805665].
Ng CS, Chandler AG, Wei W, et al. Reproducibility of CT perfusion parameters in liver tumors and normal liver. Radiology. 2011;260(3):762-770. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21788525].
Ng CS, Raunig DL, Jackson EF, et al. Reproducibility of perfusion parameters in dynamic contrast-enhanced MRI of lung and liver tumors: effect on estimates of patient sample size in clinical trials and on individual patient responses. AJR Am J Roentgenol. 2010;194(2):W134-140. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20093564].
Nguyen P, Feng JC, Chang KJ. Endoscopic ultrasound (EUS) and EUS-guided fine-needle aspiration (FNA) of liver lesions. Gastrointest Endosc. 1999;50(3):357-361. Excluded: Wrong intervention. [pmid: 10462656].
Nicolau C, Vilana R, Catala V, et al. Importance of evaluating all vascular phases on contrast-enhanced sonography in the differentiation of benign from malignant focal liver lesions. AJR Am J Roentgenol. 2006;186(1):158-167. Excluded: Wrong population. [pmid: 16357396].
Niizawa G, Ikegami T, Matsuzaki Y, et al. Monitoring of hepatocellular carcinoma, following proton radiotherapy, with contrast-enhanced color Doppler ultrasonography. J Gastroenterol. 2005;40(3):283-290. Excluded: Wrong population. [pmid: 15830288].
Nishie A, Tajima T, Asayama Y, et al. Diagnostic performance of apparent diffusion coefficient for predicting histological grade of hepatocellular carcinoma. Eur J Radiol. 2011;80(2):e29-33. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20619566].
Nishie A, Tajima T, Ishigami K, et al. Detection of hepatocellular carcinoma (HCC) using super paramagnetic iron oxide (SPIO)-enhanced MRI: Added value of diffusion-weighted imaging (DWI). J Magn Reson Imaging. 2010;31(2):373-382. Excluded: Wrong intervention. [pmid: 20099351].
Nishie A, Yoshimitsu K, Asayama Y, et al. Detection of combined hepatocellular and cholangiocarcinomas on enhanced CT: Comparison with histologic findings. AJR Am J Roentgenol. 2005;184(4):1157-1162. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15788587].
Nishie A, Yoshimitsu K, Asayama Y, et al. Radiologic detectability of minute portal venous invasion in hepatocellular carcinoma. AJR Am J Roentgenol. 2008;190(1):81-87. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18094297].
Niu Y, Huang T, Lian F, Li F. Contrast-enhanced ultrasonography for the diagnosis of small hepatocellular carcinoma: a meta-analysis and meta-regression analysis. Tumor Biology. 2013:1-8. Excluded: Systematic review; studies checked for inclusion.
Nouso K, Tanaka H, Uematsu S, et al. Cost-effectiveness of the surveillance program of hepatocellular carcinoma depends on the medical circumstances. J Gastroenterol Hepatol. 2008;23(3):437-444. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17683496].
Numminen K, Halavaara J, Isoniemi H, et al. Magnetic resonance imaging of the liver: true fast imaging with steady state free precession sequence facilitates rapid and reliable distinction between hepatic hemangiomas and liver malignancies. J Comput Assist Tomogr. 2003;27(4):571-576. Excluded: Wrong population. [pmid: 12886146].
Numminen K, Halavaara J, Tervahartiala P, et al. Liver tumour MRI: what do we need for lesion characterization?. Scand J Gastroenterol. 2004;39(1):67-73. Excluded: Wrong population. [pmid: 14992564].
Numminen K, Isoniemi H, Halavaara J, et al. Preoperative assessment of focal liver lesions: multidetector computed tomography challenges magnetic resonance imaging. Acta Radiol. 2005;46(1):9-15. Excluded: Wrong population. [pmid: 15841734].
Obuz F, Oksuzler M, Secil M, Sagol O, Karademir S, Astarcioglu H. Efficiency of MR imaging in the detection of malignant liver lesions. Diagn Interv Radiol. 2006;12(1):17-21. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16538579].
Ogata R, Majima Y, Tateishi Y, et al. Bright loop appearance; a characteristic ultrasonography sign of early hepatocellular carcinoma. Oncol Rep. 2000;7(6):1293-1298. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11032932].
Ogawa S, Kumada T, Toyoda H, et al. Evaluation of pathological features of hepatocellular carcinoma by contrast-enhanced ultrasonography: Comparison with pathology on resected specimen. Eur J Radiol. 2006;59(1):74-81. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16545532].
Ohto M, Ito R, Soma N, et al. Contrast-enhanced 3D ultrasonography in minute hepatocellular carcinoma. Journal of Medical Ultrasonics. 2011;38(1):3-12. Excluded: Wrong study design for Key Question.
Okada M, Imai Y, Kim T, et al. Comparison of enhancement patterns of histologically confirmed hepatocellular carcinoma between gadoxetate- and ferucarbotran-enhanced magnetic resonance imaging. J Magn Reson Imaging. 2010;32(4):903-913. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20882621].
Okamoto E, Sato S, Sanchez-Siles AA, et al. Evaluation of virtual CT sonography for enhanced detection of small hepatic nodules: a prospective pilot study. AJR Am J Roentgenol. 2010;194(5):1272-1278. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20410414].
Okumura E, Sanada S, Suzuki M, Matsui O. A computer-aided temporal and dynamic subtraction technique of the liver for detection of small hepatocellular carcinomas on abdominal CT images. Phys Med Biol. 2006;51(19):4759-4771. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16985269].
Okumura E, Sanada S, Suzuki M, Takemura A, Matsui O. Effectiveness of temporal and dynamic subtraction images of the liver for detection of small HCC on abdominal CT images: comparison of 3D nonlinear image-warping and 3D global-matching techniques. Radiol Phys Technol. 2011;4(2):109-120. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21229338].
Onaya H, Itai Y, Satake M, et al. Highly enhanced hepatic masses seen on CT during arterial portography: Early hepatocellular carcinoma and adenomatous hyperplasia. Jpn J Clin Oncol. 2000;30(10):440-445. Excluded: Wrong intervention. [pmid: 11185890].
Onur MR, Cicekci M, Kayali A, Poyraz AK, Kocakoc E. The role of ADC measurement in differential diagnosis of focal hepatic lesions. Eur J Radiol. 2012;81(3):e171-176. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21353418].
Ouedraogo W, Tran-Van Nhieu J, Baranes L, et al. Evaluation of noninvasive diagnostic criteria for hepatocellular carcinoma on pretransplant MRI (2010): correlation between MR imaging features and histological features on liver specimen. J Radiol. 2011;92(7–8):688-700. Excluded: Not English language. [pmid: 21819911].
Ozsunar Y, Skjoldbye B, Court-Payen M, Karstrup S, Burcharth F. Impact of intraoperative ultrasonography on surgical treatment of liver tumours. Acta Radiol. 2000;41(1):97-101. Excluded: Wrong intervention. [pmid: 10665881].
Parikh A, Taouli B. Imaging of hepatocellular carcinoma: current concepts. Recent Results Cancer Res. 2013;190:33-55. Excluded: Background. [pmid: 22941012].
Park HS, Lee J-M, Kim SH, et al. Differentiation of well-differentiated hepatocellular carcinomas from other hepatocellular nodules in cirrhotic liver: value of SPIO-enhanced MR imaging at 3.0 Tesla. J Magn Reson Imaging. 2009;29(2):328-335. Excluded: Wrong intervention. [pmid: 19161184].
Patel D, Terrault NA, Yao FY, Bass NM, Ladabaum U. Cost-effectiveness of hepatocellular carcinoma surveillance in patients with hepatitis C virus-related cirrhosis. Clin Gastroenterol Hepatol. 2005;3(1):75-84. Excluded: Background. [pmid: 15645408].
Patel M, Shariff MIF, Ladep NG, et al. Hepatocellular carcinoma: diagnostics and screening. J Eval Clin Pract. 2012;18(2):335-342. Excluded: Background. [pmid: 21114800].
Paudyal B, Oriuchi N, Paudyal P, et al. Early diagnosis of recurrent hepatocellular carcinoma with 18F-FDG PET after radiofrequency ablation therapy. Oncol Rep. 2007;18(6):1469-1473. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17982632].
Pauleit D, Textor J, Bachmann R, et al. Improving the detectability of focal liver lesions on T2-weighted MR images: ultrafast breath-hold or respiratory-triggered thin-section MRI?. J Magn Reson Imaging. 2001;14(2):128-133. Excluded: Wrong population. [pmid: 11477670].
Pawluk RS, Tummala S, Brown JJ, Borrello JA. A retrospective analysis of the accuracy of T2-weighted images and dynamic gadolinium-enhanced sequences in the detection and characterization of focal hepatic lesions. J Magn Reson Imaging. 1999;9(2):266-273. Excluded: Imaging before 1995. [pmid: 10077023].
Peck-Radosavljevic M. Imaging and early diagnosis of hepatocellular carcinoma. Minerva Gastroenterol Dietol. 2011;57(3):273-286. Excluded: Background. [pmid: 21769077].
Pei XQ, Liu LZ, Liu M, et al. Contrast-enhanced ultrasonography of hepatocellular carcinoma: correlation between quantitative parameters and histological grading. Br J Radiol. 2012;85(1017):e740-747. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22096225].
Peschl R, Werle A, Mathis G. Differential diagnosis of focal liver lesions in signal-enhanced ultrasound using BR 1, a second-generation ultrasound signal enhancer. Dig Dis. 2004;22(1):73-80. Excluded: Inadequate reference standard. [pmid: 15292698].
Petersein J, Spinazzi A, Giovagnoni A, et al. Focal liver lesions: evaluation of the efficacy of gadobenate dimeglumine in MR imaging--a multicenter phase III clinical study. Radiology. 2000;215(3):727-736. Excluded: Wrong population. [pmid: 10831691].
Phongkitkarun S, Srianujata T, Jatchavala J. Supplement value of magnetic resonance imaging in small hepatic lesion (< or = 20 mm) detected on routine computed tomography. J Med Assoc Thai. 2009;92(5):677-686. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19459531].
Pirovano G, Vanzulli A, Marti-Bonmati L, et al. Evaluation of the accuracy of gadobenate dimeglumine-enhanced MR imaging in the detection and characterization of focal liver lesions. AJR Am J Roentgenol. 2000;175(4):1111-1120. Excluded: Wrong population. [pmid: 11000175].
Piscaglia F, Lencioni R, Sagrini E, et al. Characterization of focal liver lesions with contrast-enhanced ultrasound. Ultrasound Med Biol. 2010;36(4):531-550. Excluded: Wrong publication type. [pmid: 20350680].
Pleguezuelo M, Germani G, Marelli L, et al. Evidence-based diagnosis and locoregional therapy for hepatocellular carcinoma. Expert Rev Gastroenterol Hepatol. 2008;2(6):761-784. Excluded: Background. [pmid: 19090737].
Poeckler-Schoeniger C, Koepke J, Gueckel F, Sturm J, Georgi M. MRI with superparamagnetic iron oxide: efficacy in the detection and characterization of focal hepatic lesions. Magn Reson Imaging. 1999;17(3):383-392. Excluded: Wrong population. [pmid: 10195581].
Preis O, Blake MA, Scott JA. Neural network evaluation of PET scans of the liver: a potentially useful adjunct in clinical interpretation. Radiology. 2011;258(3):714-721. Excluded: Inadequate reference standard. [pmid: 21339347].
Purysko AS, Remer EM, Coppa CP, Leao Filho HM, Thupili CR, Veniero JC. LI-RADS: a case-based review of the new categorization of liver findings in patients with end-stage liver disease. Radiographics. 2012;32(7):1977-1995. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23150853].
Purysko AS, Remer EM, Coppa CP, Obuchowski NA, Schneider E, Veniero JC. Characteristics and distinguishing features of hepatocellular adenoma and focal nodular hyperplasia on gadoxetate disodium-enhanced MRI. AJR Am J Roentgenol. 2012;198(1):115-123. Excluded: Wrong population. [pmid: 22194486].
Qayyum A, Thoeni RF, Coakley FV, Lu Y, Guay JP, Ferrell LD. Detection of hepatocellular carcinoma by ferumoxides-enhanced MR imaging in cirrhosis: Incremental value of dynamic gadolinium-enhancement. J Magn Reson Imaging. 2006;23(1):17-22. Excluded: Wrong intervention. [pmid: 16315209].
Qian MYY, Yuwei JR, Angus P, Schelleman T, Johnson L, Gow P. Efficacy and cost of a hepatocellular carcinoma screening program at an Australian teaching hospital. J Gastroenterol Hepatol. 2010;25(5):951-956. Excluded: Wrong publication type. [pmid: 20546449].
Quaia E, Alaimo V, Baratella E, et al. Effect of observer experience in the differentiation between benign and malignant liver tumors after ultrasound contrast agent injection. J Ultrasound Med. 2010;29(1):25-36. Excluded: Wrong population. [pmid: 20040772].
Quaia E, Calliada F, Bertolotto M, et al. Characterization of focal liver lesions with contrast-specific US modes and a sulfur hexafluoride-filled microbubble contrast agent: diagnostic performance and confidence. Radiology. 2004;232(2):420-430. Excluded: Wrong population. [pmid: 15286314].
Quaia E, De Paoli L, Pizzolato R, et al. Predictors of dysplastic nodule diagnosis in patients with liver cirrhosis on unenhanced and gadobenate dimeglumine-enhanced MRI with dynamic and hepatobiliary phase. AJR Am J Roentgenol. 2013;200(3):553-562. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23436844].
Quaia E, Lorusso A, Grisi G, Stacul F, Cova MA. The role of CEUS in the characterization of hepatocellular nodules detected during the US surveillance program--current practices in Europe. Ultraschall Med. 2012;33(Suppl 1):S48-56. Excluded: Background. [pmid: 22723029].
Quaia E, Pizzolato R, De Paoli L, Angileri R, Ukmar M, Cova MA. Arterial enhancing-only nodules less than 2 cm in diameter in patients with liver cirrhosis: predictors of hepatocellular carcinoma diagnosis on gadobenate dimeglumine-enhanced MR imaging. J Magn Reson Imaging. 2013;37(4):892-902. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23097278].
Quaia E, Stacul F, Gaiani S, et al. Comparison of diagnostic performance of unenhanced vs SonoVue - enhanced ultrasonography in focal liver lesions characterization. The experience of three Italian centers. Radiol Med (Torino). 2004;108(1–2):71-81. Excluded: Wrong population. [pmid: 15269691].
Rabenandrasana HA, Furukawa A, Furuichi K, Yamasaki M, Takahashi M, Murata K. Comparison between tissue harmonic imaging and liver-specific late-phase contrast-enhanced pulse-inversion imaging in the detection of hepatocellular carcinoma and liver metastasis. Radiat Med. 2004;22(2):90-97. Excluded: Inadequate reference standard. [pmid: 15176603].
Raman SS, Lu DS, Chen SC, Sayre J, Eilber F, Economou J. Hepatic MR imaging using ferumoxides: prospective evaluation with surgical and intraoperative sonographic confirmation in 25 cases. AJR Am J Roentgenol. 2001;177(4):807-812. Excluded: Wrong population. [pmid: 11566677].
Reimer P, Jahnke N, Fiebich M, et al. Hepatic lesion detection and characterization: value of nonenhanced MR imaging, superparamagnetic iron oxide-enhanced MR imaging, and spiral CT-ROC analysis. Radiology. 2000;217(1):152-158. Excluded: Wrong population. [pmid: 11012438].
Ren FY, Piao XX, Jin AL. Efficacy of ultrasonography and alpha-fetoprotein on early detection of hepatocellular carcinoma. World J Gastroenterol. 2006;12(29):4656-4659. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16937435].
Rennert J, Jung E-M, Schreyer AG, et al. MR-arterioportography: a new technical approach for detection of liver lesions. World J Gastroenterol. 2011;17(13):1739-1745. Excluded: Background. [pmid: 21483635].
Robinson PJ, Arnold P, Wilson D. Small “indeterminate” lesions on CT of the liver: a follow-up study of stability. Br J Radiol. 2003;76(912):866-874. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 14711773].
Ronot M, Bahrami S, Calderaro J, et al. Hepatocellular adenomas: Accuracy of magnetic resonance imaging and liver biopsy in subtype classification. Hepatology. 2011;53(4):1182-1191. Excluded: Wrong population. [pmid: 21480324].
Rosenkrantz AB, Mannelli L, Mossa D, Babb JS. Breath-hold T2-weighted MRI of the liver at 3T using the BLADE technique: impact upon image quality and lesion detection. Clin Radiol. 2011;66(5):426-433. Excluded: Inadequate reference standard. [pmid: 21300326].
Ruelas-Villavicencio AL, Vargas-Vorackova F. In whom, how and how often is surveillance for hepatocellular carcinoma cost-effective?. Ann Hepatol. 2004;3(4):152-159. Excluded: Background. [pmid: 15657557].
Rydberg JN, Tervonen OA, Rydberg DB, Lomas DJ, Ehman RL, Riederer SJ. Dual-echo breathhold T(2)-weighted fast spin echo MR imaging of liver lesions. Magn Reson Imaging. 2000;18(2):117-124. Excluded: Inadequate reference standard. [pmid: 10722970].
Saab S, Ly D, Nieto J, et al. Hepatocellular carcinoma screening in patients waiting for liver transplantation: a decision analytic model. Liver Transpl. 2003;9(7):672-681. Excluded: Background. [pmid: 12827551].
Sacks A, Peller PJ, Surasi DS, Chatburn L, Mercier G, Subramaniam RM. Value of PET/CT in the management of primary hepatobiliary tumors, part 2. AJR Am J Roentgenol. 2011;197(2):W260-265. Excluded: Background. [pmid: 21785051].
Saito K, Moriyasu F, Sugimoto K, et al. Histological grade of differentiation of hepatocellular carcinoma: Comparison of the efficacy of diffusion-weighted MRI with T2-weighted imaging and angiography-assisted CT. J Med Imaging Radiat Oncol. 2012;56(3):261-269. Excluded: Background. [pmid: 22697322].
Saito K, Moriyasu F, Sugimoto K, et al. Diagnostic efficacy of gadoxetic acid-enhanced MRI for hepatocellular carcinoma and dysplastic nodule. World J Gastroenterol. 2011;17(30):3503-3509. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21941417].
Sandrasegaran K, Akisik FM, Lin C, Tahir B, Rajan J, Aisen AM. The value of diffusion-weighted imaging in characterizing focal liver masses. Acad Radiol. 2009;16(10):1208-1214. Excluded: Wrong population. [pmid: 19608435].
Sandrasegaran K, Ramaswamy R, Ghosh S, et al. Diffusion-weighted MRI of the transplanted liver. Clin Radiol. 2011;66(9):820-825. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21621199].
Sangiovanni A, Del Ninno E, Fasani P, et al. Increased survival of cirrhotic patients with a hepatocellular carcinoma detected during surveillance. Gastroenterology. 2004;126(4):1005-1014. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15057740].
Sangiovanni A, Prati GM, Fasani P, et al. The natural history of compensated cirrhosis due to hepatitis C virus: A 17-year cohort study of 214 patients. Hepatology. 2006;43(6):1303-1310. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16729298].
Santagostino E, Colombo M, Rivi M, et al. A 6-month versus a 12-month surveillance for hepatocellular carcinoma in 559 hemophiliacs infected with the hepatitis C virus. Blood. 2003;102(1):78-82. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12649165].
Santi V, Trevisani F, Gramenzi A, et al. Semiannual surveillance is superior to annual surveillance for the detection of early hepatocellular carcinoma and patient survival. J Hepatol. 2010;53(2):291-297. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20483497].
Savranoglu P, Obuz F, Karasu S, et al. The role of SPIO-enhanced MRI in the detection of malignant liver lesions. Clin Imaging. 2006;30(6):377-381. Excluded: Wrong population. [pmid: 17101405].
Schindera ST, Diedrichsen L, Muller HC, et al. Iterative reconstruction algorithm for abdominal multidetector CT at different tube voltages: assessment of diagnostic accuracy, image quality, and radiation dose in a phantom study. Radiology. 2011;260(2):454-462. Excluded: Wrong population. [pmid: 21493795].
Schindera ST, Hareter LF, Raible S, et al. Effect of tumor size and tumor-to-liver contrast of hypovascular liver tumors on the diagnostic performance of hepatic CT imaging. Invest Radiol. 2012;47(3):197-201. Excluded: Wrong population. [pmid: 22233758].
Schultz JF, Bell JD, Goldstein RM, Kuhn JA, McCarty TM. Hepatic tumor imaging using iron oxide MRI: comparison with computed tomography, clinical impact, and cost analysis. Ann Surg Oncol. 1999;6(7):691-698. Excluded: Wrong population. [pmid: 10560856].
Seltzer SE, Getty DJ, Pickett RM, et al. Multimodality diagnosis of liver tumors: feature analysis with CT, liver-specific and contrast-enhanced MR, and a computer model. Acad Radiol. 2002;9(3):256-269. Excluded: Wrong population. [pmid: 11887942].
Semelka RC, Lee JK, Worawattanakul S, Noone TC, Patt RH, Ascher SM. Sequential use of ferumoxide particles and gadolinium chelate for the evaluation of focal liver lesions on MRI. J Magn Reson Imaging. 1998;8(3):670-674. Excluded: Wrong population. [pmid: 9626884].
Semelka RC, Martin DR, Balci C, Lance T. Focal liver lesions: comparison of dual-phase CT and multisequence multiplanar MR imaging including dynamic gadolinium enhancement. J Magn Reson Imaging. 2001;13(3):397-401. Excluded: Wrong population. [pmid: 11241813].
Seo JW, Lim JH, Choi D, Jang HJ, Lee WJ, Lim HK. Indeterminate small, low-attenuating hepatocellular nodules on helical CT in patients with chronic liver disease: 2-Year follow-up. Clin Imaging. 2005;29(4):266-272. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15967319].
Shah AJ, Parsons B, Pope I, Callaway M, Finch-Jones MD, Thomas MG. The clinical impact of magnetic resonance imaging in diagnosing focal hepatic lesions and suspected cancer. Clin Imaging. 2009;33(3):209-212. Excluded: Wrong population. [pmid: 19411027].
Shah TU, Semelka RC, Pamuklar E, et al. The risk of hepatocellular carcinoma in cirrhotic patients with small liver nodules on MRI. Am J Gastroenterol. 2006;101(3):533-540. Excluded: Wrong setting. [pmid: 16542290].
Sharma P, Saini SD, Kuhn LB, et al. Knowledge of hepatocellular carcinoma screening guidelines and clinical practices among gastroenterologists. Dig Dis Sci. 2011;56(2):569-577. Excluded: Background. [pmid: 20978844].
Sherman M. The radiological diagnosis of hepatocellular carcinoma. Am J Gastroenterol. 2010;105(3):610-612. Excluded: Background. [pmid: 20203642].
Shimizu A, Ito K, Sasaki K, et al. Small hyperintense hepatic lesions on T1-weighted images in patients with cirrhosis: evaluation with serial MRI and imaging features for clinical benignity. Magn Reson Imaging. 2007;25(10):1430-1436. Excluded: Inadequate reference standard. [pmid: 17524587].
Shiraishi J, Sugimoto K, Moriyasu F, Kamiyama N, Doi K. Computer-aided diagnosis for the classification of focal liver lesions by use of contrast-enhanced ultrasonography. Med Phys. 2008;35(5):1734-1746. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18561648].
Shokry A. Value of dynamic multidetector CT in different grades of hepatocellular carcinoma. Egyptian Journal of Radiology and Nuclear Medicine. 2012;43(3):361-368. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Smith JT, Hawkins RM, Guthrie JA, et al. Effect of slice thickness on liver lesion detection and characterisation by multidetector CT. J Med Imaging Radiat Oncol. 2010;54(3):188-193. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20598005].
Snowberger N, Chinnakotla S, Lepe RM, et al. Alpha fetoprotein, ultrasound, computerized tomography and magnetic resonance imaging for detection of hepatocellular carcinoma in patients with advanced cirrhosis. Aliment Pharmacol Ther. 2007;26(9):1187-1194. Excluded: Imaging before 1995. [pmid: 17944733].
Song Z-Z. Diagnosis of hepatic nodules 20 mm or smaller in cirrhosis: prospective validation of the noninvasive diagnostic criteria for hepatocellular carcinoma. Hepatology. 2008;47(6):2145-2146. author reply 2146–2147. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18508292].
Soresi M, Magliarisi C, Campagna P, et al. Usefulness of alpha-fetoprotein in the diagnosis of hepatocellular carcinoma. Anticancer Res. 2003;23(2C):1747-1753. Excluded: Background. [pmid: 12820452].
Soussan M, Aube C, Bahrami S, Boursier J, Valla DC, Vilgrain V. Incidental focal solid liver lesions: diagnostic performance of contrast-enhanced ultrasound and MR imaging. Eur Radiol. 2010;20(7):1715-1725. Excluded: Wrong population. [pmid: 20069427].
Soye JA, Mullan CP, Porter S, Beattie H, Barltrop AH, Nelson WM. The use of contrast-enhanced ultrasound in the characterisation of focal liver lesions. Ulster Med J. 2007;76(1):22-25. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17288301].
Soyer P, Corno L, Boudiaf M, et al. Differentiation between cavernous hemangiomas and untreated malignant neoplasms of the liver with free-breathing diffusion-weighted MR imaging: comparison with T2-weighted fast spin-echo MR imaging. Eur J Radiol. 2011;80(2):316-324. Excluded: Wrong population. [pmid: 20800983].
Soyer P, Dufresne AC, Somveille E, Lenormand S, Scherrer A, Rymer R. Differentiation between hepatic cavernous hemangioma and malignant tumor with T2-weighted MRI: comparison of fast spin-echo and breathhold fast spin-echo pulse sequences. Clin Imaging. 1998;22(3):200-210. Excluded: Wrong population. [pmid: 9559233].
Sporea I, Badea R, Martie A, et al. Contrast Enhanced Ultrasound for the evaluation of focal liver lesions in daily practice. A multicentre study. Med. 2012;14(2):95-100. Excluded: Wrong population. [pmid: 22675708].
Sporea I, Sirli R, Martie A, Popescu A, Danila M. How useful is contrast enhanced ultrasonography for the characterization of focal liver lesions?. J Gastrontest Liver Dis. 2010;19(4):393-398. Excluded: Wrong population. [pmid: 21188330].
Steingruber IE, Mallouhi A, Czermak BV, et al. Pretransplantation evaluation of the cirrhotic liver with explantation correlation: accuracy of CT arterioportography and digital subtraction hepatic angiography in revealing hepatocellular carcinoma. AJR Am J Roentgenol. 2003;181(1):99-108. Excluded: Background. [pmid: 12818838].
Stoker J, Romijn MG, de Man RA, et al. Prospective comparative study of spiral computer tomography and magnetic resonance imaging for detection of hepatocellular carcinoma. Gut. 2002;51(1):105-107. Excluded: Inadequate reference standard. [pmid: 12077101].
Strobel D, Bernatik T, Blank W, et al. Diagnostic accuracy of CEUS in the differential diagnosis of small (<=20 mm) and subcentimetric (<=10 mm) focal liver lesions in comparison with histology. Results of the DEGUM multicenter trial. Ultraschall Med. 2011;32(6):593-597. Excluded: Wrong population. [pmid: 22161556].
Strobel D, Seitz K, Blank W, et al. Contrast-enhanced ultrasound for the characterization of focal liver lesions--diagnostic accuracy in clinical practice (DEGUM multicenter trial). Ultraschall Med. 2008;29(5):499-505. Excluded: Wrong population. [pmid: 19241506].
Sugihara S, Suto Y, Kamba M, Ogawa T. Comparison of various techniques of iron oxide-enhanced breath-hold MR imaging of hepatocellular carcinoma. Clin Imaging. 2001;25(2):104-109. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11483419].
Suzuki K, Yamamoto M, Shirahata N, et al. Evaluation of contrast-enhanced ultrasonography in the diagnosis of hepatocellular carcinoma. Act Hepato. 2001;42(10):528-535. Excluded: Not English language.
Szklaruk J, Silverman PM, Charnsangavej C. Imaging in the diagnosis, staging, treatment, and surveillance of hepatocellular carcinoma. AJR Am J Roentgenol. 2003;180(2):441-454. Excluded: Background. [pmid: 12540450].
Tada T, Kumada T, Toyoda H, et al. Diagnosis of hepatocellular carcinoma by contrast-enhanced ultrasound with perfluorobutane and enhanced magnetic resonance imaging with Gd-EOB-DTPA. Act Hepato. 2010;51(3):99-106. Excluded: Not English language.
Tahir B, Sandrasegaran K, Ramaswamy R, et al. Does the hepatocellular phase of gadobenate dimeglumine help to differentiate hepatocellular carcinoma in cirrhotic patients according to histological grade?. Clin Radiol. 2011;66(9):845-852. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21771548].
Tajima T, Zhang X, Kitagawa T, et al. Computer-aided detection (CAD) of hepatocellular carcinoma on multiphase CT images. Progress in Biomedical Optics and Imaging - Proceedings of SPIE. 2007:6514. Excluded: Inadequate reference standard.
Takahashi M, Maruyama H, Ishibashi H, Yoshikawa M, Yokosuka O. Contrast-enhanced ultrasound with perflubutane microbubble agent: evaluation of differentiation of hepatocellular carcinoma. AJR Am J Roentgenol. 2011;196(2):W123-131. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21257852].
Takayasu K, Arii S, Ikai I, et al. Overall survival after transarterial lipiodol infusion chemotherapy with or without embolization for unresectable hepatocellular carcinoma: propensity score analysis. AJR Am J Roentgenol. 2010;194(3):830-837. Excluded: Background. [pmid: 20173167].
Takayasu K, Maeda T, Iwata R. Sensitivity of superselective arteriography for small hepatocellular carcinoma compared with proximal arteriography and computed tomography during superselective arteriography. Jpn J Clin Oncol. 2002;32(6):191-195. Excluded: Wrong population. [pmid: 12110634].
Takayasu K, Muramatsu Y, Mizuguchi Y, Ojima H. CT Imaging of early hepatocellular carcinoma and the natural outcome of hypoattenuating nodular lesions in chronic liver disease. Oncology. 2007;72(Suppl 1):83-91. Excluded: Wrong publication type. [pmid: 18087187].
Takayasu K, Yoshie K, Muramatsu Y, et al. Haemodynamic changes in non-alcoholic (viral) liver cirrhosis studied by computed tomography (CT) arterial portography and CT arteriography. J Gastroenterol Hepatol. 1999;14(9):908-914. Excluded: Wrong intervention. [pmid: 10535474].
Takeshita K, Nagashima I, Frui S, et al. Effect of superparamagnetic iron oxide-enhanced MRI of the liver with hepatocellular carcinoma and hyperplastic nodule. J Comput Assist Tomogr. 2002;26(3):451-455. Excluded: Wrong population. [pmid: 12016379].
Takumi K, Fukukura Y, Shindo T, et al. Feasibility of a fixed scan delay technique using a previous bolus tracking technique data for dynamic hepatic CT. Eur J Radiol. 2012;81(11):2996-3001. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22749800].
Tamada T, Ito K, Ueki A, et al. Peripheral low intensity sign in hepatic hemangioma: diagnostic pitfall in hepatobiliary phase of Gd-EOB-DTPA-enhanced MRI of the liver. J Magn Reson Imaging. 2012;35(4):852-858. Excluded: Wrong population. [pmid: 22127980].
Tan C, Thng C, Low A, et al. Wash-out of hepatocellular carcinoma: quantitative region of interest analysis on CT. Ann Acad Med Singapore. 2011;40(6):269-275. Excluded: Wrong comparator/Wrong reference standard. [pmid: 21779615].
Tanabe N, Ito K, Shimizu A, et al. Hepatocellular lesions with increased iron uptake on superparamagnetic iron oxide-enhanced magnetic resonance imaging in cirrhosis or chronic hepatitis: comparison of four magnetic resonance sequences for lesion conspicuity. Magn Reson Imaging. 2009;27(6):801-806. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19144487].
Tanaka H, Iijima H, Higashiura A, et al. New malignant grading system for hepatocellular carcinoma using the Sonazoid contrast agent for ultrasonography. J Gastroenterol. 2013:1-9. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Tanaka H, Iijima H, Nouso K, et al. Cost-effectiveness analysis on the surveillance for hepatocellular carcinoma in liver cirrhosis patients using contrast-enhanced ultrasonography. Hepatol Res. 2012;42(4):376-384. Excluded: Wrong study design for Key Question. [pmid: 22221694].
Tanaka S, Oshikawa O, Sasaki T, Ioka T, Tsukuma H. Evaluation of tissue harmonic imaging for the diagnosis of focal liver lesions. Ultrasound Med Biol. 2000;26(2):183-187. Excluded: Wrong population. [pmid: 10722906].
Tanaka Y, Sasaki Y, Katayama K, et al. Probability of hepatocellular carcinoma of small hepatocellular nodules undetectable by computed tomography during arterial portography. Hepatology. 2000;31(4):890-898. Excluded: Wrong population. [pmid: 10733545].
Tang A, Cruite I, Sirlin CB. Toward a standardized system for hepatocellular carcinoma diagnosis using computed tomography and MRI. [Review]. Expert Rev Gastroenterol Hepatol. 2013;7(3):269-279. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23445236].
Tanimoto A, Wakabayashi G, Shinmoto H, Nakatsuka S, Okuda S, Kuribayashi S. Superparamagnetic iron oxide-enhanced MR imaging for focal hepatic lesions: a comparison with CT during arterioportography plus CT during hepatic arteriography. J Gastroenterol. 2005;40(4):371-380. Excluded: Wrong intervention. [pmid: 15870974].
Tanimoto A, Wakabayashi G, Shinmoto H, Okuda S, Kuribayashi S, Mukai M. The mechanism of ring enhancement in hepatocellular carcinoma on superparamagnetic iron oxide-enhanced T1-weighted images: an investigation into peritumoral Kupffer cells. J Magn Reson Imaging. 2005;21(3):230-236. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15723373].
Tao R, Zhang J, Dai Y, et al. Characterizing hepatocellular carcinoma using multi-breath-hold two-dimensional susceptibility-weighted imaging: Comparison to conventional liver MRI. Clin Radiol. 2012;67(12):e91-e97. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22981726].
Taouli B, Goh JSK, Lu Y, et al. Growth rate of hepatocellular carcinoma: Evaluation with serial computed tomography or magnetic resonance imaging. J Comput Assist Tomogr. 2005;29(4):425-429. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16012295].
Taouli B, Vilgrain V, Dumont E, Daire JL, Fan B, Menu Y. Evaluation of liver diffusion isotropy and characterization of focal hepatic lesions with two single-shot echo-planar MR imaging sequences: prospective study in 66 patients. Radiology. 2003;226(1):71-78. Excluded: Wrong population. [pmid: 12511671].
Tatsumi M, Clark PA, Nakamoto Y, Wahl RL. Impact of body habitus on quantitative and qualitative image quality in whole-body FDG-PET. Eur J Nucl Med Mol Imaging. 2003;30(1):40-45. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12483408].
Tello R, Fenlon HM, Gagliano T, deCarvalho VL, Yucel EK. Prediction rule for characterization of hepatic lesions revealed on MR imaging: estimation of malignancy. AJR Am J Roentgenol. 2001;176(4):879-884. Excluded: Wrong population. [pmid: 11264070].
Thompson Coon J, Rogers G, Hewson P, et al. Surveillance of cirrhosis for hepatocellular carcinoma: a cost-utility analysis. Br J Cancer. 2008;98(7):1166-1175. Excluded: Wrong study design for Key Question. [pmid: 18382459].
Tonan T, Fujimoto K, Azuma S, et al. Evaluation of small (<or=2 cm) dysplastic nodules and well-differentiated hepatocellular carcinomas with ferucarbotran-enhanced MRI in a 1.0-T MRI unit: utility of T2*-weighted gradient echo sequences with an intermediate-echo time. Eur J Radiol. 2007;64(1):133-139. Excluded: Wrong intervention. [pmid: 17408900].
Toyoda H, Kumada T, Sone Y. Impact of a unified CT angiography system on outcome of patients with hepatocellular carcinoma. AJR Am J Roentgenol. 2009;192(3):766-774. Excluded: Wrong population. [pmid: 19234276].
Toyoda H, Kumada T, Tada T, et al. Non-hypervascular hypointense nodules detected by Gd-EOB-DTPA-enhanced MRI are a risk factor for recurrence of HCC after hepatectomy. J Hepatol. 2013. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Tradati F, Colombo M, Mannucci PM, et al. A prospective multicenter study of hepatocellular carcinoma in italian hemophiliacs with chronic hepatitis C. The Study Group of the Association of Italian Hemophilia Centers. Blood. 1998;91(4):1173-1177. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9454746].
Treglia G, Giovannini E, Di Franco D, et al. The role of positron emission tomography using carbon-11 and fluorine-18 choline in tumors other than prostate cancer: a systematic review. Ann Nucl Med. 2012;26(6):451-461. Excluded: Wrong population. [pmid: 22566040].
Trevisani F, Cantarini MC, Labate AMM, et al. Surveillance for hepatocellular carcinoma in elderly Italian patients with cirrhosis: effects on cancer staging and patient survival. [Erratum appears in Am J Gastroenterol. 2004 Oct;99(10):2074]. Am J Gastroenterol. 2004;99(8):1470-1476. Excluded: Wrong study design for Key Question. [pmid: 15307862].
Trillaud H, Bruel J-M, Valette P-J, et al. Characterization of focal liver lesions with SonoVue-enhanced sonography: international multicenter-study in comparison to CT and MRI. World J Gastroenterol. 2009;15(30):3748-3756. Excluded: Wrong population. [pmid: 19673015].
Tsai C-C, Yen T-C, Tzen K-Y. The value of Tc-99m red blood cell SPECT in differentiating giant cavernous hemangioma of the liver from other liver solid masses. Clin Nucl Med. 2002;27(8):578-581. Excluded: Wrong population. [pmid: 12170003].
Tsurusaki M, Sugimoto K, Fujii M, Fukuda T, Matsumoto S, Sugimura K. Combination of CT during arterial portography and double-phase CT hepatic arteriography with multi-detector row helical CT for evaluation of hypervascular hepatocellular carcinoma. Clin Radiol. 2007;62(12):1189-1197. Excluded: Wrong intervention. [pmid: 17981167].
Tzen KY, Yen TC, Lin WY, Tsai CC, Lin KJ. Diagnostic value of 99mTc-labeled red blood cell SPET for a solitary solid liver mass in HBV carrier patients with different echogenicities. Hepatogastroenterology. 2000;47(35):1375-1378. Excluded: Wrong population. [pmid: 11100355].
Vajragupta L, Kittisatra K, Sasiwimonphan K. Magnetic resonance imaging findings of hepatocellular carcinoma: Typical and atypical findings. Asian Biomedicine. 2010;4(1):113-124. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Valls C, Lopez E, Guma A, et al. Helical CT versus CT arterial portography in the detection of hepatic metastasis of colorectal carcinoma. AJR Am J Roentgenol. 1998;170(5):1341-1347. Excluded: Wrong population. [pmid: 9574613].
van den Esschert JW, Bieze M, Beuers UH, van Gulik TM, Bennink RJ. Differentiation of hepatocellular adenoma and focal nodular hyperplasia using 18F-fluorocholine PET/CT. Eur J Nucl Med Mol Imaging. 2011;38(3):436-440. Excluded: Wrong population. [pmid: 20717825].
Vilana R, Bianchi L, Varela M, et al. Is microbubble-enhanced ultrasonography sufficient for assessment of response to percutaneous treatment in patients with early hepatocellular carcinoma?. Eur Radiol. 2006;16(11):2454-2462. Excluded: Wrong population. [pmid: 16710666].
Vogel WV, van Dalen JA, Wiering B, et al. Evaluation of image registration in PET/CT of the liver and recommendations for optimized imaging. J Nucl Med. 2007;48(6):910-919. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17504865].
Vogl TJ, Schwarz W, Blume S, et al. Preoperative evaluation of malignant liver tumors: comparison of unenhanced and SPIO (Resovist)-enhanced MR imaging with biphasic CTAP and intraoperative US. Eur Radiol. 2003;13(2):262-272. Excluded: Wrong intervention. [pmid: 12598989].
von Herbay A, Vogt C, Haussinger D. Late-phase pulse-inversion sonography using the contrast agent levovist: differentiation between benign and malignant focal lesions of the liver. AJR Am J Roentgenol. 2002;179(5):1273-1279. Excluded: Wrong population. [pmid: 12388513].
von Herbay A, Vogt C, Haussinger D. Pulse inversion sonography in the early phase of the sonographic contrast agent Levovist: differentiation between benign and malignant focal liver lesions. J Ultrasound Med. 2002;21(11):1191-1200. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12418760].
von Herbay A, Vogt C, Willers R, Haussinger D. Real-time imaging with the sonographic contrast agent SonoVue: differentiation between benign and malignant hepatic lesions. J Ultrasound Med. 2004;23(12):1557-1568. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15557299].
von Herbay A, Westendorff J, Gregor M. Contrast-enhanced ultrasound with SonoVue: differentiation between benign and malignant focal liver lesions in 317 patients. J Clin Ultrasound. 2010;38(1):1-9. Excluded: Wrong population. [pmid: 19790253].
Vossen JA, Buijs M, Liapi E, Eng J, Bluemke DA, Kamel IR. Receiver operating characteristic analysis of diffusion-weighted magnetic resonance imaging in differentiating hepatic hemangioma from other hypervascular liver lesions. J Comput Assist Tomogr. 2008;32(5):750-756. Excluded: Wrong population. [pmid: 18830105].
Wang B, Gao ZQ, Yan X. Correlative study of angiogenesis and dynamic contrast-enhanced magnetic resonance imaging features of hepatocellular carcinoma. Acta Radiol. 2005;46(4):353-358. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16134309].
Wang DB, Zhou KR, Zeng MS, Chen KM, Wang YXJ. Mn-DPDP-enhanced 24-h delayed-scan MRI of hepatocellular carcinoma is correlated with histology [1]. Eur Radiol. 2004;14(4):743-745. Excluded: Wrong intervention. [pmid: 12802614].
Wang H, Mu XT, Zhong X. Comparative study of dynamic MRI and MSCT in hepatocellular carcinoma with cirrhosis. Chinese Journal of Medical Imaging Technology. 2007;23(7):1046-1048. Excluded: Not English language.
Wang J-H, Lu S-N, Tung H-D, et al. Flash-echo contrast sonography in the evaluation of response of small hepatocellular carcinoma to percutaneous ablation. J Clin Ultrasound. 2006;34(4):161-168. Excluded: Wrong population. [pmid: 16615047].
Wang WP, Ding H, Qi Q, Mao F, Xu ZZ, Kudo M. Characterization of focal hepatic lesions with contrast-enhanced C-cube gray scale ultrasonography. World J Gastroenterol. 2003;9(8):1667-1674. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 12918098].
Wang W-P, Wu Y, Luo Y, et al. Clinical value of contrast-enhanced ultrasonography in the characterization of focal liver lesions: a prospective multicenter trial. Hepatobiliary Pancreat Dis Int. 2009;8(4):370-376. Excluded: Wrong population. [pmid: 19666405].
Wang XY, Chen D, Zhang XS, Chen ZF, Hu AB. Value of 18F-FDG-PET/CT in the detection of recurrent hepatocellular carcinoma after hepatectomy or radiofrequency ablation: A comparative study with contrast-enhanced ultrasound. Journal of Digestive Diseases. 2013;14(8):433-438. Excluded: Inadequate reference standard. [pmid: 23615075].
Wang Z, Tang J, An L, et al. Contrast-enhanced ultrasonography for assessment of tumor vascularity in hepatocellular carcinoma. J Ultrasound Med. 2007;26(6):757-762. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17526607].
Ward J, Chen F, Guthrie JA, et al. Hepatic lesion detection after superparamagnetic iron oxide enhancement: comparison of five T2-weighted sequences at 1.0 T by using alternative-free response receiver operating characteristic analysis. Radiology. 2000;214(1):159-166. Excluded: Wrong population. [pmid: 10644117].
Ward J, Guthrie JA, Scott DJ, et al. Hepatocellular carcinoma in the cirrhotic liver: double-contrast MR imaging for diagnosis. Radiology. 2000;216(1):154-162. Excluded: Wrong population. [pmid: 10887242].
Watanabe H, Kanematsu M, Goshima S, et al. Detection of focal hepatic lesions with 3-T MRI: comparison of two-dimensional and three-dimensional T2-weighted sequences. Jpn J Radiol. 2012;30(9):721-728. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22907739].
Watanabe S, Katada Y, Gohkyu M, Nakajima M, Kawabata H, Nozaki M. Liver perfusion CT during hepatic arteriography for the hepatocellular carcinoma: Dose reduction and quantitative evaluation for normal- and ultralow-dose protocol. Eur J Radiol. 2012;81(12):3993-3997. Excluded: Wrong intervention. [pmid: 22980216].
Willkomm P, Bender H, Bangard M, Decker P, Grunwald F, Biersack HJ. FDG PET and immunoscintigraphy with 99mTc-labeled antibody fragments for detection of the recurrence of colorectal carcinoma. J Nucl Med. 2000;41(10):1657-1663. Excluded: Wrong population. [pmid: 11037995].
Wilson SR, Burns PN, Muradali D, Wilson JA, Lai X. Harmonic hepatic US with microbubble contrast agent: initial experience showing improved characterization of hemangioma, hepatocellular carcinoma, and metastasis. Radiology. 2000;215(1):153-161. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 10751481].
Wilson SR, Kim TK, Jang H-J, Burns PN. Enhancement patterns of focal liver masses: discordance between contrast-enhanced sonography and contrast-enhanced CT and MRI. AJR Am J Roentgenol. 2007;189(1):W7-W12. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17579140].
Winters SD, Jackson S, Armstrong GA, Birchall IW, Lee KHY, Low G. Value of subtraction MRI in assessing treatment response following image-guided loco-regional therapies for hepatocellular carcinoma. Clin Radiol. 2012;67(7):649-655. Excluded: Wrong population. [pmid: 22300821].
Witjes CDM, Willemssen FEJA, Verheij J, et al. Histological differentiation grade and microvascular invasion of hepatocellular carcinoma predicted by dynamic contrast-enhanced MRI. J Magn Reson Imaging. 2012;36(3):641-647. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 22532493].
Wolf GK, Lang H, Prokop M, Schreiber M, Zoller W. Volume measurements of localized hepatic lesions using three-dimensional sonography in comparison with three-dimensional computed tomography. Eur J Med Res. 1998;3(3):157-164. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9502756].
Wong K, Paulson EK, Nelson RC. Breath-hold three-dimensional CT of the liver with multi-detector row helical CT. Radiology. 2001;219(1):75-79. Excluded: Wrong population. [pmid: 11274537].
Woodall CE, Scoggins CR, Loehle J, Ravindra KV, McMasters KM, Martin RCG. Hepatic imaging characteristics predict overall survival in hepatocellular carcinoma. Ann Surg Oncol. 2007;14(10):2824-2830. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 17690939].
Wu LM, Xu JR, Gu HY, et al. Is Liver-Specific Gadoxetic Acid-Enhanced Magnetic Resonance Imaging a Reliable Tool for Detection of Hepatocellular Carcinoma in Patients with Chronic Liver Disease?. Dig Dis Sci. 2013:1-13. Excluded: Systematic review; studies checked for inclusion. [pmid: 23179161].
Wu LM, Xu JR, Lu Q, Hua J, Chen J, Hu J. A pooled analysis of diffusion-weighted imaging in the diagnosis of hepatocellular carcinoma in chronic liver diseases. [Review]. J Gastroenterol Hepatol. 2013;28(2):227-234. Excluded: Systematic review; studies checked for inclusion. [pmid: 23190006].
Wu W, Chen M-H, Yin S-S, et al. The role of contrast-enhanced sonography of focal liver lesions before percutaneous biopsy. AJR Am J Roentgenol. 2006;187(3):752-761. Excluded: Wrong population. [pmid: 16928941].
Xia D, Jing J, Shen H, Wu J. Value of diffusion-weighted magnetic resonance images for discrimination of focal benign and malignant hepatic lesions: a meta-analysis. J Magn Reson Imaging. 2010;32(1):130-137. Excluded: Wrong study design for Key Question. [pmid: 20578019].
Xie L, Guang Y, Ding H, Cai A, Huang Y. Diagnostic value of contrast-enhanced ultrasound, computed tomography and magnetic resonance imaging for focal liver lesions: a meta-analysis. Ultrasound Med Biol. 2011;37(6):854-861. Excluded: Systematic review; studies checked for inclusion. [pmid: 21531500].
Xing GS, Wang S, Ouyang H, Ma XH, Zhou CW. Comparison of CT and dynamic-enhancement MRI for the diagnosis of hepatocellular carcinoma. Chinese Journal of Medical Imaging Technology. 2010;26(1):1-4. Excluded: Not English language.
Xu HX, Liu GJ, Lu MD, et al. Characterization of focal liver lesions using contrast-enhanced sonography with a low mechanical index mode and a sulfur hexafluoride-filled microbubble contrast agent. J Clin Ultrasound. 2006;34(6):261-272. Excluded: Inadequate reference standard. [pmid: 16788957].
Xu HX, Liu GJ, Lu MD, et al. Characterization of small focal liver lesions using real-time contrast-enhanced sonography: diagnostic performance analysis in 200 patients. J Ultrasound Med. 2006;25(3):349-361. Excluded: Inadequate reference standard. [pmid: 16495496].
Xu H-X, Lu M-D, Xie X-H, et al. Three-dimensional contrast-enhanced ultrasound of the liver: experience of 92 cases. Ultrasonics. 2009;49(3):377-385. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19041996].
Xu J, Wu Y, Dong F. Clinical value of contrast-enhanced ultrasound in differentiating benign and malignant focal liver lesions. J Huazhong Univ Sci Technolog Med Sci. 2007;27(6):703-705. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 18231748].
Yan FH, Zeng MS, Zhou KR. Role and pitfalls of hepatic helical multi-phase CT scanning in differential diagnosis of small hemangioma and small hepatocellular carcinoma. World Journal of Gastroenterology. 41998:343-347. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 11819317].
Yanaga Y, Awai K, Nakaura T, et al. Hepatocellular carcinoma in patients weighing 70 kg or less: Initial trial of compact-bolus dynamic CT with low-dose contrast material at 80 kVp. AJR Am J Roentgenol. 2011;196(6):1324-1331. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 21606296].
Yang DM, Jahng GH, Kim HC, et al. The detection and discrimination of malignant and benign focal hepatic lesions: T2 weighted vs diffusion-weighted MRI. Br J Radiol. 2011;84(1000):319-326. Excluded: Wrong population. [pmid: 20959371].
Yao QJ, Hu HT, Li HL, Guo CY, Meng YL, Li YN. Xper CT in diagnosis and treatment of micro hepatocellular carcinoma. Chinese Journal of Medical Imaging Technology. 2012;28(7):1363-1366. Excluded: Wrong population.
Yaqoob J, Bari V, Usman MU, Munir K, Mosharaf F, Akhtar W. The Evaluation of Hepatocellular Carcinoma with Biphasic Contrast enhanced Helical CT Scan. Journal of the Pakistan Medical Association. 2004;54(3):123-127. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15129870].
Yen Y-H, Wang J-H, Lu S-N, et al. Contrast-enhanced ultrasonographic spoke-wheel sign in hepatic focal nodular hyperplasia. Eur J Radiol. 2006;60(3):439-444. Excluded: Wrong population. [pmid: 16916591].
Yi J, Gwak GY, Sinn DH, et al. Screening for extrahepatic metastases by additional staging modalities is required for hepatocellular carcinoma patients beyond modified UICC stage T1. Hepato Gastroenterology. 2013;60(122):328-332. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 23241421].
Yoo HJ, Lee JM, Lee MW, et al. Hepatocellular carcinoma in cirrhotic liver: double-contrast-enhanced, high-resolution 3.0T-MR imaging with pathologic correlation. Invest Radiol. 2008;43(7):538-546. Excluded: Wrong intervention. [pmid: 18580337].
Yoon J-H, Lee E-J, Cha S-S, et al. Comparison of gadoxetic acid-enhanced MR imaging versus four-phase multi-detector row computed tomography in assessing tumor regression after radiofrequency ablation in subjects with hepatocellular carcinomas. J Vasc Interv Radiol. 2010;21(3):348-356. Excluded: Wrong population. [pmid: 20116285].
Yoon MA, Kim SH, Park HS, et al. Value of dual contrast liver MRI at 3.0 T in differentiating well-differentiated hepatocellular carcinomas from dysplastic nodules: preliminary results of multivariate analysis. Invest Radiol. 2009;44(10):641-649. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19724237].
Yoon SH, Lee JM, So YH, et al. Multiphasic MDCT enhancement pattern of hepatocellular carcinoma smaller than 3 cm in diameter: Tumor size and cellular differentiation. AJR Am J Roentgenol. 2009;193(6):W482-W489. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19933622].
Yoshioka H, Sato J, Takahashi N, et al. Dual double arterial phase dynamic MR imaging with sensitivity encoding (SENSE): which is better for diagnosing hypervascular hepatocellular carcinomas, in-phase or opposed-phase imaging?. Magn Reson Imaging. 2004;22(3):361-367. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 15062931].
Yu DX, Ma XX, Wei HG, Zhang XM, Wang Q, Li CF. Angiogenesis and its maturation of hepatocellular carcinoma and its correlation with the deoxyhemoglobin parameters R2 * and T2 * values by using noninvasive magnetic resonance imaging. Acta Academiae Medicinae Sinicae. 2009;31(5):589-593. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 19968077].
Yu EWR, Chie WC, Chen THH. Does screening or surveillance for primary hepatocellular carcinoma with ultrasonography improve the prognosis of patients?. Cancer J. 2004;10(5):317-325. Excluded: Wrong study design for Key Question. [pmid: 15530261].
Yu JS, Kim KW, Kim YH, Jeong EK, Chien D. Comparison of multishot turbo spin echo and HASTE sequences for T2-weighted MRI of liver lesions. J Magn Reson Imaging. 1998;8(5):1079-1084. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 9786145].
Yu JS, Kim KW, Lee JT, Yoo HS. MR imaging during arterial portography for assessment of hepatocellular carcinoma: comparison with CT during arterial portography. AJR Am J Roentgenol. 1998;170(6):1501-1506. Excluded: Wrong intervention. [pmid: 9609162].
Yu JS, Kim KW, Lee JT, Yoo HS. Focal lesions in cirrhotic liver: comparing MR imaging during arterial portography with Gd-enhanced dynamic MR imaging. Yonsei Med J. 2000;41(5):546-555. Excluded: Wrong population. [pmid: 11079613].
Yu MH, Lee JM, Yoon JH, et al. Low tube voltage intermediate tube current liver MDCT: Sinogram-affirmed iterative reconstruction algorithm for detection of hypervascular hepatocellular carcinoma. AJR Am J Roentgenol. 2013;201(1):23-32. Excluded: Wrong intervention. [pmid: 23789655].
Yucel C, Ozdemir H, Gurel S, Ozer S, Arac M. Detection and differential diagnosis of hepatic masses using pulse inversion harmonic imaging during the liver-specific late phase of contrast enhancement with Levovist. J Clin Ultrasound. 2002;30(4):203-212. Excluded: Wrong population. [pmid: 11981929].
Zacherl J, Scheuba C, Imhof M, et al. Current value of intraoperative sonography during surgery for hepatic neoplasms. World J Surg. 2002;26(5):550-554. Excluded: Wrong intervention. [pmid: 12098044].
Zandrino F, Curone P, Benzi L, Musante F. Value of an early arteriographic acquisition for evaluating the splanchnic vessels as an adjunct to biphasic CT using a multislice scanner. Eur Radiol. 2003;13(5):1072-1079. Excluded: Wrong intervention. [pmid: 12695830].
Zech CJ, Grazioli L, Breuer J, Reiser MF, Schoenberg SO. Diagnostic performance and description of morphological features of focal nodular hyperplasia in Gd-EOB-DTPA-enhanced liver magnetic resonance imaging: results of a multicenter trial. Invest Radiol. 2008;43(7):504-511. Excluded: Wrong population. [pmid: 18580333].
Zhang B, Yang B. Combined alpha fetoprotein testing and ultrasonography as a screening test for primary liver cancer. J Med Screen. 1999;6(2):108-110. Excluded: Wrong population. [pmid: 10444731].
Zhang HP, Du LF, Li F, He YQ. Differential diagnosis of isolated hepatocellular carcinoma and metastatic hepatic carcinoma with contrast-enhanced ultrasonography. Chinese Journal of Medical Imaging Technology. 2009;25(11):2053-2056. Excluded: Wrong outcome/Did not report diagnostic accuracy measures.
Zhang J-W, Feng X-Y, Liu H-Q, et al. CT volume measurement for prognostic evaluation of unresectable hepatocellular carcinoma after TACE. World J Gastroenterol. 2010;16(16):2038-2045. Excluded: Wrong population. [pmid: 20419843].
Zhang K, Kokudo N, Hasegawa K, et al. Detection of new tumors by intraoperative ultrasonography during repeated hepatic resections for hepatocellular carcinoma. Arch Surg. 2007;142(12):1170-1175. Excluded: Wrong intervention. [pmid: 18086983].
Zhang L-J, Peng J, Wu S-Y, et al. Liver virtual non-enhanced CT with dual-source, dual-energy CT: a preliminary study. Eur Radiol. 2010;20(9):2257-2264. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20393717].
Zhang M-G, Huang X-J, Zhu Q, Geng J, Zhang A-J. Relationship between CT grouping and complications of liver cirrhosis. Hepatobiliary Pancreat Dis Int. 2006;5(2):219-223. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 16698579].
Zhang P, Zhou P, Tian SM, Qian Y, Deng J, Zhang L. Application of acoustic radiation force impulse imaging for the evaluation of focal liver lesion elasticity. Hepatobiliary Pancreat Dis Int. 2013;12(2):165-170. Excluded: Inadequate reference standard. [pmid: 23558071].
Zhang R, Qin S, Zhou Y, Song Y, Sun L. Comparison of imaging characteristics between hepatic benign regenerative nodules and hepatocellular carcinomas associated with Budd-Chiari syndrome by contrast enhanced ultrasound. Eur J Radiol. 2012;81(11):2984-2989. Excluded: Wrong population. [pmid: 22341409].
Zhang X, Kanematsu M, Fujita H, et al. Application of an artificial neural network to the computer-aided differentiation of focal liver disease in MR imaging. Radiol Phys Technol. 2009;2(2):175-182. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20821117].
Zheng J, Li J, Cui X, Ye H, Ye L. Comparison of diagnostic sensitivity of C-arm CT, DSA and CT in detecting small HCC. Hepatogastroenterology. 2013;60(126):1509-1512. Excluded: Inadequate reference standard. [pmid: 23665467].
Zhong-Zhen S, Kai L, Rong-Qin Z, et al. A feasibility study for determining ablative margin with 3D-CEUS-CT/MR image fusion after radiofrequency ablation of hepatocellular carcinoma. Ultraschall Med. 2012;33(7):E250-E255. Excluded: Wrong population. [pmid: 23238803].
Zhou JS, Huan Y, Wei MG. Quantitative analysis of hepatocellular adenomas with triphasic contrast enhanced multislice spiral computed tomography (MSCT). Afr J Biotechnol. 2010;9(23):3448-3457. Excluded: Wrong setting.
Zhou JS, Huan Y, Wei MQ, Jiang XQ. Detection of hepatocellular carcinoma with multi-slice spiral CT by using double-arterial phase and portal venous phase enhanced scanning: Effect of iodine concentration of contrast material. Afr J Biotechnol. 2010;9(23):3443-3447. Excluded: Wrong population.
Zhou J-Y, Wong DWK, Ding F, et al. Liver tumour segmentation using contrast-enhanced multi-detector CT data: performance benchmarking of three semiautomated methods. Eur Radiol. 2010;20(7):1738-1748. Excluded: Wrong outcome/Did not report diagnostic accuracy measures. [pmid: 20157817].
Zhu GY, Teng GJ, Guo JH, et al. Application of PET-CT in monitoring residual and extrahepatic metastatic lesions for hepatocellular carcinoma with positive alpha fetoproteins after interventional therapy. Chinese Journal of Radiology. 2010;44(7):726-730. Excluded: Not English language.
Zhuang H, Sinha P, Pourdehnad M, Duarte PS, Yamamoto AJ, Alavi A. The role of positron emission tomography with fluorine-18-deoxyglucose in identifying colorectal cancer metastases to liver. Nuclear Medicine Communications. 2000;21(9):793-798. Excluded: Wrong population. [pmid: 11065150].
Zimmerman P, Lu DS, Yang LY, Chen S, Sayre J, Kadell B. Hepatic metastases from breast carcinoma: comparison of noncontrast, arterial-dominant, and portal-dominant phase spiral CT. J Comput Assist Tomogr. 2000;24(2):197-203. Excluded: Wrong population. [pmid: 10752878].
Zorger N, Jung E-M, Schreyer AG, et al. Ultrasound-arterioportography (US-AP): A new technical approach to perform detection of liver lesions. Clin Hemorheol Microcirc. 2010;46(2–3):117-126. Excluded: Wrong intervention. [pmid: 21135487].
Zuber-Jerger I, Schacherer D, Woenckhaus M, Jung EM, Scholmerich J, Klebl F. Contrast-enhanced ultrasound in diagnosing liver malignancy. Clin Hemorheol Microcirc. 2009;43(1–2):109-118. Excluded: Wrong population. [pmid: 19713605].