# Addendum

Following finalization and posting of the comparative effectiveness review (CER), “Imaging Techniques for the Diagnosis and Staging of Hepatocellular Carcinoma”1 we updated selected portions of the review in preparation for journal manuscript submission. 2 The update focused on the diagnostic accuracy of ultrasound (US), computed tomography (CT), and magnetic resonance imaging (MRI) for detection of hepatocellular carcinoma (HCC) in surveillance and non-surveillance settings and for identification of HCC in patients with a focal liver lesion. We did not update evidence regarding diagnostic accuracy of positron emission tomography (PET), which is not addressed in the journal manuscript, or studies on the diagnostic accuracy of imaging for distinguishing HCC from a specific type of focal liver lesion. The search strategy used for the update was the same as in the original CER, and the update search was conducted in December 2014. Citations from the update search (687) were screened for possible inclusion. Twelve new studies met inclusion criteria and were added for the update.3–14 Two studies addressed diagnostic accuracy of CT,9,11 11 studies addressed MRI,3–12, 14 and 1 study addressed US.13 With the new studies, the total numbers of studies for the update were 68 for CT, 125 for MRI, and 131 for US

Data from the new studies were abstracted (Table 1) and risk of bias was assessed (Table 2) using the same methods as in the original CER. Meta-analyses conducted for the original CER were updated with data from the new included studies.

Overall conclusions with the new studies were unchanged from the original CER, though point estimates and confidence intervals differed slightly (Tables 3, 4, and 5, and Figures 1–14). Updated strength of evidence ratings are shown in Table 6.

Figure 1 Test performance of computed tomography for detection of patients with hepatocellular carcinoma in nonsurveillance settings

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance for studies CT for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 17 studies, with a combined sensitivity of 0.83 (95% confidence interval: 0.75 to 0.89) and the tau-squared value is 0.60, p = 0.01. Specificity was reported or calculated for 17 studies, with a combined specificity of 0.92 (95% confidence interval: 0.86 to 0.96) and the tau-squared value is 0.63, p = 0.02.

Figure 2 Test performance of magnetic resonance imaging for detection of patients with hepatocellular carcinoma in nonsurveillance settings

Abbreviations: CI = confidence interval; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance for studies of MRI for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 14 studies, with a combined sensitivity of 0.86 (95% confidence interval: 0.79 to 0.91) and the tau-squared value is 0.43, p = 0.02. Specificity was reported or calculated for 14 studies, with a combined specificity of 0.89 (95% confidence interval: 0.83 to 0.93) and the tau-squared value is 0.54, p = 0.02.

Figure 3 Test performance of ultrasound without contrast for detection of patients with hepatocellular carcinoma in surveillance settings

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance of ultrasound without contrast for detection of patients with hepatocellular carcinoma in surveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 4 studies, with a combined sensitivity of 0.78 (95% confidence interval: 0.60 to 0.89) and the tau-squared value is 0.52, p = 0.108. Specificity was reported or calculated for 3 studies, with a combined specificity of 0.89 (95% confidence interval: 0.80 to 0.94) and the tau-squared value is 0.26, p = 0.164.

Figure 4 Test performance of ultrasound without contrast for detection of patients with hepatocellular carcinoma in nonsurveillance settings

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance for studies of ultrasound without contrast for detection of patients with hepatocellular carcinoma in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 8 studies, with a combined sensitivity of 0.73 (95% confidence interval: 0.46 to 0.90) and the tau-squared value is 2.35, p = 0.24. Specificity was reported or calculated for 8 studies, with a combined specificity of 0.93 (95% confidence interval: 0.85 to 0.97) and the tau-squared value is 0.78, p = 0.123.

Figure 5 Test performance of ultrasound without contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance for studies of ultrasound without contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 11 studies, with a combined sensitivity of 0.59 (95% confidence interval: 0.42 to 0.74) and the tau-squared value is 1.21, p = 0.005. Specificity was reported or calculated for 11 studies, with a combined specificity of 0.83 (95% confidence interval: 0.53 to 0.95) and the tau-squared value is 3.35, p = 0.075.

Figure 6 Sensitivity of ultrasound with contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings

Abbreviations: CI = confidence interval; P = p-value

This figure is a forest plot that displays the sensitivity of studies of ultrasound with contrast for detection of hepatocellular carcinoma lesions in nonsurveillance settings. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. An overall mixed-effects model was based on 9 studies, with a value of 0.75 (95% confidence interval: 0.57 to 0.88) and the tau-squared value is 1.53, p = 0.006.

Figure 7 Test performance of computed tomography for detection of hepatocellular carcinoma lesions in nonsurveillance settings, sensitivity

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance for studies of CT for detection of hepatocellular carcinoma lesions in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 80 studies, with a combined sensitivity of 0.76 (95% confidence interval: 0.72 to 0.80). Specificity was reported or calculated for 21 studies, with a combined specificity of 0.90 (95% confidence interval: 0.84 to 0.93).

Figure 8 Test performance of magnetic resonance imaging for detection of hepatocellular carcinoma lesions in nonsurveillance settings

Abbreviations: CI= confidence interval; N = number; P = p-value

This figure is a forest plot that displays the test performance for studies of MRI for detection of hepatocellular carcinoma lesions in nonsurveillance settings. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 82 studies, with a combined sensitivity of 0.83 (95% confidence interval: 0.80 to 0.86). Specificity was reported or calculated for 16 studies, with a combined specificity of 0.88 (95% confidence interval: 0.79 to 0.93).

Figure 9 Test performance of ultrasound with contrast in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative, TP=true positive

This figure is a forest plot that displays the test performance of ultrasound with contrast in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 12 studies, with a combined sensitivity of 0.87 (95% confidence interval: 0.079 to 0.92) and the tau-squared value is 0.59, p = 0.0046. Specificity was reported or calculated for 12 studies, with a combined specificity of 0.92 (95% confidence interval: 0.83 to 0.95) and the tau-squared value is 0.62, p = 0.037.

Figure 10 Test performance of computed tomography in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance of CT in evaluation of focal liver lesions for identification of patients with hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 8 studies, with a combined sensitivity of 0.86 (95% confidence interval: 0.75 to 0.92) and the tau-squared value is 0.65 p = 0.036. Specificity was reported or calculated for 8 studies, with a combined specificity of 0.88 (95% confidence interval: 0.76 to 0.95) and the tau-squared value is 0.64, p = 0.083.

Figure 11 Test performance of magnetic resonance imaging in evaluation of focal liver lesions for patients with hepatocellular carcinoma

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative, TP = true positive

This figure is a forest plot that displays the test performance of MRI in evaluation of focal liver lesions for patients with hepatocellular carcinoma. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 5 studies, with a combined sensitivity of 0.75 (95% confidence interval: 0.65 to 0.83) and the tau-squared value is 0.12, p = 0.040. Specificity was reported or calculated for 5 studies, with a combined specificity of 0.83 (95% confidence interval: 0.61 to 0.93).

Figure 12 Test performance of ultrasound with contrast for evaluation of focal liver lesions for identification of hepatocellular carcinoma lesions

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative, TP = true positive

This figure is a forest plot that displays the test performance of ultrasound with contrast for evaluation of focal liver lesions for identification of hepatocellular carcinoma lesions. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 23 studies, with a combined sensitivity of 0.87 (95% confidence interval: 0.80 to 0.92) and the tau-squared value is 1.19, p < 0.0001. Specificity was reported or calculated for 11 studies, with a combined specificity of 0.91 (95% confidence interval: 0.85 to 0.95) and the tau-squared value is 0.51, p = 0.012.

Figure 13 Test performance of computed tomography in evaluation of focal liver lesions for hepatocellular carcinoma lesions

Abbreviations: CI = confidence interval; N = number; P = p-value; TN = true negative; TP = true positive

This figure is a forest plot that displays the test performance of CT in evaluation of focal liver lesions for hepatocellular carcinoma lesions. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 13 studies, with a combined sensitivity of 0.79 (95% confidence interval: 0.67 to 0.87) and the tau-squared value is 0.97, p = 0.001. Specificity was reported or calculated for 6 studies, with a combined specificity of 0.90 (95% confidence interval: 0.37 to 0.99) and the tau-squared value is 4.39, p = 0.110.

Figure 14 Test performance of magnetic resonance imaging in evaluation of focal liver lesions for hepatocellular carcinoma lesion

Abbreviations: CI = confidence interval; N = number; P = p-value

This figure is a forest plot that displays the test performance of MRI in evaluation of focal liver lesions for hepatocellular carcinoma lesions. There is a graph of sensitivity on the left and a graph of specificity on the right. The individual studies are depicted as horizontal lines with a square. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The combined sensitivity and specificity values are represented by diamonds at the bottom each graph. Sensitivity was reported or calculated for 14 studies, with a combined sensitivity of 0.81 (95% confidence interval: 0.73 to 0.88. Specificity was reported or calculated for 11 studies, with a combined specificity of 0.92 (95% confidence interval: 0.78 to 0.97).

Table 1 Evidence Tables Data Extraction

### Diagnostic Accuracy Studies of Ultrasound Imaging

Table 1a Characteristics of diagnostic accuracy studies of ultrasound imaging

Author, Year | Reason for Ultrasound Imaging^a^ | Contrast | Imaging Start Date | Reference Standard^b^ | Country | Sample Size | Population Characteristics^c^
Zhang, 2014^1^ | 2 | Sulfur hexaluoride (Sonovue) | 2013 | 2 | China | 69 | Age: 53 | Male: 80% | HBV: 91% | Cirrhosis: NR

HBV = hepatitis B virus; NR = not reported

a Reason for imaging key: 1=surveillance, 2=detection rate in patients undergoing surgery or with known HCC; 3=evaluation/characterization of liver mass; 4=differentiation between HCC and another type of lesion mass; 5=staging

b Reference standard key: 1=explanted livers only, 2=histological specimen (may include some explanted livers), 3=imaging and clinical criteria, 4=mixed histological and imaging/clinical criteria

c Age reported as mean (years), unless otherwise indicated

### Diagnostic Accuracy Studies of Computed Tomography Imaging

Table 1b Characteristics of diagnostic accuracy studies of computed tomography imaging

Author, Year | Reason for CT Imaging^a^ | Scanner Type | Contrast Rate (ml/s) | Delayed Phase? | Delayed Phase Timing ≥120 s^b^ | Section Thickness (mm) | Did study meet all imaging criteria?^c^ | Imaging Start Date | Reference Standard^d^ | Country | Number of Patients | Population Characteristics^e^
Maiwald 2014^2^ | 3 | 8-row multidetector | 3 | No | NA | [underlined: 3] | No | NR | 4 | Germany | 50 | Age: 61 | Male: 84 %
Maiwald 2014^2^ | 3 | 8-row multidetector | 3 | No | NA | [underlined: 3] | No | NR | 4 | Germany | 50 | HBV: 4% | Cirrhosis: 100%
Park VY, 2014^3^ | 3 | 8-row multidetector | 3 | Yes | Yes | [underlined: 2] | Yes | 2008 | 2 | Korea | 55 | Age: 55 | Male: 80%
Park VY, 2014^3^ | 3 | 8-row multidetector | 3 | Yes | Yes | [underlined: 2] | Yes | 2008 | 2 | Korea | 55 | HBV: 89% | Cirrhosis: 69%

CT = computed tomography; HBV = hepatitis B virus; ml = milliliters; mm = millimeters; NA = not applicable; NR = not reported; s = second

a Reason for CT imaging key: 1=surveillance; 2=detection rate in patients undergoing surgery or with known HCC; 3=evaluation/characterization of liver mass; 4=differentiation between HCC and another type of lesion; 5=staging

b Delayed phase reported as time after contrast injection

c Imaging criteria = multidetector CT >=8 rows; contrast rate >3 ml/s; included delayed phase imaging; timing of delayed phase imaging >=120 s after contrast injection; enhanced imaging section thickness <=5 mm

d Reference standard key: 1=explanted livers only, 2=histological specimen (may include some explanted livers), 3=imaging and clinical criteria, 4=mixed histological and imaging/clinical criteria

e Age reported as mean (years), unless otherwise noted

### Diagnostic Accuracy Studies of Magnetic Resonance Imaging

Table 1c Characteristics of diagnostic accuracy studies of magnetic resonance imaging

Author, Year | Reason for MRI Imaging^a^ | Scanner Type | Contrast, Rate | Delayed phase? | Delayed Phase Timing ≥120 s^b^ | Section Thickness (mm) | Did study meet all imaging criteria?^c^ | Imaging Start Date | Reference Standard^d^ | Country | Number of Patients | Population Characteristics^e^
Donati, 2014^4^ | 1 | 1.5 T | Gadoxetic acid, rate not reported | Yes | Yes | [underlined: 3–7] | No | 2006 | 2 | Europe, New Zealand, U.S. | 29 | Age: 39 | Male: 38%
Donati, 2014^4^ | 1 | 1.5 T | Gadoxetic acid, rate not reported | Yes | Yes | [underlined: 3–7] | No | 2006 | 2 | Europe, New Zealand, U.S. | 29 | HBV: 8% | Cirrhosis: NR
Hanna, 2014^5^ | 3 | 1.5 T | Gadobenate, 2 ml/s | Yes | Yes | [underlined: 3] | Yes | 2006 | 1 | U.S. | 87 | Age: 54 | Male: 71%
Hanna, 2014^5^ | 3 | 1.5 T | Gadobenate, 2 ml/s | Yes | Yes | [underlined: 3] | Yes | 2006 | 1 | U.S. | 87 | HBV: 6.9% | Cirrhosis: 100%
Hwang J, 2014^6^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2008 | 1 | Korea | 63 | Age: 52 | Male: 86%
Hwang J, 2014^6^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2008 | 1 | Korea | 63 | HBV: 79% | Cirrhosis:86%
Kim MY, 2014^7^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2010 | 2 | Korea | 176 | Age: 59 | Male: 58%
Kim MY, 2014^7^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2010 | 2 | Korea | 176 | HBV: NR | Cirrhosis: NR
Kim YK, 2014^8^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2010 | 2 | Korea | 157 | Age: 57 | Male: 71%
Kim YK, 2014^8^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2010 | 2 | Korea | 157 | HBV: 89% | Cirrhosis: NR
Kwon, 2014^9^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2013 | 2 | Korea | 144 | Age: 57 | Male: 71%
Kwon, 2014^9^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2013 | 2 | Korea | 144 | HBV: 72% | Cirrhosis: 93%
Maiwald, 2014^2^ | 3 | 3.0 T | Gadoxetic acid, 2 ml/s | Yes | Yes | [underlined: 3] | Yes | 2011 | 4 | Germany | 50 | Age: 61 | Male: 84%
Maiwald, 2014^2^ | 3 | 3.0 T | Gadoxetic acid, 2 ml/s | Yes | Yes | [underlined: 3] | Yes | 2011 | 4 | Germany | 50 | HBV: 4% | Cirrhosis: 100%
Park MJ, 2013^10^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2009 | 2 | Korea | 260 | Age: 56 | Male: 71 %
Park MJ, 2013^10^ | 3 | 3.0 T | Gadoxetic acid, 1 ml/s | Yes | Yes | [underlined: 2] | Yes | 2009 | 2 | Korea | 260 | HBV: NR | Cirrhosis: NR
Park VY, 2014^3^ | 3 | 3.0 T | Gadoxetic acid, 2 ml/s | Yes | Yes | [underlined: 2] | Yes | 2008 | 2 | Korea | 55 | Age: 55 | Male: 80%
Park VY, 2014^3^ | 3 | 3.0 T | Gadoxetic acid, 2 ml/s | Yes | Yes | [underlined: 2] | Yes | 2008 | 2 | Korea | 55 | HBV: 89% | Cirrhosis: 69%
Yu MH, 2014^11^ | 3 | 1.5 or 3.0 T | Gadoxetic acid, 1 or 1.5 ml/s | Yes | Yes | [underlined: 3–6] | No | 2009 | 4 | Korea | 90 | Age: 60 | Male: 93%
Yu MH, 2014^11^ | 3 | 1.5 or 3.0 T | Gadoxetic acid, 1 or 1.5 ml/s | Yes | Yes | [underlined: 3–6] | No | 2009 | 4 | Korea | 90 | HBV: NR | Cirrhosis: NR
Zhao, 2014^12^ | 3 | 3.0 T | Gadoxetic acid, 1.5 ml/s | Yes | Yes | [underlined: 5] | Yes | 2011 | 2 | China | 33 | Age: 54 | Male: 82%
Zhao, 2014^12^ | 3 | 3.0 T | Gadoxetic acid, 1.5 ml/s | Yes | Yes | [underlined: 5] | Yes | 2011 | 2 | China | 33 | HBV: 82% | Cirrhosis: 100%

HBV = hepatitis B virus; ml = milliliters; mm = millimeters; MRI = magnetic resonance imaging; NR = not reported; s = second; T = tesla

a Reason for MRI imaging key: 1=surveillance; 2=detection rate in patients undergoing surgery or with known HCC; 3=evaluation/characterization of liver mass; 4=differentiation between HCC and another type of lesion; 5=staging

b Delayed phase reported as time after gadolinium contrast injection

c Imaging criteria = 1.5 or 3.0 T MRI; included delayed phase imaging (or hepatobiliary for gadobenate or gadoxetic acid contrast); timing of delayed phase imaging >=120 s after contrast injection; enhanced imaging section thickness < =5 mm

d Reference standard key: 1=explanted livers only; 2=histological specimen (may include some explanted livers); 3=imaging and clinical criteria; 4=mixed histological and imaging/clinical criteria

e Age reported as mean (years), unless otherwise noted

#### References

1 Zhang X-Y, Luo Y, Wen T-F, et al. Contrast-enhanced ultrasound: improving the preoperative staging of hepatocellular carcinoma and guiding individual treatment. World J Gastroenterol. Sep. 21. 2014;20(3):12628-36. [pmid: 25253968].
2 Maiwald B, Lobsien D, Kahn T, et al. Is 3-Tesla Gd-EOB-DTPA-enhanced MRI with diffusion-weighted imaging superior to 64-slice contrast-enhanced CT for the diagnosis of hepatocellular carcinoma?. PLoS ONE. Nov. 6. 2014;9(11):e111935. [pmid: 25375778].
3 Park VY, Choi J-Y, Chung YE, Kim H, Park M-S, Lim JS, et al. Dynamic enhancement pattern of HCC smaller than 3 cm in diameter on gadoxetic acid-enhanced MRI: comparison with multiphasic MDCT. Liver Int. Nov. 2014;34(10):1593-602. [pmid: 24673802].
4 Donati OF, Hunziker R, Fischer MA, et al. MRI for characterization of primary tumors in the non-cirrhotic liver: added value of Gd-EOB-DTPA enhanced hepatospecific phase. Eur J Radiol. Jul. 2014;83(7):1074-9. [pmid: 24816085].
5 Hanna RF, Ward TJ, Chow DS, et al. An evaluation of the sensitivity of MRI at detecting hepatocellular carcinoma in cirrhotic patients utilizing an explant reference standard. Clin Imaging. Sep–Oct. 2014;38(5):693-7. [pmid: 24997104].
6 Hwang J, Kim YK, et al. Pretransplant diagnosis of hepatocellular carcinoma by gadoxetic acid-enhanced and diffusion-weighted magnetic resonance imaging. Liver Transpl. Dec. 2014;20(12):1436-46. [pmid: 25103727].
7 Kim MY, Kim YK, Park HJ, et al. Diagnosis of focal liver lesions with gadoxetic acid-enhanced MRI: is a shortened delay time possible by adding diffusion-weighted imaging?. J Magn Reson Imaging. Jan. 2014;39(1):31-41. [pmid: 24115329].
8 Kim YK, Kim YK, Park HJ, et al. Noncontrast MRI with diffusion-weighted imaging as the sole imaging modality for detecting liver malignancy in patients with high risk for hepatocellular carcinoma. Magn Reson Imaging. Jul. 2014;32(6):610-8. [pmid: 24702980].
9 Kwon S, Kim YK, Park HJ, et al. Is gadoxetic acid-enhanced MRI limited in tumor characterization for patients with chronic liver disease?. Magn Reson Imaging. Dec. 2014;32(10):1214-22. [pmid: 25192607].
10 Park MJ, Kim YK, Lee MW, et al. Small hepatocellular carcinomas: improved sensitivity by combining gadoxetic acid-enhanced and diffusion-weighted MR imaging patterns. Radiology. Sep. 2012;264(3):761-70. [pmid: 22843769].
11 Yu MH, Kim JH, Yoon J-H, Kim H-C, Chung JW, Han JK, et al. Small (<1-cm) hepatocellular carcinoma: diagnostic performance and imaging features at gadoxetic acid-enhanced MR imaging. Radiology. Jun. 2014;271(3):748-60. [pmid: 24588677].
12 Zhao XT, Li WX, Chai WM, et al. Detection of small hepatocellular carcinoma using gadoxetic acid-enhanced MRI: Is the addition of diffusion-weighted MRI at 3.0T beneficial?. J Dig Dis. Mar. 2014;15(3):137-45. [pmid: 24354621].

Table 2 Risk of bias: Diagnostic studies

Author, Year | Random or Consecutive Sample | Avoidance of Case-control Design | Avoidance of Inappropriate Exclusions | Index Test Results Interpreted Without Knowledge of Reference Standard | Use of Pre-specified Threshold or Definition for a Positive Test | Credible Reference Standard | Reference Standard Interpreted Independently from the Test Under Evaluation | Appropriate Interval Between Index Test and Reference Standard | Same Reference Standard Applied to All Patients | Were all patients included in the analysis? | Overall Quality/Risk of Bias(Low, Moderate, High)
Donati, 2014^1^ | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Moderate
Hanna, 2014^2^ | Unclear | Yes | Yes | No | Yes | Yes | Unclear | Yes | Yes | Yes | Moderate
Hwang, 2014^3^ | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Low
Kim MY, 2014^4^ | Yes | No (cases only) | Yes | Yes | Yes | Yes | Unclear | Yes | No | Yes | Moderate
Kwon S, 2014^5^ | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Moderate
Maiwold, 2014^6^ | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | No | Yes | Moderate
Park MJ, 2012^7^ | Yes | No (case-control) | Yes | Yes | Yes | Yes | Unclear | Yes | No | Yes | Moderate
Park VY, 2014^8^ | Yes | No (all cases) | Yes | Unclear | Yes | Yes | Unclear | Yes | No | Yes | Moderate
Yu MH, 2014^9^ | Unclear | No (case-control) | Yes | Yes | Unclear | Yes | Unclear | Yes | No | Yes | Moderate
Zhang, 2014^10^ | Yes | No (all cases) | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Moderate
Zhao, 2014^11^ | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Moderate

### References

1 Donati OF, Hunziker R, Fischer MA, et al. MRI for characterization of primary tumors in the non-cirrhotic liver: added value of Gd-EOB-DTPA enhanced hepatospecific phase. Eur J Radiol. Jul. 2014;83(7):1074-9. [pmid: 24816085].
2 Hanna RF, Ward TJ, Chow DS, et al. An evaluation of the sensitivity of MRI at detecting hepatocellular carcinoma in cirrhotic patients utilizing an explant reference standard. Clin Imaging. Sep–Oct. 2014;38(5):693-7. [pmid: 24997104].
3 Hwang J, Kim YK, et al. Pretransplant diagnosis of hepatocellular carcinoma by gadoxetic acid-enhanced and diffusion-weighted magnetic resonance imaging. Liver Transpl. Dec. 2014;20(12):1436-46. [pmid: 25103727].
4 Kim MY, Kim YK, Park HJ, et al. Diagnosis of focal liver lesions with gadoxetic acid-enhanced MRI: is a shortened delay time possible by adding diffusion-weighted imaging?. J Magn Reson Imaging. Jan. 2014;39(1):31-41. [pmid: 24115329].
5 Kwon S, Kim YK, Park HJ, et al. Is gadoxetic acid-enhanced MRI limited in tumor characterization for patients with chronic liver disease?. Magn Reson Imaging. Dec. 2014;32(10):1214-22. [pmid: 25192607].
6 Maiwald B, Lobsien D, Kahn T, et al. Is 3-Tesla Gd-EOB-DTPA-enhanced MRI with diffusion-weighted imaging superior to 64-slice contrast-enhanced CT for the diagnosis of hepatocellular carcinoma?. PLoS ONE. Nov. 6. 2014;9(11):e111935. [pmid: 25375778].
7 Park MJ, Kim YK, Lee MW, et al. Small hepatocellular carcinomas: improved sensitivity by combining gadoxetic acid-enhanced and diffusion-weighted MR imaging patterns. Radiology. Sep. 2012;264(3 Issue):761-70. [pmid: 22843769].
8 Park VY, Choi J-Y, Chung YE, Kim H, Park M-S, Lim JS, et al. Dynamic enhancement pattern of HCC smaller than 3 cm in diameter on gadoxetic acid-enhanced MRI: comparison with multiphasic MDCT. Liver Int. Nov. 2014;34(10):1593-602. [pmid: 24673802].
9 Yu MH, Kim JH, Yoon J-H, Kim H-C, Chung JW, Han JK, et al. Small (<1-cm) hepatocellular carcinoma: diagnostic performance and imaging features at gadoxetic acid-enhanced MR imaging. Radiology. Jun. 2014;271(3):748-60. [pmid: 24588677].
10 Zhang X-Y, Luo Y, Wen T-F, et al. Contrast-enhanced ultrasound: improving the preoperative staging of hepatocellular carcinoma and guiding individual treatment. World J Gastroenterol. Sep. 21. 2014;20(3):12628-36. [pmid: 25253968].
11 Zhao XT, Li WX, Chai WM, et al. Detection of small hepatocellular carcinoma using gadoxetic acid-enhanced MRI: Is the addition of diffusion-weighted MRI at 3.0T beneficial?. J Dig Dis. Mar. 2014;15(3):137-45. [pmid: 24354621].

Table 3 Test performance of ultrasound imaging for identification and diagnosis of hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of HCC (KQ 1)
Surveillance settings
Ultrasound without contrast | Patient | 0.78 (0.60 to 0.89); 0.52 (p=0.11) | 4 | 0.89 (0.80 to 0.94); 0.26 (p=0.16) | 3 | 6.8 (4.2 to 11) | 0.25 (0.13 to 0.46)
| Lesion | 0.60 (0.24 to 0.87) | 1 | No data | -- | -- | --
Nonsurveillance settings
Ultrasound without contrast | Patient | 0.73 (0.46 to 0.90); 2.3 (p=0.02) | 8 | 0.93 (0.85 to 0.97); 0.78 (p=0.12) | 6 | 11 (5.4 to 21) | 0.29 (0.13 to 0.65)
- Excluding Doppler | | 0.77 (0.48 to 0.93); 2.5 (p=0.04) | 7 | 0.92 (0.82 to 0.97); 0.70 (p=0.14) | 5 | 9.8 (4.7 to 21) | 0.25 (0.09 to 0.64)
- Prospective design | | 0.97 (0.68 to 0.998); 1.3 (p=0.02) | 2 | 0.73 (0.45 to 0.90) | 1 | 3.6 (1.5 to 8.5) | 0.04 (0.003 to 0.59)
- Reference standard: Explanted liver | | 0.48 (0.35 to 0.61); 0.17 (p=0.08) | 5 | 0.96 (0.94 to 0.97); <0.0001 (p=0.97) | 5 | 12 (7.4 to 19) | 0.54 (0.42 to 0.70)
- Reference standard: Histopathological, non-explant | | 0.95 (0.87 to 0.98) | 3 | 0.73 (0.47 to 0.90) | 1 | 3.6 (1.5 to 8.2) | 0.07 (0.03 to 0.19)
- United States or Europe | | 0.70 (0.37 to 0.91); 1.9 (p=0.02) | 5 | 0.93 (0.84 to 0.97); 0.51 (p=0.13) | 4 | 10 (4.9 to 21) | 0.32 (0.12 to 0.83)
- Excluding poor quality studies | | 0.77 (0.48 to 0.93); 2.5 (p=0.04) | 7 | 0.92 (0.82 to 0.97); 0.70 (p=0.14) | 5 | 9.8 (4.7 to 21) | 0.25 (0.09 to 0.64)
- Avoided case-control design | | 0.54 (0.38 to 0.70); 0.44 (p=0.09) | 6 | 0.95 (0.91 to 0.97); 0.41 (p=0.16) | 6 | 11 (6.1 to 19) | 0.48 (0.34 to 0.68
- Blinded interpretation of imaging | | 0.75 (0.33 to 0.95); 2.0 (p=0.02) | 3 | 0.94 (0.81 to 0.98); 0.51 (p=0.13) | 2 | 12 (4.4 to 33) | 0.27 (0.07 to 0.97)
| Lesion | 0.59 (0.42 to 0.74); 1.2 (p=0.005) | 11 | 0.83 (0.53 to 0.95); 3.4 (p=0.07) | 2 | 3.4 (1.2 to 9.4) | 0.50 (0.37 to 0.66)
- HCC lesions <2–3 cm | | 0.75 (0.72 to 0.78); <0.0001 (p=1.0) | 2 | No data | -- | -- | --
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.54 (0.35 to 0.73); 1.3 (p=0.01) | 9 | 0.86 (0.55 to 0.97); 3.5 (p=0.09) | 2 | 4.0 (1.2 to 13) | 0.53 (0.38 to 0.73)
- Excluding Doppler | | 0.50 (0.30 to 0.71); 1.2 (p=0.02) | 7 | 0.95 (95% CI 0.85 to 0.99) | 1 | Not calculated | Not calculated
- Reference standard: Explanted liver | | 0.34 (0.22 to 0.47); 0.28 (p=0.06) | 5 | Insufficient data | -- | -- | --
- Reference standard: Histopathological, non-explant | | 0.75 (0.58 to 0.86) | 3 | Insufficient data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical criteria | | 0.72 (0.46 to 0.88) | 1 | Insufficient data | -- | -- | --
- Prospective | | 0.78 (0.55 to 0.91); 0.61 (p=0.02) | 3 | Insufficient data | -- | -- | --
- U.S. or Europe | | 0.66 (0.35 to 0.87); 1.3 (p=0.01) | 4 | Insufficient data | -- | -- | --
- Avoided case-control design | | 0.43 (0.22 to 0.68); 1.2 (p=0.01) | 5 | Insufficient data | -- | -- | --
- Blinded interpretation of imaging | | 0.67 (0.44 to 0.84); 1.0 (p=0.02) | 5 | Insufficient data | -- | -- | --
Ultrasound with contrast | Lesion | 00.75 (0.57 to 0.88); 1.5 (p=0.006) | 9 | 0.97 (0.84 to 0.999) | 1 | -- | --
- All HCC lesions <2–3 cm | | 0.63 (0.35 to 0.84); 0.89 (p=0.16) | 3 | No data | -- | -- | --
- No Doppler | | 0.78 (0.50 to 0.92); 1.9 (p=0.05) | 5 | No data | -- | -- | --
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.80 (0.58 to 0.92); 1.6 (p=0.03) | 6 | 0.97 (0.84 to 0.999) | 1 | -- | --
- Contrast: Perflubutane | | 0.85 (0.63 to 0.95); 1.4 (p=0.03) | 4 | No data | -- | -- | --
- Contrast: Sulfur hexafluoride | | 0.67 (0.27 to 0.92) | 2 | 0.97 (0.84 to 0.999) | 1
- Reference standard: Histopathological, non-explant | | 0.73 (0.54 to 0.86); 0.77 (p=0.03) | 5 | 0.97 (0.84 to 0.999) | 1 | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.98 (0.84 to 0.998) | 1 | No data | -- | -- | --
- Prospective | | 0.34 (95% CI 0.09 to 0.71); 0.57 (p=0.05) | 1 | 0.97 (0.84 to 0.999) | 1 | -- | --
- United States or Europe | | 0.34 (95% CI 0.09 to 0.72); 0.63 (p=0.05) | 1 | 0.97 (0.84 to 0.999) | 1 | -- | --
- Excluding high risk of bias studies | | 0.74 (0.46 to 0.90); 1.4 (p=0.03) | 4 | 0.97 (0.84 to 0.999) | 1 | -- | --
- Avoided case-control design | | No data | 0 | 0.97 (0.84 to 0.999) | 1 | -- | --
- Blinded interpretation of imaging | | 0.82 (0.59 to 0.94); 1.6 (p=0.03) | 5 | 0.97 (0.84 to 0.999) | 1 | -- | --
| Liver segment | 0.79 (0.62 to 0.89); 1.6 (p=0.0006) | 2 | 0.95 (0.84 to 0.99); 0.74 (p=0.04) | 2 | 17 (4.7 to 60) | 0.22 (0.12 to 0.42)
Evaluation of focal liver lesions (KQ 2)
Ultrasound without contrast | Patient | 0.78 (0.69 to 0.86) | 1 | No data | -- | -- | --
Ultrasound with contrast | Patient | 0.87 (0.79 to 0.92); 0.59 (p=0.005) | 12 | 0.91 (0.83 to 0.95); 0.62 (p=0.04) | 8 | 9.6 (5.1 to 18) | 0.14 (0.09 to 0.23)
- HCC lesions <2–3 cm | | 0.79 (0.56 to 0.92); 0.90 (p=0.18) | 4 | 0.91 (0.74 to 0.97); 0.88 (p=0.26) | 4 | 8.6 (2.9 to 26) | 0.23 (0.10 to 0.53)
- Excluding Doppler | | 0.90 (0.85 to 0.93); 0.02 (p=0.60) | 6 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 10 (5.0 to 21) | 0.11 (0.07 to 0.16)
- Excluding studies restricted to hypervascular HCC | | 0.87 (0.78 to 0.92); 0.65 (p=0.007) | 11 | 0.91 (0.83 to 0.95); 0.62 (p=0.04) | 8 | 9.6 (5.1 to 18) | 0.15 (0.09 to 0.25)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.90 (0.86 to 0.93); 0.02 (p=0.76) | 8 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 10 (5.0 to 21) | 0.11 (0.08 to 0.16)
- Contrast: sulfur hexafluoride | | 0.87 (0.82 to 0.91); 0.02 (p=0.59) | 6 | 0.92 (0.78 to 0.97); 0.42 (p=0.10) | 2 | 11 (3.7 to 31) | 0.14 (0.10 to 0.20)
- Contrast: perflubutane | | 0.95 (0.89 to 0.97) | 2 | 0.92 (0.78 to 0.97) | 2 | 12 (3.9 to 35) | 0.06 (0.03 to 0.13)
- Reference standard: Histopathological, non-explant | | 0.91 (0.84 to 0.95); 0.06 (p=0.39) | 4 | 0.87 (0.61 to 0.97); 0.41 (p=0.09) | 1 | 7.0 (1.9 to 25) | 0.11 (0.06 to 0.20)
- Reference standard: Mixed histological and imaging/clinical criteria | | 0.89 (0.83 to 0.93) | 4 | 0.93 (0.83 to 0.97) | 3 | 12 (5.0 to 29) | 0.12 (0.07 to 0.19)
- Prospective Design | | 0.87 (0.82 to 0.91); 0.02 (p=0.59) | 6 | 0.92 (0.78 to 0.97); 0.42 (p=0.10) | 2 | 11 (3.7 to 31) | 0.14 (0.10 to 0.20)
- United States or Europe | | 0.87 (0.82 to 0.91); 0.02 (p=0.59) | 6 | 0.92 (0.78 to 0.97); 0.42 (p=0.10)) | 2 | 11 (3.7 to 31) | 0.14 (0.10 to 0.20)
- Excluding high risk of bias studies | | 0.89 (0.84 to 0.93); 0.03 (p=0.73) | 6 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 10 (4.9 to 21) | 0.12 (0.07 to 0.18)
- Avoided case-control design | | 0.90 (0.86 to 0.93); 0.02 (p=0.61) | 6 | 0.91 (0.83 to 0.96); 0.41 (p=0.10) | 4 | 11 (5.1 to 22) | 0.11 (0.07 to 0.16)
- Blinded interpretation of imaging | | 0.92 (0.87 to 0.95); 0.03 (p=0.54) | 5 | 0.94 (0.89 to 0.96); 0.05 (p=0.51) | 3 | 14 (8.1 to 26) | 0.09 (0.06 to 0.14)
- Used confidence rating scale | | 0.93 (0.83 to 0.97) | 1 | 0.89 (0.65 to 0.97) | 1 | 8.5 (2.2 to 33) | 0.08 (0.03 to 0.21)
Ultrasound without contrast | Lesion | 0.62 (0.18 to 0.93); 3.7 (p=0.19) | 4 | 0.92 (0.84 to 0.96); 0.16 (p=0.34) | 3 | 8.1 (3.6 to 18) | 0.41 (0.12 to 1.4)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.76 (0.14 to 0.98); 5.4 (p=0.36) | 3 | 0.91 (0.78 to 0.97); 0.14 (p=0.54) | 2 | 8.5 (3.2 to 22) | 0.26 (0.03 to 2.4)
Ultrasound with contrast | | 0.87 (0.80 to 0.92); 1.2 (p<0.0001) | 21 | 0.91 (0.85 to 0.95); 0.51 (p=0.01) | 10 | 9.8 (5.7 to 17) | 0.14 (0.09 to 0.23)
- HCC lesions <2–3 cm | | 0.73 (0.55 to 0.85); 0.997 (p=0.02) | 7 | 0.92 (0.81–0.97); 0.95 (p=0.07) | 6 | 8.7 (4.1 to 18) | 0.30 (0.18 to 0.51)
- Excluding studies restricted to hypervascular HCC | | 0.87 (0.79 to 0.92); 1.3 (p<0.0001) | 20 | 0.91 (0.85 to 0.95); 0.52 (p=0.01) | 10 | 9.8 (5.7 to 17) | 0.15 (0.09 to 0.24)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.91 (0.86 to 0.95); 0.59 (p=0.002) | 14 | 0.93 (0.88 to 0.96); 0.05 (p=0.38) | 4 | 14 (7.7 to 24) | 0.09 (0.06 to 0.15)
- Contrast: sulfur hexafluoride | | 0.91 (0.84 to 0.96); 0.53 (p=0.003) | 7 | No data; 0.03 (p=0.34) | -- | -- | --
- Contrast: perflubutane | | 0.86 (0.67 to 0.95) | 2 | 0.92 (0.87 to 0.96) | 2 | 11 (5.8 to 22) | 0.15 (0.06 to 0.40)
- Contrast: galactose | | 0.94 (0.85 to 0.97) | 4 | 0.95 (0.86 to 0.98) | 2 | 19 (6.2 to 61) | 0.07 (0.03 to 0.17)
- Reference standard: Histological specimen | | 0.94 (0.88 to 0.97); 0.54 (p=0.002) | 6 | 0.95 (0.86 to 0.98); 0.03 (p=0.34) | 2 | 20 (6.3 to 61) | 0.06 (0.03 to 0.13)
- Reference standard: Mixed histological and imaging/clinical criteria | | 0.89 (0.81 to 0.94) | 8 | 0.93 (0.87 to 0.96) | 2 | 12 (6.5 to 23) | 0.12 (0.07 to 0.22)
- Prospective design | | 0.91 (0.85 to 0.95); 0.58 (p=0.002) | 8 | 0.93 (0.88 to 0.96); 0.05 (p=0.36) | 2 | 14 (7.7 to 24) | 0.09 (0.05 to 0.17)
- United States or Europe | | 0.94 (0.87 to 0.97); 0.53 (p=0.002) | 5 | No data | -- | -- | --
- Excluding Doppler | | 0.90 (0.85 to 0.94); 0.57 (p=0.002) | 12 | 0.93 (0.88 to 0.96); 0.05 (p=0.38) | 4 | 13 (7.6 to 24) | 0.10 (0.06 to 0.17)
- Excluding high risk of bias studies | | 0.91 (0.85 to 0.95); 0.59 (p=0.002) | 10 | 0.93 (0.88 to 0.96); 0.05 (p=0.38) | 4 | 14 (7.7 to 24) | 0.09 (0.05 to 0.17)
- Avoided case-control design | | 0.90 (0.83 to 0.94); 0.55 (p=0.002) | 10 | 0.92 (0.87 to 0.96); 0.03 (p=0.49) | 3 | 12 (6.6 to 21) | 0.11 (0.06 to 0.19)
- Blinded interpretation of imaging | | 0.92 (0.84 to 0.96); 0.60 (p=0.002) | 7 | 0.93 (0.86 to 0.96); 0.03 (p=0.48) | 2 | 12 (6.5 to 23) | 0.09 (0.05 to 0.18)
- Used confidence rating scale | | No studies | 0 | No studies | 0 | -- | --
Lesion depth <53, <60, or <85 mm | | 0.87 (0.80–0.92); <0.0001 (p=1.0) | 3 | Insufficient data | -- | -- | --
- >53, >60, or >85 mm | | 0.83 (0.74 to 0.90) | 3 | Insufficient data | -- | -- | --
Body mass index <23 or <25 | | 0.80 (0.70–0.88); 0.11 (p=0.37) | 2 | Insufficient data | -- | -- | --
- >23 or >25 | | 0.80 (0.70–0.87) | 2 | Insufficient data | -- | -- | --

CI = confidence interval; cm = centimeters; HCC = hepatocellular carcinoma; KQ = Key Question; LR+ = positive likelihood ratio; LR− = negative likelihood ratio; mm = millimeters

Table 4 Test performance of computed tomography imaging for identification of intrahepatic and extrahepatic hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of HCC (KQ 1)
Surveillance settings | Patient | 0.84 (0.59 to 0.95); 0.50 (p=0.74) | 2 | 0.99 (0.86 to 0.999); 1.1 (p=0.97) | 2 | 60 (5.9 to 622) | 0.16 (0.06 to 0.47)
| Lesion | 0.62 (0.46 to 0.76) | 1 | Insufficient data | -- | -- | --
Nonsurveillance settings | Patient | 0.83 (0.76 to 0.88); 0.52 (p=0.007) | 17 | 0.91 (0.84 to 0.95); 0.65 (p=0.01) | 12 | 9.1 (5.1 to 16) | 0.19 (0.13 to 0.27)
- Excluding studies restricted to hypervascular HCC | | 0.84 (0.78 to 0.89); 0.37 (p=0.03) | 16 | 0.91 (0.84 to 0.95); 0.64 (p=0.01) | 12` | 9.2 (5.0 to 17) | 0.17 (0.12 to 0.25)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.83 (0.76 to 0.88); 0.52 (p=0.007) | 17 | 0.91 (0.84 to 0.95); 0.65 (p=0.01) | 12 | 9.1 (5.1 to 16) | 0.19 (0.13 to 0.27)
- CT type: Multidetector, ≥8 rows | | 0.87 (0.72 to 0.95); 0.49 (p=0.01) | 3 | 0.77 (0.45 to 0.93); 0.37 (p=0.08) | 1 | 3.7 (1.2 to 11) | 0.17 (0.06 to 0.44)
- CT type: Multidetector, <8 rows | | 0.89 (0.69 to 0.97) | 2 | 0.98 (0.89 to 0.995) | 1 | 36 (6.9 to 184) | 0.11 (0.04 to 0.36)
- CT type: Non-multidetector | | 0.82 (0.71 to 0.89) | 11 | 0.90 (0.83 to 0.94) | 9 | 8.1 (4.6 to 14) | 0.21 (0.13 to 0.33)
- Contrast rate: ≥3 ml/s | | 0.86 (0.78 to 0.92); 0.37 (p=0.05) | 9 | 0.88 (0.80 to 0.93); 0.36 (p=0.07) | 8 | 7.1 (4.1 to 12) | 0.16 (0.10 to 0.26)
- Contrast rate: <3 ml/s | | 0.71 (0.53 to 0.84) | 4 | 0.95 (0.87 to 0.98) | 3 | 14 (5.2 to 37) | 0.30 (0.17 to 0.53)
- Imaging phases: Arterial, portal venous, and delayed | | 0.89 (0.81 to 0.94); 0.30 (p=0.05) | 7 | 0.89 (0.81 to 0.94); 0.71 (p=0.03) | 4 | 8.1 (4.5 to 14) | 0.12 (0.07 to 0.22)
- Imaging phases: Missing delayed phase imaging | | 0.79 (0.68 to 0.87) | 8 | 0.92 (0.83 to 0.96) | 6 | 9.6 (4.3 to 21) | 0.23 (0.14 to 0.36)
- Delayed phase ≥120 s | | 0.87 (0.79 to 0.92); 0.16 (p=0.12) | 6 | 0.88 (0.72 to 0.96); 0.70 (p=0.03) | 4 | 7.3 (2.8 to 19) | 0.15 (0.09 to 0.25)
- Section thickness: ≤5 mm | | 0.84 (0.75 to 0.90); 0.46 (p=0.02) | 10 | 0.84 (0.74 to 0.91); 0.16 (p=0.17) | 7 | 5.4 (3.2 to 9.0) | 0.19 (0.12 to 0.31)
- Section thickness: >5 mm | | 0.82 (0.68 to 0.91) | 5 | 0.95 (0.91 to 0.97) | 4 | 16 (8.6 to 32) | 0.18 (0.10 to 0.35)
- Reference standard: Explanted liver | | 0.81 (0.71 to 0.88); 0.41 (p=0.01) | 11 | 0.93 (0.87 to 0.96); 0.43 (p=0.02) | 9 | 11 (5.9 to −21) | 0.21 (0.14 to 0.32)
- Reference standard: Histopathological, non-explant | | 0.85 (0.65 to 0.95) | 3 | 0.74 (0.29 to 0.95) | 1 | 3.2 (0.77 to 14) | 0.20 (0.07 to 0.61)
- Reference standard: Histological and clinical/imaging reference standard | | 0.87 (0.73 to 0.95) | 3 | 0.87 (0.69 to 0.95) | 2 | 6.7 (2.5 to 18) | 0.15 (0.06 to 0.33)
- Prospective | | 0.75 (0.62 to 0.85); 0.29 (p=0.03) | 6 | 0.83 (0.68 to 0.92); 0.36 (p=0.03) | 4 | 4.4 (2.2 to 8.7) | 0.30 (0.19 to 0.48)
- United States or Europe | | 0.83 (0.73 to 0.89); 0.53 (p=0.007) | 13 | 0.87 (0.79 to 0.92); 0.27 (p=0.10) | 9 | 6.3 (3.7 to 11) | 0.20 (0.12 to 0.31)
- Used confidence rating scale | | 0.85 (0.73 to 0.93); 0.45 (p=0.01) | 5 | 0.74 (0.49 to 0.89); 0.28 (p=0.05) | 2 | 3.3 (1.5 to 7.4) | 0.20 (0.10 to 0.40)
- Excluding high risk of bias studies | | 0.85 (0.76 to 0.91); 0.47 (p=0.01) | 10 | 0.90 (0.80 to 0.95); 0.63 (p=0.01) | 7 | 8.6 (0.76 to 0.91) | 0.90 (0.80 to 0.95)
- Avoided case-control design | | 0.77 (0.66 to 0.85); 0.40 (p=0.007) | 10 | 0.90 (0.82 to 0.94); 0.56 (p=0.01) | 10 | 7.4 (4.1 to 13) | 0.26 (0.17 to 0.39)
- Blinded interpretation of imaging | | 0.83 (0.75 to 0.0.88); 0.48 (p=0.01) | 14 | 0.92 (0.86 to 0.96); 0.58 (p=0.01) | 9 | 11 (5.5 to 21) | 0.19 (0.13 to 0.28)
| Lesion | 0.76 (0.72 to 0.80); 0.91 (p<0.0001) | 80 | 0.89 (0.84 to 0.93); 0.92 (p<0.0001) | 21 | 7.1 (4.7 to 11) | 0.26 (0.22 to 0.32)
- HCC lesions <2–3 cm | | 0.69 (0.47 to 0.84); 1.6 (p=0.01) | 8 | 0.97 (0.89 to 0.99); 2.0 (p=0.06) | 2 | 25 (7.1 to 86) | 0.32 (0.18 to 0.58)
- Excluding studies restricted to hypervascular HCC | | 0.75 (0.70 to 0.79); 0.75 (p<0.0001) | 61 | 0.88 (0.81 to 0.92); 0.88 (p<0.0001) | 18 | 6.1 (3.9 to 9.4) | 0.29 (0.24 to 0.34)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.77 (0.73 to 0.81); 0.81 (p<0.0001) | 72 | 0.89 (0.83 to 0.93); 0.83 (p<0.0001) | 19 | 7.0 (4.5 to 11) | 0.26 (0.21 to 0.31)
- CT type: Multidetector, ≥8 rows | | 0.77 (0.71 to 0.82); 0.81 (p<0.0001) | 36 | 0.91 (0.84 to 0.95); 0.79 (p<0.0001) | 10 | 8.5 (4.6 to 16) | 0.26 (0.20 to 0.33)
- CT type: Multidetector, <8 rows | | 0.79 (0.59 to 0.91) | 4 | Insufficient data | -- | -- | --
- CT type: Non-multidetector | | 0.75 (0.67 to 0.82) | 22 | 0.86 (0.73 to 0.93) | 7 | 5.3 (2.7 to 10) | 0.29 (0.21 to 0.40)
- Contrast rate: ≥3 ml/s | | 0.78 (0.74 to 0.82); 0.79 (p<0.0001) | 58 | 0.90 (0.84 to 0.94); 0.82 (p<0.0001) | 18 | 7.7 (4.8 to 12) | 0.24 (0.20 to 0.30)
- Contrast rate: <3 ml/s | | 0.74 (0.59 to 0.85) | 7 | 0.71 (0.22 to 0.95) | 1 | 2.5 (0.54 to 12) | 0.37 (0.16 to 0.85)
- Imaging phases: Arterial, portal venous, and delayed | | 0.74 (0.69 to 0.80); 0.78 (p<0.0001) | 42 | 0.90 (0.85 to 0.94); 0.51 (p<0.0001) | 13 | 7.8 (4.9 to 12) | 0.28 (0.23 to 0.35)
- Imaging phases: Missing delayed phase imaging | | 0.81 (0.75 to 0.86) | 26 | 0.88 (0.75 to 0.95) | 5 | 6.7 (3.0 to 15) | 0.22 (0.16 to 0.30)
- Delayed phase ≥120 s | | 0.75 (0.69 to 0.80); 0.78 (p<0.0001) | 38 | 0.92 (0.88 to 0.95) ; 0.39(p=0.002) | 10 | 9.6 (5.9 to 16) | 0.27 (0.22 to 0.35)
- Section thickness: ≤5 mm | | 0.75 (0.70 to 0.79); 0.78 (p<0.0001) | 53 | 0.90 (0.85 to 0.94); 0.76 (p<0.0001) | 16 | 7.5 (4.7 to 12) | 0.28 (0.23 to 0.34)
- Section thickness: >5 mm | | 0.83 (0.75 to 0.89) | 14 | 0.83 (0.53 to 0.96) | 2 | 4.9 (1.4 to 17) | 0.21 (0.13 to 0.34)
- Reference standard: Explanted liver | | 0.67 (0.59 to 0.75); 0.63 (p<0.0001) | 23 | 0.82 (0.74 to 0.88); 0.46 (p=0.0001) | 12 | 3.8 (2.6 to 5.6) | 0.40 (0.31 to 0.50)
- Reference standard: Histopathological, non-explant | | 0.86 (0.78 to 0.91) | 12 | 0.95 (0.88 to 0.98) | 3 | 19 (7.1 to 49) | 0.15 (0.10 to 0.23)
- Reference standard: Imaging/clinical | | 0.65 (0.43 to 0.83) | 3 | Insufficient data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.80 (0.75 to 0.84) | 34 | 0.92 (0.83 to 0.96) | 4 | 11 (5.3 to 21) | 0.22 (0.17 to 0.27)
- Prospective | | 0.73 (0.63 to 0.81); 0.71 (p<0.0001) | 16 | 0.84 (0.74 to 0.91); 0.58 (p<0.0001) | 8 | 4.5 (2.6 to 7.8) | 0.32 (0.23 to 0.46)
- United States or Europe | | 0.76 (0.69 to 0.83); 0.81 (p<0.0001) | 23 | 0.81 (0.70 to 0.88); 0.46 (p=0.0002) | 10 | 3.9 (2.5 to 6.3) | 0.29 (0.21 to 0.40)
- Used confidence rating scale | | 0.74 (0.67 to 0.80); 0.80 (p<0.0001) | 31 | 0.92 (0.86 to 0.96); 0.63 (p<0.0001) | 9 | 9.3 (5.2 to 17) | 0.28 (0.22 to 0.36)
- Excluding high risk of bias studies | | 0.75 (0.70 to 0.80); 0.79 (p<0.0001) | 47 | 0.91 (0.87 to 0.94); 0.51 (p<0.0001) | 15 | 8.5 (5.6 to 13) | 0.27 (0.22 to 0.34)
- Avoided case-control design | | 0.74 (0.66 to 0.81); 0.80 (p<0.0001) | 21 | 0.87 (0.78 to 0.93); 0.78 (p<0.0001) | 10 | 5.7 (3.2 to 10) | 0.30 (0.21 to 0.41)
- Blinded interpretation of imaging | | 0.78 (0.72 to 0.82); 0.81 (p<0.0001) | 42 | 0.86 (0.77 to 0.92); 0.79 (p<0.0001) | 10 | 5.7 (3.3 to 9.7) | 0.26 (0.20 to 0.33)
| Liver segment | 0.88 (0.78 to 0.94); 0.81 (p=0.02) | 8 | 0.97 (0.94 to 0.98); 0.29 (p=0.06) | 8 | 26 (15 to 42) | 0.10 (0.94 to 0.98)
- Excluding studies restricted to hypervascular HCC | | 0.87 (0.75 to 0.93); 0.86 (p=0.03) | 7 | 0.97 (0.95 to 0.98); 0.31 (p=0.08) | 7 | 29 (16 to 51) | 0.14 (0.07 to 0.27)
- Excluding studies restricted to HCC lesions <2 cm | | 0.87 (0.76 to 0.94); 0.87 (p=0.02) | 7 | 0.97 (0.94 to 0.98); 0.39 (p=0.06) | 7 | 28 (15 to 51) | 0.13 (0.07 to 0.25)
Evaluation of focal liver lesions (KQ 2)
| Patient | 0.86 (0.75 to 0.92); 0.65 (p=0.04) | 8 | 0.88 (0.76 to 0.95); 0.64 (p=0.08) | 5 | 7.4 (3.3 to 17) | 0.16 (0.09 to 0.30)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.87 (0.78 to 0.93); 0.42 (p=0.11) | 6 | 0.93 (0.85 to 0.96); 0.11 (p=0.57) | 3 | 12 (5.7 to 24) | 0.14 (0.08 to 0.25)
| HCC lesion | 0.79 (0.67 to 0.87); 0.97 (p=0.001) | 13 | 0.90 (0.37 to 0.99); 4.4 (p=0.11) | 6 | 7.7 (0.71 to 84) | 0.24 (0.15 to 0.38)
- HCC lesions <2–3 cm | | 0.61 (0.49 to 0.71); 0.19 (p=0.14) | 5 | 0.98 (0.87 to 0.996); 2.5 (p=0.11) | 5 | 25 (4.5 to 138) | 0.40 (0.30 to 0.53)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.87 (0.78 to 0.92); 0.67 (p=0.01) | 8 | 0.71 (0.57 to 0.83) | 1 | Not calculated | Note calculated
- CT type: Multidetector, ≥8 rows | | 0.79 )0.56 to 0.91); 0.49 (p=0.02) | 2 | Insufficient data | -- | -- | --
- CT type: Non-multidetector | | 0.87 (0.77 to 0.93) | 5 | Insufficient data | -- | -- | --
- Contrast rate: ≥3 ml/s | | 0.87 (0.78 to 0.92); 0.67 (p=0.01) | 8 | Insufficient data | -- | -- | --
- Imaging phases: Arterial, portal venous, and delayed | | 0.83 (0.73 to 0.90); 0.48 (p=0.15) | 6 | Insufficient data | -- | -- | --
- Imaging phases: Missing delayed phase imaging | | 0.94 (0.82 to 0.98) | 2 | Insufficient data | -- | -- | --
- Delayed phase imaging >120 s | | 0.88 (0.81 to 0.92); 0.17 (p=0.03) | 4 | Insufficient data | -- | -- | --
- Section thickness: ≤5 mm | | 0.78 (0.61 to 0.89); 0.45 (p=0.01) | 3 | Insufficient data | -- | -- | --
- Section thickness: >5 mm | | 0.91 (0.78 to 0.97); 0.45 | 2 | Insufficient data | -- | -- | --
- Reference standard: Histopathological, non-explant | | 0.83 (0.73 to 0.90); 0.48 (p=0.02) | 6 | Insufficient data | -- | -- | --
- Reference standard: Histological and clinical/imaging | | 0.93 (0.82 to 0.98) | 2 | Insufficient data | -- | -- | --
- Prospective | | 0.90 (0.80 to 0.95); 0.48 (p=0.02) | 4 | Insufficient data | -- | -- | --
- United States or Europe | | 0.89 (0.80 to 0.94); 0.53 (p=0.02) | 5 | Insufficient data | -- | -- | --
- Used confidence rating scale | | 0.86 (0.64 to 0.95); 0.66 (p=0.01) | 2 | Insufficient data | -- | -- | --
- Excluding high risk of bias studies | | 00.83 (0.71 to 0.90); 0.51 (p=0.01) | 5 | Insufficient data | -- | -- | --
- Avoided case-control design | | 0.88 (0.74 to 0.95); 0.66 (p=0.01) | 4 | Insufficient data | -- | -- | --
- Blinded interpretation of imaging | | 0.86 (0.75 to 0.93); 0.65 (p=0.01) | 6 | Insufficient data | -- | -- | --

CI = confidence interval; CT = computed tomography; HCC = hepatocellular carcinoma; KQ = Key Question; LR+ = positive likelihood ratio; LR− = negative likelihood ratio

Table 5 Test performance of magnetic resonance imaging for identification of intrahepatic and extrahepatic hepatocellular carcinoma

| Unit of Analysis | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR−
Detection of HCC (KQ 1)
Nonsurveillance settings
| Patient | 0.86 (0.79 to 0.91); 0.43 (p=0.03) | 14 | 0.89 (0.82 to 0.93); 0.54 (p=0.03) | 12 | 7.7 (4.6 to 13) | 0.16 (0.10 to 0.24)
- Excluding studies restricted to hypervascular HCC | | 0.86 (0.78 to 0.91); 0.60 (p=0.02) | 12 | 0.90 (0.82 to 0.95); 0.73 (p=0.04) | 10 | 8.9 (4.6 yo 17) | 0.16 (0.10 to 0.26)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.85 (0.76 to 0.91); 0.47 (p=0.07) | 10 | 0.90 (0.81 to 0.94); 0.51 (p=0.05) | 8 | 8.1 (4.3 to 15) | 0.17 (0.10 to 0.28)
- MRI type: 1.5 T | | 0.84 (0.75 to 0.90); 0.53 (p=0.04) | 11 | 0.90 (0.82 to 0.94); 0.51 (p=0.05) | 9 | 8.1 (4.4 to 15) | 0.18 (0.11 to 0.30)
- Contrast: Gadopentetate or gadodiamide | | 0.85 (0.76 to 0.91); 0.45 (p=0.10) | 10 | 0.90 (0.82 to 0.95); 0.48 (p=0.08) | 8 | 8.3 (4.5 to 15) | 0.17 (0.10 to 0.27)
- Imaging phases: Arterial, portal venous, and delayed | | 0.86 (0.79 to 0.91); 0.44 (p=0.02) | 12 | 0.88 (0.81 to 0.93); 0.57 (p=0.03) | 10 | 7.4 (4.2 to 13) | 0.16 (0.10 to 0.25)
- Imaging phases: Missing delayed phase imaging | | 0.83 (0.56 to 0.95) | 2 | 0.92 (0.69 to 0.99) | 2 | 11 (2.1 to 57) | 0.18 (0.06 to 0.59)
- Delayed phase ≥120 s | | 0.85 (0.76 to 0.91); 0.30 (p=0.05) | 6 | 0.90 (0.80 to 0.95); 0.55 (p=0.03) | 6 | 8.1 (3.8 to 17) | 0.17 (0.10 to 0.29)
- Section thickness: ≤5 mm | | 0.88 (0.79 to 0.93); 0.38 (p=0.03) | 7 | 0.92 (0.85 to 0.96); 0.31 (p=0.11) | 6 | 11 (5.5 to 22) | 0.13 (0.07 to 0.24)
- Section thickness: >5 mm | | 0.81 (0.64 to 0.91) | 4 | 0.84 (0.69 to 0.92) | 4 | 5.0 (2.3 to 11) | 0.23 (0.11 to 0.48)
- Reference standard: Explanted liver | | 0.87 (0.80 to 0.91); 0.29 (p=0.05) | 10 | 0.92 (0.87 to 0.96); 0.25 (p=0.13) | 8 | 11 (6.2 to 20) | 0.14 (0.09 to 0.22)
- Reference standard: Histological and clinical/imaging | | 0.89 (0.76 to 0.95) | 3 | 0.80 (0.64 to 0.90) | 3 | 4.4 (2.2 to 8.8) | 0.14 (0.06 to 0.35)
- Prospective | | 0.82 (0.66 to 0.91); 0.48 (p=0.02) | 5 | 0.89 (0.75 to 0.95); 0.53 (p=0.04) | 4 | 7.3 (2.9 to 18) | 0.21 (0.10 to 0.43)
- United States or Europe | | 0.84 (0.77 to 0.89); 0.34 (p=0.04) | 12 | 0.89 (0.81 to 0.93); 0.52 (p=0.03) | 10 | 7.4 (4.2 to 13) | 0.18 (0.12 to 0.27)
- Used confidence rating scale | | 0.84 (0.66 to 0.93); 0.40 (p=0.03) | 3 | 0.76 (0.60 to 0.87); 0.20 (p=0.12) | 3 | 3.5 (1.8 to 6.8) | 0.22 (0.09 to 0.53)
- Excluding high risk of bias studies | | 0.85 (0.78 to 0.90); 0.40 (p=0.03) | 12 | 0.89 (0.81 to 0.93); 0.53 (p=0.03) | 10 | 7.4 (4.2 to 13) | 0.17 (0.11 to 0.26)
- Avoided case-control design | | 0.83 (0.76 to 0.89); 0.37 (p=0.03) | 11 | 0.89 (0.81 to 0.93); 0.54 (p=0.03) | 10 | 7.3 (4.1 to 13) | 0.19 (0.12 to 0.29)
- Blinded interpretation of imaging | | 0.90 (0.85 to 0.93); 0.06 (p=0.38) | 8 | 0.91 (0.85 to 0.93); 0.28 (p=0.07) | 7 | 10 (5.6 to 18) | 0.11 (0.07 to 0.17)
| Lesion | 0.83 (0.80 to 0.86); 0.76 (p<0.0001) | 82 | 0.87 (0.79 to 0.93); 1.6 (p<0.0001) | 20 | 6.5 (3.8 to 11) | 0.20 (0.16 to 0.24)
- HCC lesions <2–3 cm | | 0.85 (0.78 to 0.90); 0.78 (p=0.0002) | 16 | 0.75 (0.28 to 0.96); 2.5 (p=0.08) | 4 | 3.4 (0.72 to 16) | 0.20 (0.09 to 0.42)
- Excluding studies that used diffusion-weighted imaging | | 0.82 (0.78 to 0.85); 0.78 (p<0.0001) | 71 | 0.86 (0.75 to 0.93); 1.6 (p<0.0001) | 15 | 5.8 (3.2 to 11) | 0.21 (0.17 to 0.26)
- Excluding studies restricted to hypervascular HCC | | 0.84 (0.81 to 0.87); 0.68 (p<0.0001) | 70 | 0.87 (0.79 to 0.93); 1.6 (p<0.0001) | 20 | 6.7 (3.9 to 11) | 0.18 (0.15 to 0.22)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.82 (0.79 to 0.85); 0.74 (p<0.0001) | 66 | 0.87 (0.77 to 0.93); 1.6 (p<0.0001) | 16 | 6.3 (3.4 to 11) | 0.21 (0.17 to 0.25)
- MRI type: 3.0 T | | 0.86 (0.77 to 0.92); 0.72 (p<0.0001) | 9 | 0.94 (0.75 to 0.99); 1.4 (p<0.0001) | 3 | 13 (3.0 to 60) | 0.15 (0.08 to 0.25)
- MRI type: 1.5 T | | 0.82 (0.77 to 0.85) | 51 | 0.83 (0.69 to 0.91) | 11 | 4.8 (2.5 to 8.9) | 0.22 (0.17 to 0.28)
- Contrast: Gadopentetate or gadodiamide | | 0.81 (0.75 to 0.85); 0.72 (p<0.0001) | 32 | 0.62 (0.49 to 0.74); 0.39 (p=0.005) | 6 | 2.2 (1.5 to 3.0) | 0.31 (0.23 to 0.42)
- Contrast: Gadobenate disodium or gadobenate | | 0.83 (0.78 to 0.87) | 32 | 0.95 (0.91 to 0.97) | 9 | 16 (9.5 to 28) | 0.18 (0.14 to 0.23)
- Imaging phases: Arterial, portal venous, and delayed | | 0.82 (0.78 to 0.85); 0.72 (p<0.0001) | 62 | 0.87 (0.76 to 0.93); 1.6 (p<0.0001) | 15 | 6.2 (3.3 to 12) | 0.21 (0.17 to 0.26)
- Imaging phases: Missing delayed phase imaging | | 0.77 (0.52 to 0.91) | 3 | 0.88 (0.31 to 0.99) | 1 | 6.5 (0.55 to 77) | 0.26 (0.10 to 0.65)
- Delayed phase ≥120 s | | 0.83 (0.79 to 0.86); 0.70 (p<0.0001) | 52 | 0.91 (0.85 to 0.94); 0.62 (p=0.0001) | 11 | 8.8 (5.4 to 14) | 0.19 (0.15 to 0.24)
- Section thickness: ≤5 mm | | 0.85 (0.81 to 0.88); 0.65 (p<0.0001) | 41 | 0.87 (0.75 to 0.94); 1.6 (p<0.0001) | 11 | 6.7 (3.2 to 14) | 0.18 (0.14 to 0.23)
- Section thickness: >5 mm | | 0.81 (0.73 to 0.86) | 16 | 0.88 (0.62 to 0.97) | 3 | 6.6 (1.8 to 24) | 0.22 (0.15 to 0.33)
- Reference standard: Explanted liver | | 0.70 (0.62 to 0.77); 0.54 (p<0.0001) | 20 | 0.86 (0.73 to 0.93); 1.4 (p=0.001) | 10 | 5.0 (2.5 to 9.8) | 0.35 (0.27 to 0.44)
- Reference standard: Histopathological, non-explant | | 0.88 (0.82 to 0.93) | 11 | 0.97 (0.88 to 0.99) | 3 | 29 (7.3 to 117) | 0.12 (0.08 to 0.19)
- Reference standard: Imaging/clinical reference standard | | 0.86 (0.67 to 0.95) | 2 | Insufficient data | -- | -- | --
- Reference standard: Mixed histological and imaging/clinical | | 0.85 (0.81 to 0.88) | 33 | 0.84 (0.54 to 0.96) | 3 | 5.2 (1.5 to 18) | 0.18 (0.13 to 0.24)
- Prospective | | 0.82 (0.74 to 0.88); 0.74 (p<0.0001) | 15 | 0.89 (0.71 to 0.96); 1.6 (p<0.0001) | 5 | 7.6 (2.6 to 22) | 0.20 (0.13 to 0.30)
- United States or Europe | | 0.78 (0.71 to 0.84); 0.67 (p<0.0001) | 20 | 0.73 (0.58 to 0.84); 0.66 (p=0.0003) | 8 | 2.9 (1.8 to 4.7) | 0.30 (0.21 to 0.42)
- Used confidence rating scale | | 0.85 (0.81 to 0.89); 0.65 (p<0.0001) | 37 | 0.90 (0.77 to 0.96); 1.7 (p=0.0002) | 9 | 8.5 (3.6 to 20) | 0.16 (0.13 to 0.21)
- Excluding high risk of bias studies | | 0.81 (0.76 to 0.84); 0.70 (p<0.0001) | 50 | 0.88 (0.78 to 0.94); 1.6 (p<0.0001) | 13 | 6.8 (3.5 to 13) | 0.22 (0.18 to 0.28)
- Avoided case-control design | | 0.80 (0.73 to 0.85); 0.73 (p<0.0001) | 24 | 0.84 (0.71 to 0.92); 1.4 (p<0.0001) | 12 | 5.1 (2.7 to 9.5) | 0.24 (0.17 to 0.33)
- Blinded interpretation of imaging | | 0.83 (0.79 to 0.87); 0.73 (p<0.0001) | 40 | 0.89 (0.76 to 0.95); 1.6 (p<0.0001) | 9 | 7.5 (3.3 to 17) | 0.19 (0.15 to 0.25)
| Liver segment | 0.77 (0.56 to 0.90); 0.56 (p=0.31) | 3 | 0.97 (0.87 to 0.99); 1.6 (p=0.29) | 3 | 28 (5.6 to 0.90) | 0.97 (0.87 to 0.99)
Evaluation of focal liver lesions (KQ 2)
| Patient | 0.75 (0.66 to 0.83); 0.12 (p=0.16) | 5 | 0.82 (0.60 to 0.93); 1.1 (p=0.13) | 5 | 4.1 (1.8 to 9.2) | 0.31 (0.23 to 0.40)
- HCC lesions <2–3 cm | | 0.72 (0.55 to 0.85); 0.22 (p=0.38) | 2 | 0.79 (0.16 to 0.99); 3.9 (p=0.34) | 2 | 3.5 (0.38 to 31) | 0.35 (0.23 to 0.53)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.78 (0.69 to 0.86); <0.0001 (p=1.0) | 3 | 0.79 (0.70 to 0.86); <0.0001 (p=1.0) | 3 | 3.8 (2.5 to 5.7) | 0.27 (0.18 to 0.41)
| HCC lesion | 0.82 (0.74 to 0.88); 0.68 (p=0.001) | 15 | 0.92 (0.78 to 0.97); 3.5 (p=0.003) | 12 | 10 (3.6 to 29) | 0.20 (0.14 to 0.28)
- HCC lesions <2–3 cm | | 0.73 (0.62 to 0.82); 0.44 (p=0.01) | 9 | 0.95 (0.73 to 0.99); 5.8 (p=0.03) | 8 | 14 (2.5 to 76) | 0.29 (0.21 to 0.39)
- Excluding studies that used diffusion-weighted imaging | | 0.79 (0.70 to 0.85); 0.53 (p=0.002) | 13 | 0.94 (0.78 to 0.98); 4.3 (p=0.01) | 10 | 13 (3.3 to 47) | 0.23 (0.16 to 0.32)
- Excluding studies restricted to hypervascular HCC lesions | | 0.78 (0.67 to 0.86); 0.71 (p=0.005) | 10 | 0.91 (0.66 to 0.98); 6.3 (p=0.01) | 8 | 8.5 (2.1 to 34) | 0.24 (0.17 to 0.35)
- Excluding studies restricted to HCC lesions <2–3 cm | | 0.91 (0.88 to 0.93); 0.01 (p=0.64) | 6 | 0.85 (0.68 to 0.93); 0.47 (p=0.20) | 4 | 5.9 (2.7 to 13) | 0.11 (0.08 to 0.15)
- MRI type: 3.0 T | | 0.92 (0.87 to 0.95); 0.0003 (p= | 3 | 0.74 (0.60 to 0.84); 0.01 | 2 | 3.5 (2.2 to 5.7) | 0.11 (0.07 to 0.19)
- MRI type: 1.5 T | | 0.91 (0.86 to 0.94) | 3 | 0.92 (0.80 to 0.97) | 2 | 11 (4.2 to 28) | 0.10 (0.07 to 0.15)
- Contrast: Gadopentetate or gadodiamide | | 0.91 (0.86 to 0.94); 0.0003 (p=0.96) | 3 | 0.92 (0.80 to 0.97); <0.0001 (p=0.89) | 2 | 11 (4.2 to 28) | 0.10 (0.07 to 0.15)
- Contrast: Gadoxetic acid or gadobenate | | 0.92 (0.87 to 0.95) | 3 | 0.74 (0.60 to 0.84) | 2 | 3.5 (2.2 to 5.7) | 0.11 (0.07 to 0.19)
- Imaging phases: Arterial, portal venous, and delayed | | 0.91 (0.88 to 0.94); 0.001 (p=0.91) | 5 | 0.84 (0.68 to 0.93); 0.46 (p=0.20) | 4 | 5.6 (2.7 to 12) | 0.10 (0.07 to 0.15)
- Delayed phase imaging >120 s | | 0.91 (0.88 to 0.94); 0.001 (p=0.91) | 5 | 0.84 (0.68 to 0.93); 0.46 (p=0.20) | 4 | 5.6 (2.7 to 12) | 0.10 (0.07 to 0.15)
- Section thickness: ≤5 mm | | 0.92 (0.86 to 0.94); <0.0001 (p=1.0) | 3 | 0.84 (0.61 to 0.95); <0.0001 (p=1.0) | 2 | 3.5 (2.2 to 5.6) | 0.11 (0.07 to 0.19)
- Reference standard: Histopathological, non-explant | | 0.92 (0.87 to 0.95); 0.0003 (p=0.95) | 2 | 0.84 (0.60 to 0.95); 0.46 (p=0.20) | 2 | 5.8 (2.0 to 17) | 0.10 (0.06 to 0.16)
- Reference standard: Histological and clinical/imaging | | 0.90 (0.86 to 0.94) | 4 | 0.83 (0.60 to 0.94) | 2 | 5.4 (2.0 to 15) | 0.12 (0.07 to 0.18)
- Used confidence rating scale | | 0.91 (0.86 to 0.94); <0.0001 (p=1.0) | 2 | 0.64 (0.42 to 0.81); <0.0001 (p=1.0) | 1 | 2.5 (1.4 to 4.3) | 0.15 (0.09 to 0.24)
- Excluding high risk of bias studies | | 0.91 (0.88 to 0.93); 0.01 (p=0.64) | 6 | 0.85 (0.68 to 0.93); 0.47 (p=0.20) | 4 | 5.9 (2.7 to 13) | 0.11 (0.08 to 0.15)

HCC = hepatocellular carcinoma; LR+ = positive likelihood ratio; LR− = negative likelihood ratio; MRI = magnetic resonance imaging

Table 6 Strength of Evidence

Table 6a Surveillance: Test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
Surveillance settings Unit of analysis: patients with HCC | US without contrast | Sens: 4 Spec: 3 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 540 Spec: 488 | Sens: Low Spec: Low
Surveillance settings Unit of analysis: patients with HCC | CT | Sens: 2 Spec: 2 | Moderate | Consistent | Indirect | Imprecise | Sens: 385 Spec: 385 | Sens: Low Spec: Low
Surveillance settings Unit of analysis: patients with HCC | MRI | No evidence | -- | -- | -- | -- | -- | Insufficient
Surveillance settings Unit of analysis: HCC lesions | US without contrast | Sens: 1 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 42 Spec: -- | Sens: Low Spec: Insufficient
Surveillance settings Unit of analysis: HCC lesions | CT | Sens: 1 Spec: 0 | Moderate | Sens: Single study Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 42 Spec: -- | Sens: Low Spec: Insufficient
Surveillance settings Unit of analysis: HCC lesions | MRI | No evidence | -- | -- | -- | -- | -- | Insufficient
Nonsurveillance settings Unit of analysis: patients with HCC | US without contrast | Sens: 8 Spec: 6 | Moderate | Inconsistent | Indirect | Imprecise | Sens: 975 Spec: 858 | Sens: Low Spec: Low
Nonsurveillance settings Unit of analysis: patients with HCC | CT | Sens: 17 Spec: 12 | Moderate | Inconsistent | Indirect | Precise | Sens: 1327 Spec: 1145 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: patients with HCC | MRI | Sens: 14 Spec: 12 | Moderate | Inconsistent | Indirect | Precise | Sens: 1332 Spec: 1240 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: HCC lesions | US without contrast | Sens: 11 Spec: 2 | Moderate | Inconsistent | Indirect | Sens: Precise Spec: Imprecise | Sens: 1996 Spec: 323 | Sens: Moderate Spec: Low
Nonsurveillance settings Unit of analysis: HCC lesions | US with contrast | Sens: 9 Spec: 1 | Moderate | Sens: Inconsistent Spec: Single study | Indirect | Sens: Imprecise Spec: Imprecise | Sens: 443 Spec: -- | Sens: Low Spec: Insufficient
Nonsurveillance settings Unit of analysis: HCC lesions | CT | Sens: 80 Spec: 21 | Moderate | Inconsistent | Indirect | Precise | Sens: 8145 Spec: 2948 | Sens: Moderate Spec: Moderate
Nonsurveillance settings Unit of analysis: HCC lesions | MRI | Sens: 82 Spec: 20 | Moderate | Inconsistent | Indirect | Precise | Sens: 7162 Spec: 2472 | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. CT | Sens: 6 Spec: 5 | Moderate | Inconsistent | Direct | Precise | Sens: 899 (US) Sens: 838 (CT) Spec: 885 (US) Spec: 824 (CT) | Sens: Moderate Spec: Moderate For the 2 studies in surveillance settings, the strength of evidence is low for sensitivity and specificity.
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | US without contrast vs. MRI | Sens: 3 Spec: 3 | Moderate | Consistent | Direct | Precise | Sens: 712 (US) Sens: 712 (MRI) Spec: 712 (US) Spec: 712 (MRI) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: patients with HCC | MRI vs. CT | Sens: 5 Spec: 5 | Moderate | Inconsistent | Direct | Precise | Sens: 318 (MRI) Sens: 484 (CT) Spec: 318 (MRI) Spec: 534(CT) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US without contrast vs. CT | Sens: 3 Spec: 2 | Moderate | Inconsistent | Direct | Precise | Sens: 535 (US) Sens: 539 (CT) Spec: 323 (US) Spec: 323 (CT) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US without contrast vs. MRI | Sens: 3 Spec: 2 | Moderate | Consistent | Direct | Precise | Sens: 660 (US) Sens: 660 (MRI) Spec: 323 (US) Spec: 323 (MRI) | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. CT | Sens: 4 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Precise Spec: No studies | Sens: 217 (US) Sens: 217 (CT) Spec: -- | Sens: Moderate Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. MRI | Sens: 3 Spec: 0 | Moderate | Sens: Consistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 172 (US) Sens: 170 (MRI) Spec: -- | Sens: Moderate Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | MRI vs. CT | Sens: 32 Spec: 7 | Moderate | Inconsistent | Direct | Precise | Sens: 3002(MRI) Sens: 3288(CT) Spec: 874 (MRI) Spec: 842(CT) | Sens: Moderate Spec: Moderate

Table 6b Diagnosis: Test performance

| Imaging Modality or Comparison | Number of Studies | Risk of Bias (Low, Moderate, High) | Consistency (Consistent or Inconsistent) | Directness (Direct or Indirect) | Precision (Precise or Imprecise) | Number of Subjects/Lesions | Strength of Evidence (High, Moderate, Low, Insufficient)
Evaluation of focal liver lesion Unit of analysis: patients with HCC | US with contrast | Sens: 12 Spec: 8 | Moderate | Inconsistent | Indirect | Precise | Sens: 836 Spec: 678 | Sens: Moderate Spec: Moderate
Evaluation of focal liver lesion Unit of analysis: patients with HCC | US without contrast | Sens: 1 Spec: 0 | Moderate | Sens: Consistent Spec: No studies | Indirect | Sens: Imprecise Spec: No studies | Sens: 93 Spec: -- | Sens: Low Spec: Insufficient
Evaluation of focal liver lesion Unit of analysis: patients with HCC | CT | Sens: 8 Spec: 5 | Moderate | Inconsistent | Indirect | Sens: Precise Spec: Imprecise | Sens: 656 Spec: 471 | Sens: Moderate Spec: Low
Evaluation of focal liver lesion Unit of analysis: patients with HCC | MRI | Sens: 5 Spec: 5 | Moderate | Consistent | Indirect | Imprecise | Sens: 337 Spec: 337 | Sens: Low Spec: Low
Evaluation focal liver lesion Unit of analysis: HCC lesions | US with contrast | Sens: 21 Spec: 10 | Moderate | Inconsistent | Indirect | Precise | Sens: 1652 Spec: 1175 | Sens: Moderate Spec: Moderate
Evaluation focal liver lesion Unit of analysis: HCC lesions | CT | Sens: 13 Spec: 6 | Moderate | Inconsistent | Indirect | Precise | Sens: 1196 Spec: 591 | Sens: Moderate Spec: Moderate
Evaluation focal liver lesion Unit of analysis: HCC lesions | MRI | Sens: 15 Spec: 12 | Moderate | Inconsistent | Indirect | Precise | Sens: 1214 Spec: 1043 | Sens: Moderate Spec: Moderate
Direct (within-study) comparisons of imaging modalities Unit of analysis: Patients with HCC | US without contrast vs. CT | Sens: 1 Spec: 0 | Moderate | Sens: Single study Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 121 Spec: 0 | Sens: Low Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: Patients with HCC | US with contrast vs. CT | Sens: 5 Spec: 2 | Moderate | Consistent | Direct | Sens: Precise Spec: Imprecise | Sens: 956 Spec: 586 | Sens: Moderate Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: Patients with HCC | MRI vs. CT | Sens: 1 Spec: 1 | Moderate | Single study | Direct | Imprecise | Sens: 74 Spec: 74 | Sens: Low Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. CT | Sens: 4 Spec: 0 | Moderate | Sens: Inconsistent Spec: No studies | Direct | Sens: Imprecise Spec: No studies | Sens: 446 Spec: 0 | Sens: Moderate Spec: Insufficient
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | US with contrast vs. MRI | Sens: 1 Spec: 1 | Moderate | Single study | Direct | Imprecise | Sens: 162 Spec: 162 | Sens: Low Spec: Low
Direct (within-study) comparisons of imaging modalities Unit of analysis: HCC lesions | MRI vs. CT | Sens: 1 Spec: 1 | Moderate | Single study | Direct | Imprecise | Sens: 123 Spec: 123 | Sens: Low Spec: Low

CT = computed tomography; HCC = hepatocellular carcinoma; MRI = magnetic resonance imaging; US = ultrasound; sens = sensitivity; spec = specificity

## References

1 Chou R, Cuevas C, Fu R, et al. Imaging Techniques for the Diagnosis and Staging of Hepatocellular Carcinoma. Comparative Effectiveness Review No. 143. (Prepared by the Pacific Northwest Evidence-based Practice Center under Contract No. 290-2012-00014-I.). AHRQ Publication No. 14-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2014. [pmid: 25473698].
2 Chou R, Cuevas C, Fu R, et al. Imaging techniques for the diagnosis of hepatocellular carcinoma: a systematic review and meta-analysis. Ann Intern Med. 2015. May. 18. publication in process.
3 Donati OF, Hunziker R, Fischer MA, et al. MRI for characterization of primary tumors in the non-cirrhotic liver: added value of Gd-EOB-DTPA enhanced hepatospecific phase. Eur J Radiol. Jul. 2014;83(7):1074-9. [pmid: 24816085].
4 Hanna RF, Ward TJ, Chow DS, et al. An evaluation of the sensitivity of MRI at detecting hepatocellular carcinoma in cirrhotic patients utilizing an explant reference standard. Clin Imaging. Sep–Oct. 2014;38(5):693-7. [pmid: 24997104].
5 Hwang J, Kim YK, Kim JM, et al. Pretransplant diagnosis of hepatocellular carcinoma by gadoxetic acid-enhanced and diffusion-weighted magnetic resonance imaging. Liver Transpl. Dec. 2014;20(12):1436-46. [pmid: 25103727].
6 Kim MY, Kim YK, Park HJ, et al. Diagnosis of focal liver lesions with gadoxetic acid-enhanced MRI: is a shortened delay time possible by adding diffusion-weighted imaging?. J Magn Reson Imaging. Jan. 2014;39(1):31-41. [pmid: 24115329].
7 Kim YK, Kim YK, Park HJ, et al. Noncontrast MRI with diffusion-weighted imaging as the sole imaging modality for detecting liver malignancy in patients with high risk for hepatocellular carcinoma. Magn Reson Imaging. Jul. 2014;32(6):610-8. [pmid: 24702980].
8 Kwon S, Kim YK, Park HJ, et al. Is gadoxetic acid-enhanced MRI limited in tumor characterization for patients with chronic liver disease?. Magn Reson Imaging. Dec. 2014;32(10):1214-22. [pmid: 25192607].
9 Maiwald B, Lobsien D, Kahn T, et al. Is 3-Tesla Gd-EOB-DTPA-enhanced MRI with diffusion-weighted imaging superior to 64-slice contrast-enhanced CT for the diagnosis of hepatocellular carcinoma?. PLoS ONE. Nov. 6. 2014;9(11):e111935. [pmid: 25375778].
10 Park MJ, Kim YK, Lee MW, et al. Small hepatocellular carcinomas: improved sensitivity by combining gadoxetic acid-enhanced and diffusion-weighted MR imaging patterns. Radiology. Sep. 2012;264(3):761-70. [pmid: 22843769].
11 Park VY, Choi J-Y, Chung YE, et al. Dynamic enhancement pattern of HCC smaller than 3 cm in diameter on gadoxetic acid-enhanced MRI: comparison with multiphasic MDCT. Liver Int. Nov. 2014;34(10):1593-602. [pmid: 24673802].
12 Yu MH, Kim JH, Yoon J-H, et al. Small (<1-cm) hepatocellular carcinoma: diagnostic performance and imaging features at gadoxetic acid-enhanced MR imaging. Radiology. Jun. 2014;271(3):748-60. [pmid: 24588677].
13 Zhang X-Y, Luo Y, Wen T-F, et al. Contrast-enhanced ultrasound: improving the preoperative staging of hepatocellular carcinoma and guiding individual treatment. World J Gastroenterol. Sep. 21. 2014;20(3):12628-36. [pmid: 25253968].
14 Zhao XT, Li WX, Chai WM, et al. Detection of small hepatocellular carcinoma using gadoxetic acid-enhanced MRI: Is the addition of diffusion-weighted MRI at 3.0T beneficial?. J Dig Dis. Mar. 2014;15(3):137-45. [pmid: 24354621].