# Abbreviations and Acronyms

AASLD: American Association for the Study of Liver Diseases
AFP: Alpha-fetoprotein
AFROC: alternate free response operating characteristic
AHRQ: Agency for Healthcare Research and Quality
AUROC: area under the receiver operating characteristic
BCLC: Barcelona Clinic Liver Cancer
CER: Comparative effectiveness review
CT: Computed tomography
EASL: European Association for the Study of the Liver
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
FDG: ^18^F-fluorodeoxyglucose
FLT: ^18^F-fluorothymidine
HBV: Hepatitis B virus
HCC: Hepatocellular carcinoma
HCV: Hepatitis C virus
KQ: Key Question
LR: Likelihood ratio
MRI: Magnetic resonance imaging
PET: Positron emission tomography
PICOTS: Populations, interventions, comparators, outcomes, timing, setting
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
SIP: Scientific information packet
TEP: Technical expert panel
UCSF: University of California, San Francisco
US: Ultrasound