# Results

## Introduction

In this chapter, we describe the evidence in terms of literature search results and screening procedures. We then present the results for each key question. Findings for imaging studies of rectal cancer were often reported separately, but those of colon cancer were not reported separately in any studies that met the inclusion criteria; they were reported only in the included studies mixed with rectal cancer cases, as “colorectal” cancer; consequently, we have presented findings for rectal cancer first, followed by results for colorectal cancer. Under Key Question 1, we summarize the findings of previous systematic reviews on diagnostic accuracy of individual imaging modalities (endoscopic rectal ultrasound [ERUS], computed tomography [CT], magnetic resonance imaging [MRI], and positron emission tomography/computed tomography [PET/CT]) for staging rectal and colorectal cancer before initial treatment, supplemented by an assessment of primary studies of PET/CT diagnostic accuracy for these indications. Following this, we present our assessment of primary studies comparing accuracy of one imaging modality to another for TNM staging of rectal and colorectal cancer. These sections are organized by the type of staging under consideration. We also present results of studies of the impact of imaging on therapeutic management. We then present reports of adverse events associated with the imaging techniques and the patient, disease, and technical factors that affect the accuracy of the imaging studies. The results for Key Question 2, on restaging cancer in patients with primary and recurrent rectal and colorectal cancer after initial treatment, are presented in a similar fashion.

A list of acronyms and abbreviations is available following the list of references for this report. The Appendixes include Appendix A. Search Strategy, Appendix B. Excluded Studies, Appendix C. Evidence Tables and Appendix D. Analyses and Risk of Bias Assessments.

## Results of Literature Searches

The study selection process is summarized in Figure 2. The literature searches identified 4,683 citations. After review of the abstracts of these articles in duplicate, 4,473 were excluded. The most common reason for exclusion was lack of relevancy to the key questions (off topic). Some of the excluded narrative reviews and patterns of care articles were used to inform the background section and the patterns of care section. In all, 210 articles were retrieved in full, 31 of which were thought to be systematic reviews and were screened against the systematic review inclusion criteria, and 179 that were thought to be clinical studies and were screened against the clinical study inclusion criteria. See the “Methods” chapter for the inclusion criteria. After screening the articles in duplicate, 8 systematic reviews and 65 primary clinical studies were included. See Appendix B for a list of the excluded studies.

Figure 2 Study flow diagram

Figure 2 shows a study flow diagram. The large number of citations identifed by the literature searches enters the flow diagram at the top. Abstract screening then occurs, and those citations excluded during abstract screening exit the flow diagram to the right, listed in a large box with reasons for exclusion. Continuing down the flow diagram, the number of articles retrieved (210) for full-article screening are shown in a box, and then they are screened against the full inclusion criteria. Exlcluded articles exit the diagram to the right, and are listed in a large box with reasons for exclusion. Continuing down the flow diagram, at the bottom the number of included studies (8 systematic reviews and 65 primary studies) are shown.

## Test Performance of Imaging Modalities for Pretreatment Staging

Key Question 1. What is the comparative effectiveness of imaging techniques for pretreatment cancer staging in patients with primary and recurrent colorectal cancer?

Key Question 1a What is the test performance of the imaging techniques used (singly, in combination, or in a specific sequence) to stage colorectal cancer compared with a reference standard?

### Key Points

We addressed Key Question 1a using systematic reviews supplemented by assessment of primary studies if insufficient evidence from systematic reviews was available. Seven recent (2009 or later) high-quality systematic reviews met the inclusion criteria for this question (Table 6) and analyzed accuracy of ERUS, MRI, CT, and PET/CT for staging colorectal cancer. There was insufficient information from systematic reviews for PET/CT, so primary studies were used to assess the test performance of PET/CT.

Table 6 Included systematic reviews addressing accuracy of ERUS, MRI, CT, or PET/CT

Study | Modalities Studied | Condition | Databases Searched | Dates Searched | Inclusion Criteria | Primary Method of Analysis | Number of Articles | Number of Patients | Study Quality
Gall et al. 2013^84^ | ERUS (mini-probe only) | Colorectal | MEDLINE, EMBASE, Cochrane | Through January 2013 | Studies of mini-probe ERUS for staging of colon cancer or mixed colorectal that used histopathology as the reference standard and staged using the TNM system. | Bivariate and hierarchical summary receiver operating characteristics model | 10 total; 5 included patients with colon cancer only, 5 had mixed colorectal populations | 642 total; 210 colon cancer | All studies had 8 or more of the 14 QUADAS items
Puli et al. 2009^85^ | ERUS | Rectal cancer | MEDLINE, PubMed, EMBASE, CINAHL, Cochrane, DARE, Healthstar | 1966 to January 2008 | Full-length published studies of rectal cancer N staging confirmed by surgical histology that reported sufficient data to construct 2×2 tables | Random-effects or fixed-effects pooling of sensitivity/specificity separately | 35 | 2,732 | All of the studies fulfilled 4 to 5 out of the 14 QUADAS items
Puli et al. 2009^14^ | ERUS | Rectal cancer | MEDLINE, PubMed, EMBASE, CINAHL, Cochrane, DARE, Healthstar | 1980 to January 2008 | Full-length published studies of T staging rectal cancer with endoscopic ultrasound using surgical histology as the reference standard and sufficient data to construct 2×2 tables | Random-effects or fixed-effects pooling of sensitivity/specificity separately | 42 | 5,039 | All of the studies fulfilled 4 to 5 out of the 14 QUADAS items
Al-Sukhni et al. 2012^86^ | MRI | Rectal cancer | MEDLINE, EMBASE, Cochrane | January 2000 to March 2011 | English-language original published reports of MRI using a phase-array coil, histopathology as the reference standard, and sufficient data reported to construct 2×2 tables | Bivariate random-effects model and hierarchical summary receiver operating characteristics model | 19 studies for T stage, 12 studies for N stage, 10 studies for CRM | 1,986 patients for T stage, 1,249 patients for N stage, 986 patients for CRM | 62% of the studies had 10 or more of the 13 modified QUADAS items
Dighe et al. 2010^16^ | CT | Colon cancer primarily, a few studies mixed colorectal | MEDLINE, EMBASE, Cochrane | Through March 5, 2009 | Published preoperative N staging using histopathology as the reference standard and sufficient data reported to calculate TP, TN, FP, and FN | Bivariate random-effects model | 19 total; 17 reported on T stage, 15 on N stage | 907 total, 784 T stage, 674 N stage | 53% of studies scored 12 or higher on the QUADAS items
Lu et al. 2012^87^ | PET/CT, PET | Colorectal cancer | MEDLINE, PubMed, EMBASE | Through February 2012 | Full-length published articles of nodal staging by PET or PET/CT in patients with colorectal cancer with sufficient data reported to derive 2×2 tables | Random-effects or fixed-effects pooling of sensitivity/specificity separately | 8 PET, 2 PET/CT | 83 PET/CT, 326 PET | On the Cochrane Diagnostic Tests tool, the mean quality score was 59.2%, Range: 33% to 83%
Niekel et al. 2010^15^ | CT, MRI, PET/CT | Colorectal liver metastases | MEDLINE, EMBASE, Cochrane, CINAHL, Web of Science | January 1990 to January 2010 | Prospective full-length, published articles with at least 10 patients with histo­pathologically proven colorectal cancer undergoing evaluation for liver metastases that reported sufficient data to allow calculation of sensitivity and specificity | Random-effects or fixed-effects pooling of sensitivity/specificity separately | 25 CT, 18 MRI, 5 PET/CT | 3,391 | 65% of the studies had 6 or more of the 10 modified QUADAS items

CINAHL=Cumulative Index to Nursing and Allied Health Literature; CRM=circumferential resection margin; DARE=Database of Reviews of Effectiveness; ERUS=endorectal ultrasound; FN=false negative; FP=false positive; MRI=magnetic resonance imaging; N=nodal stage; PET=positron emission tomography; PET/CT=positron emission tomography/computed tomography; QUADAS=quality assessment tool for diagnostic accuracy studies; T=tumor stage; TN=true negative; TP=true positive.

### Detailed Synthesis

#### Endoscopic Rectal Ultrasound

One group (Puli et al.) conducted two systematic reviews of the accuracy of ERUS for staging rectal cancer; one of the reviews covered nodal (N) staging; the other covered tumor (T) staging. Another group conducted a systematic review of colorectal staging, but using a particular type of probe (mini-probe) only. The results are summarized in Table 7.

Table 7 Results from included systematic reviews for endoscopic rectal ultrasound

Study | Included Articles | Number of Patients | Primary Results | Author's Conclusion
Gall et al. 2013^84^ | 10 | 642 | T1: sensitivity 91% (95% CI, 76 to 97%), specificity 98% (95% CI, 97 to 99); T2 sensitivity 78% (95% CI, 62 to 88), specificity 94% (95% CI, 91 to 96); T3/T4: sensitivity 97% (95% CI, 91 to 99), specificity 90% (95% CI 85 to 94); N: sensitivity 63% (95% CI 47 to 77), specificity 82% (95% CI 73 to 89). | Mini-probe ERUS is effective in staging colorectal cancer.
Puli et al. 2009^85^ | 35 | 2,732 | [underlined: ERUS for N staging]: Sensitivity of 73.2% (95% CI, 70.6 to 75.6); Specificity 75.8% (95% CI, 73.5 to 78.0), +LR 2.84 (95% CI, 2.16 to 3.72), -LR 0.42 (95% CI, 0.33 to 0.52) | ERUS is an important and accurate diagnostic tool for evaluating nodal metastasis of rectal cancers. This meta-analysis shows that the sensitivity and specificity of ERUS is moderate.
Puli et al. 2009^14^ | 42 | 5,039 | [underlined: ERUS for T1]: Sensitivity 87.8% (95% CI, 85.3 to 90.0), Specificity 98.3% (95% CI, 97.8 to 98.7), +LR 44.0 (95% CI, 22.7 to 85.5), -LR 0.16 (95% CI, 0.13 to 0.23) | As a result of the demonstrated sensitivity and specificity, ERUS should be the investigation of choice to T stage rectal cancers. The sensitivity of ERUS is higher for advanced disease than for early disease.
Puli et al. 2009^14^ | 42 | 5,039 | [underlined: ERUS for T2]: Sensitivity 80.5% (95% CI, 77.9 to 82.9), Specificity 95.6% (95% CI, 94.9 to 96.3), +LR 17.3 (95% CI, 11.9 to 24.9), -LR 0.22 (95% CI, 0.17 to 0.29)
Puli et al. 2009^14^ | 42 | 5,039 | [underlined: ERUS for T3]: Sensitivity 96.4% (95% CI, 95.4 to 97.2), Specificity 90.6% (95% CI, 89.5 to 91.7), +LR 8.9 (95% CI, 6.8 to 11.8), -LR 0.06 (95% CI, 0.04 to 0.09)
Puli et al. 2009^14^ | 42 | 5,039 | [underlined: ERUS for T4]: Sensitivity 95.4% (95% CI, 92.4 to 97.5), Specificity 98.3% (95% CI, 97.8 to 98.7), +LR 37.6 (95% CI, 19.9 to 71.0), -LR 0.14 (95% CI, 0.09 to 0.23)

CI=Confidence interval; ERUS=endoscopic rectal ultrasound; +LR=positive likelihood ratio; -LR=negative likelihood ratio; N=nodal stage; T=tumor stage.

##### Publication Bias

Puli et al. concluded that there was no evidence of publication bias in 2009; however, a systematic review published in 2005 (thus, not included to address the key questions) concluded that “the performance of EUS [endoscopic ultrasound] in staging rectal cancer may be overestimated in the literature due to publication bias.”13 The review included 41 studies published between 1985 and 2003. The author, Harewood, performed visual analyses of funnel diagrams and other plots, demonstrating that there appeared to be few smaller studies that found lower accuracy rates and that the reported accuracy appeared to be declining over time. Studies published in the surgical literature reported higher accuracies than studies published in other types of journals.13 Declining accuracy over time and non-random patterns of accuracy in different types of journals both suggest the presence of publication and/or reporting bias.

Puli et al. also analyzed the reported accuracy of ERUS over time and found that the reported accuracy had declined significantly from the 1980s through 2000 and had stabilized or only declined slightly since.14 Gall et al. did not assess the possibility of publication bias.84

#### Computed Tomography

Two groups published systematic reviews of the use of T for staging colorectal cancer; their results are summarized in Table 8.

Table 8 Results from included systematic reviews for computed tomography

Study | Included Articles | Number of Patients | Primary Results | Author's Conclusion
Niekel et al. 2010^15^ | 25 CT, 18 MRI, 5 PET/CT | 3,391 | Sensitivity of CT for liver metastasis: 83.6% | The sensitivity of CT was lower than either MRI or PET imaging.
Dighe et al. 2010^16^ | 19 total; 17 reported on T stage, 15 on N stage | 907 total, 784 T stage, 674 N stage | CT T1/T2 differentiate from T3/T4 sensitivity 86% (95% CI, 78 to 92%), specificity 78% (95% CI, 71 to 84%) | Preoperative staging CT accurately distinguishes between tumors confined to the bowel wall and those invading beyond the MP; however, it is significantly poorer at identifying nodal status. MDCT provides the best results.
Dighe et al. 2010^16^ | 19 total; 17 reported on T stage, 15 on N stage | 907 total, 784 T stage, 674 N stage | CT T3 from T4 sensitivity 92% (95% CI, 87% to 95%), specificity 81% (95% CI, 70 to 89%)
Dighe et al. 2010^16^ | 19 total; 17 reported on T stage, 15 on N stage | 907 total, 784 T stage, 674 N stage | CT N stage sensitivity 70% (95% CI, 59% to 80%), specificity 78% (95% CI, 66 to 86%)

CI=Confidence interval; CT=computed tomography; MDCT=multidetector computed tomography; MP=muscularis propria; MRI=magnetic resonance imaging; N=nodal stage; PET/CT=positron emission tomography/computed tomography; T=tumor stage.

##### Publication Bias

Niekel et al. reported no evidence of publication bias for distant metastasis (M) staging by CT, but Dighe et al. reported that for N staging with CT there was evidence that smaller studies were reporting higher accuracies (suggesting publication bias) and that there was a nonsignificant trend showing the same result for T staging.16

#### Magnetic Resonance Imaging

Two groups reported on the accuracy of MRI, one for staging colorectal cancer (Niekel et al.) and the other for rectal cancer (Al-Sukhni et al.), summarized in Table 9.

Table 9 Results from included systematic reviews for MRI

Study | Included Articles | Number of Patients | Primary Results | Author's Conclusion
Al-Sukhni et al. 2012^86^ | 19 studies for T stage, 12 studies for N stage, 10 studies for CRM | 1,986 patients for T stage, 1,249 patients for N stage, 986 patients for CRM | [underlined: MRI for N]: sensitivity 77% (95% CI, 69% to 84), specificity 71% (95% CI, 59% to 81%) | “MRI has good accuracy for both CRM and T category and should be considered for preoperative rectal cancer staging. In contrast, lymph node assessment is poor on MRI.”
Al-Sukhni et al. 2012^86^ | 19 studies for T stage, 12 studies for N stage, 10 studies for CRM | 1,986 patients for T stage, 1,249 patients for N stage, 986 patients for CRM | [underlined: MRI for T]: sensitivity 87% (95% CI, 81% to 92%), specificity 75% (95% CI, 68% to 80%) | “MRI has good accuracy for both CRM and T category and should be considered for preoperative rectal cancer staging. In contrast, lymph node assessment is poor on MRI.”
Al-Sukhni et al. 2012^86^ | 19 studies for T stage, 12 studies for N stage, 10 studies for CRM | 1,986 patients for T stage, 1,249 patients for N stage, 986 patients for CRM | [underlined: MRI for CRM]: sensitivity 77% (95% CI, 57 to 90), specificity 94% (95% CI, 88 to 97) | “MRI has good accuracy for both CRM and T category and should be considered for preoperative rectal cancer staging. In contrast, lymph node assessment is poor on MRI.”
Niekel et al. 2010^15^ | 25 CT, 18 MRI, 5 PET/CT | 3,391 | Sensitivity of MRI for liver metastasis: 88.2% | “MRI imaging is the preferred first-line modality for evaluating colorectal liver metastases in patients who have not had earlier therapy.”

CI=confidence interval; CRM=circumferential resection margin; MRI=magnetic resonance imaging; N=nodal stage; PET/CT=positron emission tomography/computed tomography; T=tumor stage.

##### Publication Bias

Niekel et al. reported there was no evidence of publication bias in the MRI staging literature.15

#### Positron Emission Tomography/Computed Tomography

One group (Lu et al.) published a systematic review on the accuracy of PET/CT for staging colorectal cancer, summarized in Table 10; however, they pooled data from eight studies of stand-alone PET with two studies of PET/CT. Another group (Niekel et al.) also published a systematic review on PET/CT, but concluded there was insufficient data.

Table 10 Results from included systematic reviews of PET/CT

Study | Included Articles | Number of Patients | Primary Results | Author's Conclusion
Lu et al. 2012^87^ | 8 PET, 2 PET/CT | 83 PET/CT, 326 PET | The sensitivity of PET for detecting involved lymph nodes was 42.9% (95% CI, 36.0 to 50.0%); the specificity was 87.9% (95% CI, 82.6 to 92.0). | There is no solid evidence to support the routine clinical application of PET (PET/CT) in the pretherapeutic evaluation of lymph node status in patients with colorectal cancer.
Niekel et al. 2010^15^ | 25 CT, 18 MRI, 5 PET/CT | 3,391 | Sensitivity of PET/CT for liver metastasis: data were too limited. | The role of PET/CT is unclear because of the small number of studies.

CI=Confidence interval; CT=computed tomography; MRI=magnetic resonance imaging; PET=positron emission tomography; PET/CT=positron emission tomography/computed tomography.

Because there were insufficient recent (2009 or later) high-quality systematic reviews on PET/CT, we searched for high-quality, older systematic reviews but did not identify any that met the inclusion criteria. We therefore examined the studies of PET/CT included in this report to address the comparative questions; these results are summarized in Table 11.

Table 11 Results from included primary studies for PET/CT

Study | Number of Patients | Primary Results
Kim et al. 2011^88^ | 30 primary rectal | Rectal N staging: sensitivity 61%, specificity 83%
Uchiyama et al. 2012^89^ | 77 colorectal | Colorectal T staging: accuracy 95.0% Colorectal N staging: sensitivity 34.3%, specificity 100% Colorectal M staging: sensitivity 93.8%
Ramos et al. 2011^19^ | 70 colorectal | Colorectal M staging: sensitivity 72% (per lesion basis)
Orlacchio et al. 2009^90^ | 467 colorectal | Colorectal M staging: sensitivity 97.9%, specificity 97.7%
Lubezky et al. 2007^91^ | 27 colorectal | Colorectal M staging: sensitivity 93.3%

M=Distant metastasis stage; N=nodal stage; PET/CT=positron emission tomography/computed tomography; T=tumor stage.

##### Publication Bias

Neither systematic review on PET/CT evaluated the possibility of publication bias.

## Comparative Test Performance of Imaging Modalities for Pretreatment Staging

### Key Points

- ERUS is more accurate (odds ratio [OR]=0.36; 95% CI, 0.24 to 0.54), less likely to understage (OR=0.63; 95% CI, 0.44 to 0.89), and less likely to overstage (OR=0.47; 95% CI, 0.28 to 0.80) rectal cancer than CT in the preoperative T staging setting. Strength of evidence is low.
- There is no significant difference in accuracy between MRI and ERUS or between MRI and CT for preoperative rectal T staging. Strength of evidence is low.
- There is no significant difference in accuracy across CT, MRI, or ERUS for preoperative rectal N staging. MRI is less likely than CT to overstage (OR=0.498, 95% CI, 0.308 to 0.806). Strength of evidence is low.
- MRI is superior to CT in detecting colorectal liver metastases in the preoperative setting (OR=1.334; 95% CI, 1.012 to 1.761). Strength of evidence is moderate.
- The evidence was insufficient for drawing conclusions about the accuracy of PET/CT compared to either MRI or CT for rectal T, N, or M staging.

### Detailed Synthesis

#### Preoperative Rectal Tumor Staging

We identified 23 studies of preoperative rectal T staging (summarized in Table 12). Six studies compared MRI with ERUS, 13 compared CT with ERUS, three compared MRI with CT, and one study compared CT, MRI, and ERUS.

Table 12 Preoperative rectal T staging

Study | Compares | Number of Patients | Design | Risk of Bias
Barbaro et al. 1995^92^ | CT, MRI, ERUS | 13 | Cohort | Moderate
Yimei et al. 2012^93^ | MRI to ERUS | 129 | Cohort | Moderate
Halefoglu et al. 2008^94^ | MRI to ERUS | 34 | Cohort | Low
Bianchi et al. 2005^95^ | MRI to ERUS | 49 | Cohort | Moderate
Starck et al. 1995^96^ | MRI to ERUS | 35 | Prospective cohort | Moderate
Thaler et al. 1994^97^ | MRI to ERUS | 34 | Prospective cohort | Low
Waizer et al. 1991^98^ | MRI to ERUS | 13 | Prospective cohort | Moderate
Ju et al. 2009^99^ | CT to ERUS | 78 | Cohort | Moderate
Kim et al. 1999^100^ | CT to ERUS | 89 | Cohort | Moderate
Osti et al. 1997^101^ | CT to ERUS | 63 | Cohort | Moderate
Ramana et al. 1997^102^ | CT to ERUS | 10 | Prospective cohort | Moderate
Goldman et al. 1991^103^ | CT to ERUS | 29 | Prospective cohort | Moderate
Pappalardo et al. 1990^104^ | CT to ERUS | 14 | Prospective cohort | Moderate
Rotte et al. 1989^105^ | CT to ERUS | 25 | Cohort | Moderate
Waizer et al. 1989^106^ | CT to ERUS | 58 | Prospective cohort | Moderate
Beynon et al. 1986^107^ | CT to ERUS | 44 | Prospective cohort | Moderate
Kramann and Hildebrandt 1986^108^ | CT to ERUS | 29 | Cohort | Moderate
Rifkin and Wechsler 1986^109^ | CT to ERUS | 79 | Prospective cohort | Moderate
Rifkin, McGlynn, and Marks 1986^110^ | CT to ERUS | 54 | Prospective cohort | Moderate
Romano et al. 1985^111^ | CT to ERUS | 23 | Cohort | Moderate
Matsuoka et al. 2003^112^ | MRI to CT | 21 | Prospective cohort | Moderate
Guinet et al. 1990^113^ | MRI to CT | 19 | Cohort | Moderate
Hodgman et al. 1986^114^ | MRI to CT | 30 | Cohort | Moderate

CT=Computed tomography; ERUS=endorectal ultrasound; MRI=magnetic resonance imaging.

The data reported by the six studies of MRI versus ERUS for rectal T staging are shown in Appendix C. The diagnostic test characteristics reported by the five studies that reported diagnostic test characteristics are shown below, in Figure 3. We pooled the reported diagnostic data in a binomial-bivariate model of the diagnostic accuracy of distinguishing between T1/T2 and T3/T4 stages, and we also pooled the accuracy, over-, and understaging data in random-effects models. The full bivariate model and summary receiver operating characteristic (HSROC) curves are shown in Appendix D. The complete results of the random-effects models are reported in Appendix D and are summarized below, in Table 13. All of our analyses indicated that there was no significant difference between the MRI and ERUS. The level of study limitations was medium, and the data were consistent and direct but not very precise (wide confidence intervals); therefore, the strength of evidence is low.

Figure 3 MRI versus ERUS accuracy for rectal T staging

Graphical representation in ROC space of reported data for MRI (left side) vs. ERUS (right side) for rectal T staging. The data points for each study are shown as black diamonds. The diagonal line represents chance.

Figure 3 shows the data for MRI versus ERUS accuracy for rectal T staging in ROC space

Table 13 Summary results for primary preoperative rectal T staging

Test Characteristics | MRI vs. ERUS | ERUS vs. CT | MRI vs. CT
Sensitivity (95% CI) of T1/T2 vs. T3/T4 | [underlined: MRI]: 88.9% (79.0% to 94.4%) [underlined: ERUS]: 88.0% (80.0% to 93.1%) | Not calculated | Not calculated
Specificity (95% CI) of T1/T2 vs. T3/T4 | [underlined: MRI]: 85.3% (70.6% to 93.4%) [underlined: ERUS]: 85.6% (65.8% to 94.9%) | Not calculated | Not calculated
Accuracy: OR of getting an incorrect result (95% CI)^a^ | 1.24 (0.835 to 1.84) | 0.359 (0.238 to 0.541) | 0.317 (0.056 to 1.784)^b^
Understaging OR (95% CI)^a^ | 1.571 (0.605 to 4.083) | 0.626 (0.438 to 0.894) | 0.317 (0.027 to 3.646) (based on Guinet et al.113 , n=19)
Overstaging OR (95% CI)^a^ | 1.05 (0.518 to 2.16) | 0.472 (0.28 to 0.798) | 0.317 (0.028 to 3.653) (based on Matsuoka et al. 2003^112^ , n=21)
Favors | No statistical difference | ERUS | No statistical difference

CI=Confidence interval; CT=computed tomography; ERUS=endorectal ultrasound; MRI=magnetic resonance imaging.

a OR < 1 indicates a lower risk of error in the first imaging modality listed in the column header; OR > 1 indicates a higher risk of error in the first imaging modality listed in the column header.

b Study with 0.15T magnet excluded from analyses.

The data reported by the 13 studies of CT versus ERUS for rectal T staging are shown in Appendix C. Because many of the studies reported insufficient data to calculate sensitivity and specificity, we pooled only the accuracy, over-, and understaging data in random-effects models. The full results of the analyses are shown in Appendix D and are shown graphically below in Figure 4 and Figure 5. The results are summarized below, in Table 13. ERUS was statistically significantly more accurate than CT and was statistically significantly less likely to over- or understage rectal cancer than CT. The level of study limitations was medium, and the data were consistent and direct but not precise (wide confidence intervals); although the effect size was large it was not extremely large; therefore, the strength of evidence is low.

Figure 4 CT versus ERUS: risk of rectal T overstaging

Figure 4 shows a forest plot of the data. Each point is a study. Points to the left of the center line favor ERUS, whereas points to the right of the center line favor CT. The results are also presented in the text.

Figure 5 CT versus ERUS: risk of rectal T understaging

Figure 5 shows a forest plot of the data. Each point is a study. Points to the left of the center line favor ERUS, whereas points to the right of the center line favor CT. The results are also presented in the text.

The data reported by the three studies of MRI versus CT are shown in Appendix C. The oldest study, Hodgman et al., used an obsolete 0.15 tesla magnet MRI device and reported that CT was more accurate than this MRI device. The other two studies used more modern MRI machines and reported higher accuracy rates for MRI than for CT for rectal T staging, but the results did not reach statistical significance (Figure 6). This may be due to lack of power, as the accuracy analysis only included 40 patients, and the understaging and overstaging data come from one small study each.

Figure 6 MRI versus CT rectal T accuracy

Figure 6 shows a forest plot of the studies comparing MRI to CT for accuracy of rectal T staging. The results are also presented in the text.

One study by Barbaro et al.92 compared CT, MRI, and ERUS for rectal T staging. The data reported by this study are shown in Appendix C. The authors concluded that for rectal T staging, ERUS was most accurate, MRI was slightly less accurate than ERUS, and CT was less accurate than either MRI or ERUS.

Two studies (Blomqvist et al.115 and Fleshman et al.116) also reported on the accuracy of staging performed before neoadjuvant therapy, using surgery after the treatment as the reference standard. The lag time and treatment given may confound the results of these studies—namely, the pretreatment stage may have been correctly identified by the imaging modality, but by the time surgery/histopathology had been performed, the patient's stage may have changed. The Blomqvist study compared MRI with CT in a retrospective analysis of patients with locally advanced cancer who underwent neoadjuvant chemotherapy before surgery. The data reported by the study are shown in Appendix C. The accuracy of both CT and MRI was reported to be quite poor (44.4% and 46.2%, respectively) but should be interpreted carefully because of the potentially confounding factors. The Fleshman study compared CT with ERUS in a prospective study of patients with advanced rectal tumors who underwent neoadjuvant radiation therapy before surgery. Similar to the other study, Fleshman reported that both modalities had very poor accuracy for pretreatment T staging (53% for CT and 32% for ERUS), but had excellent accuracy for N staging (both modalities had 100% negative predictive value for affected lymph nodes). Again, the results should be interpreted carefully because of the potentially confounding factors.

#### Preoperative Rectal Nodal Staging

We identified 19 studies that reported data on rectal N staging (summarized in Table 14). One study compared MRI with PET/CT, five compared MRI with ERUS, nine compared CT with ERUS, and four compared MRI with CT.

Table 14 Preoperative rectal nodal staging

Study | Compares | Number of Patients | Design | Risk of Bias
Kim et al. 2011^88^ | MRI to PET/CT | 30 | Retrospective cohort | Moderate
Yimei et al. 2012^93^ | MRI to ERUS | 129 | Retrospective controlled trial | Moderate
Halefoglu et al. 2008^94^ | MRI to ERUS | 34 | Cohort | Low
Bianchi et al. 2005^95^ | MRI to ERUS | 49 | Cohort | Moderate
Starck et al. 1995^96^ | MRI to ERUS | 35 | Prospective cohort | Moderate
Thaler et al. 1994^97^ | MRI to ERUS | 34 | Prospective cohort | Low
Ju et al. 2009^99^ | CT to ERUS | 78 | Cohort | Moderate
Kim et al. 1999^100^ | CT to ERUS | 89 | Cohort | Moderate
Osti et al. 1997^101^ | CT to ERUS | 63 | Cohort | Moderate
Ramana et al. 1997^102^ | CT to ERUS | 10 | Prospective cohort | Moderate
Goldman et al. 1991^103^ | CT to ERUS | 29 | Prospective cohort | Moderate
Pappalardo et al. 1990^104^ | CT to ERUS | 14 | Prospective cohort | Moderate
Rotte et al. 1989^105^ | CT to ERUS | 25 | Cohort | Moderate
Rifkin and Wechsler 1986^109^ | CT to ERUS | 79 | Prospective cohort | Moderate
Rifkin, McGlynn, and Marks 1986^110^ | CT to ERUS | 54 | Prospective cohort | Moderate
Arii et al. 2004^117^ | MRI to CT | 53 | Prospective cohort | Moderate
Matsuoka et al. 2003^112^ | MRI to CT | 21 | Prospective cohort | Moderate
Guinet et al. 1990^113^ | MRI to CT | 19 | Cohort | Moderate
Hodgman et al. 1986^114^ | MRI to CT | 30 | Cohort | Moderate

CT=Computed tomography; ERUS=endorectal ultrasound; MRI=magnetic resonance imaging.

Kim et al. compared MRI with PET/CT for rectal N staging. The data reported by Kim et al. are shown in Appendix C. MRI had superior sensitivity over PET/CT for detecting affected lymph nodes (94% vs. 61%, respectively), but PET/CT had a higher specificity (83% vs. 67%, respectively). The authors concluded that MRI is preferable for rectal N node staging because missing affected lymph nodes is a more clinically serious error than false-positive findings.

The data reported by the five studies that compared MRI with ERUS for rectal N staging are shown in Appendix C. We pooled the data in a binomial-bivariate regression model; full details of the results and HSROC curves are shown in Appendix D. We also pooled the accuracy, over-, and understaged data in random-effects models. The full details of these results are shown in Appendix D. The results of the analyses are summarized below, in Table 15. The bivariate model suggests that ERUS had a slightly higher sensitivity and specificity than MRI, but the confidence intervals overlap, indicating the difference is probably not significant. The accuracy, overstaging and understaging comparisons of ERUS and MRI did not find statistically significant differences. Therefore, we conclude that for preoperative rectal N staging, MRI and ERUS are similar in accuracy. The level of study limitations was medium; the data were consistent and direct but not precise (wide confidence intervals), so the strength of evidence supporting this conclusion is low.

Table 15 Summary results for rectal N staging

Test Characteristics | MRI vs. ERUS | CT vs. ERUS | MRI vs. CT
Sensitivity (95% CI) | [underlined: MRI]: 49.5% (36.0% to 63.1%) [underlined: ERUS]: 53.0% (39.7% to 65.5%) | [underlined: CT]: 39.6% (28.1% to 52.4%) [underlined: ERUS]: 49.1% (34.9% to 63.5%) | Not calculated
Specificity (95% CI) | [underlined: MRI]: 69.7% (51.9% to 83.0%) [underlined: ERUS]: 73.7% (43.6% to 91.0%) | [underlined: CT]: 93.2% (58.8% to 99.2%) [underlined: ERUS] 71.7% (56.2% to 83.4%) | Not calculated
Accuracy: OR of getting an incorrect result (95% CI)^a^ | 0.882 (0.542 to 1.408) | 1.13 (0.85 to 1.503) | 1.316 (0.709 to 2.443)
Understaging OR (95% CI)^a^ | 0.972 (0.563 to 1.679) | 1.453 (0.854 to 2.473) | 1.743 (1.028 to 2.957) (not robust in sensitivity analysis)
Overstaging OR (95% CI)^a^ | 0.752 (0.457 to 1.237) | 1.015 (0.571 to 1.801) | 0.498 (0.308 to 0.806)
Favors | Not statistically different | Not statistically different | CT favored for avoiding understaging, and MRI favored for avoiding overstaging

CI=Confidence interval; CT=computed tomography; ERUS=endorectal ultrasound; MRI=magnetic resonance imaging.

a OR < 1 indicates a lower risk of error in the first imaging modality listed in the column header; OR > 1 indicates a higher risk of error in the first imaging modality listed in the column header.

The data reported by the nine studies that compared CT with ERUS are shown in Appendix C. We pooled the data in a binomial-bivariate regression model; full details of the results and HSROC curves are shown in Appendix D. We also pooled the accuracy, over-, and understaging data in random-effects models. The full details of these results are shown in in Appendix D. The results are summarized in Table 15, below. The bivariate model indicates no significant differences in sensitivity or specificity. The results of the accuracy, over-, and understaging analyses also indicated no significant difference. The level of study limitations was medium; the data were consistent and direct but not precise (wide confidence intervals), so the strength of evidence supporting this conclusion is low.

The data reported by the four studies that compared MRI with CT are shown in Appendix C. Because only three of the four reported sensitivity and specificity, we did not compute a bivariate model. However, we pooled the data for accuracy, over-, and understaging in a random-effects model. The full results are shown in Appendix D and summarized below in Table 15. The accuracy analysis indicated no significant difference between the two modalities; however, MRI is less likely than CT to overstage (OR = 0.498, 95% CI, 0.308 to 0.806). CT appears to be less likely to understage than is MRI, but the result did not remain statistically significant in sensitivity analyses when we varied the correlation for tests performed in the same subjects. Table 16 provides a list of factors we considered that may have impacted the results, but we did not have sufficient data to explore this further.

Table 16 Rectal N staging: differences between studies in various factors

Factor | MRI vs. ERUS | CT vs. ERUS | MRI vs. CT
Date of publication | 40% before 2000 60% after 2005 | 88% before 2000 11% after 2005 | 33% before 2000 0 after 2005
Patient age | Mean: 58.7 to 68 years | 67% did not report | Means 62 to 66 years
Percentage of male patients | 44.1% to 68% | 54% to 70% | 58.8% to 74%
CT details | Not applicable | 22% rectal air 11% rectal contrast 56% oral contrast 33% IV contrast 11% bowel prep | 25% rectal air 50% rectal contrast 50% oral contrast 100% IV contrast 25% bowel prep
MRI details | 20% rectal air 0% IV contrast 20% bowel prep 20% 3T magnet 50% 1.0 and 1.5T magnets 20% 0.3T magnet 100% T2 weighting 60% T1 weighting | Not applicable | 50% rectal air 25% IV contrast 25% bowel prep 50% 1.5T magnet 25% 0.5T magnet 25% 0.15T magnet 100% T2 weighting 100% T1 weighting

CT=Computed tomography; IV=intravenous; MRI=magnetic resonance imaging; T=tesla

#### Preoperative Recurrent Rectal Staging

One study reported on staging recurrent rectal cancer (Milsom et al.118). The study included a prospective comparison of CT with ERUS for staging of biopsy-proven, recurrent rectal cancer in 14 patients. The data are presented in Appendix C. The authors reported that ERUS was better than CT for predicting the extent of local organ invasion (i.e., bladder, rectum, prostate). However, one small (n=14) study is insufficient to support an evidence-based conclusion.

#### Preoperative Rectal Circumferential Margin Status

Only one study reported information about assessing circumferential margin (CRM) status. The study directly compared MRI with CT for this purpose (Taylor et al.119). The study was retrospective in design and examined the records of 42 patients, who were examined by T1- and T2-weighted 1.5T MRI with a phased-array coil and CT using intravenous contrast; no intravenous contrast agent was used for the MRI examinations. See Table C-42 in Appendix C for the reported data. CT was reported to be more accurate than MRI in assessing CRM status (64.3% vs. 54.8%, respectively); the authors concluded that both modalities tended to overstage CRM status but rarely understage it. The study was rated as being at moderate risk of bias, but a single study is insufficient to support an evidence-based conclusion.

#### Preoperative Colon Staging

We did not identify any studies of staging that enrolled patients who had only colon cancer (not mixed with rectal cancer cases) that met the inclusion criteria.

#### Preoperative Colorectal Tumor Staging

We identified only one study that reported on preoperative colorectal T staging (Uchiyama et al.89). The study was a prospective comparison of CT versus PET/CT on a mixed group of patients with rectal and colon cancer. See Appendix C for the data reported by this study. The authors reported that PET/CT was to be preferred for T staging because it had a higher accuracy (95.0% vs. 78.8%, respectively). Rates of over- and understaging were not reported, nor was the sensitivity or specificity of the modalities for distinguishing between T1/T2 stages and T3/T4 stages. A single study is insufficient to support an evidence-based conclusion.

#### Preoperative Colorectal Nodal Staging

We identified only one study that reported on preoperative colorectal N staging (Uchiyama et al.89). The study was a prospective comparison of CT versus PET/CT in a mixed group of patients with rectal and colon cancer. See Appendix C for the data reported by this study. The authors reported that CT was preferable over PET/CT for N staging because it had a much higher sensitivity for detecting patients with affected lymph nodes (68.6% vs. 34.3%, respectively), although PET/CT was better than CT at identifying patients without affected lymph nodes (100% and 72.5% specificity, respectively). Although the study was rated as moderate risk of bias, a single study is insufficient to support an evidence-based conclusion.

#### Preoperative Colorectal Metastasis Staging

We identified nine studies of preoperative colorectal M staging (summarized in Table 17). Four compared PET/CT with CT, and five compared MRI with CT.

Table 17 Preoperative colorectal M staging

Study | Compares | Number of Patients | Design | Risk of Bias
Uchiyama et al. 2012^89^ | PET/CT to CT | 77 colorectal | Prospective cohort | Moderate
Ramos et al. 2011^19^ | PET/CT to CT | 70 colorectal | Prospective cohort | Moderate
Orlacchio et al. 2009^90^ | PET/CT to CT | 467 colorectal | Cohort | Moderate
Lubezky et al. 2007^91^ | PET/CT to CT | 27 colorectal | Cohort | Moderate
Bartolozzi et al. 2004^120^ | MRI to CT | 44 colorectal | Prospective cohort | Low
Bhattacharjya et al. 2004^121^ | MRI to CT | 100 colorectal | Prospective cohort | Moderate
Bohm et al. 2004^122^ | MRI to CT | 24 colorectal | Prospective cohort | Moderate
Lencioni et al. 1998^123^ | MRI to CT | 14 colorectal | Prospective cohort | Low
Strotzer et al. 1997^124^ | MRI to CT | 35 colorectal | Prospective cohort | Low

CT=computed tomography; MRI=magnetic resonance imaging; PET/CT=positron emission tomography/computed tomography.

Unlike the other studies of PET/CT versus CT, Uchiyama et al. enrolled patients for T, N, and M staging; the other studies enrolled patients to specifically look for suspected liver metastases; therefore, we decided to not include Uchiyama in the meta-analysis. Lubezky et al. reported data on a per-patient basis, and the other two remaining studies reported data on a per-lesion basis. We therefore decided to pool only the data from Orlacchio et al. and Ramos et al. in a random-effects meta-analysis of sensitivity for detecting colorectal liver metastases (per lesion basis). See Appendix C for the data reported by all four studies.

We were able to calculate the lesion detection rate on a per-lesion basis for all five studies of MRI versus CT; therefore, we pooled data from all five in a random-effects meta-analysis. See Appendix C for the data reported by these studies.

The results of the two meta-analyses are summarized in Table 18. MRI was superior to CT, and the difference was statistically significant. CT was superior to PET/CT, and the confidence intervals around the summary effect measure did not overlap, suggesting the difference is statistically significant. The level of study limitations for the CT-versus-MRI data set was low. The data were consistent and direct but not precise. Thus, we graded the overall strength of evidence for MRI versus CT as moderate. For PET/CT versus CT, the level of study limitations was medium; but the results were neither consistent nor precise, so we graded the strength of evidence supporting that conclusion as insufficient.

Table 18 Pooled random-effects analyses for preoperative colorectal M staging (per lesion basis)

Measure | CT vs. MRI | PET/CT vs. CT
Sensitivity | Not calculated | [underlined: CT]: 83.6% (95% CI, 78.1% to 88.2%) [underlined: PET/CT]: 60.4% (95% CI, 53.7% to 66.9%)
Summary OR for lesion detection ratea | 1.334 (95% CI 1.012 to 1.761) | Not calculated
I^2^ | 36% | [underlined: CT]: 0.0% [underlined: PET/CT]: 95.1%
Favors | MRI | Insuffficient evidence

CI=Confidence interval; CT=computed tomography; MRI=magnetic resonance imaging; PET/CT=positron emission tomography/computed tomography.

OR > 1 indicates greater likelihood of detecting metastatic lesions by the first imaging modality in the column header.

## Comparative and Additive Impact of Imaging Modalities on Stage Reclassification and Management

Key Question 1b. What is the impact of alternative imaging techniques on intermediate outcomes, including stage reclassification and changes in therapeutic management?

### Key Points

- MRI and ERUS were assessed for primary rectal cancer treatment decisionmaking but pooled results were not statistically significant.
- Addition of ERUS to CT during primary rectal cancer treatment resulted in changes in management, but appropriateness was not assessed. Strength of evidence was graded as insufficient.
- Addition of PET/CT to CT for preoperative rectal cancer staging resulted in changes in management, but in the one study measuring appropriateness, changes were appropriate in only half of the instances. Strength of evidence was graded as insufficient.

### Detailed Synthesis

#### Magnetic Resonance Imaging Versus Endorectal Ultrasound

Two studies that met the inclusion criteria reported on patient management based on MRI or ERUS for preoperative rectal staging (Yimea et al.93 and Brown et al.125). Both studies used a similar design: for each patient, the investigators devised a theoretical treatment strategy based solely on MRI information, they devised another theoretical treatment strategy based solely on ERUS information, and then they used a third strategy based on clinical information, MRI, and ERUS data to actually treat the patient. The histopathology after surgery was used to define the “correct” treatment strategy that should have been used. See Appendix C for the results reported by the studies. We pooled the results from both studies in a random-effects meta-analysis. We analyzed the outcomes “correct treatment,” “undertreatment,” and “overtreatment.” All three analyses favored MRI as the more accurate modality for treatment planning, but none reached statistical significance. See Appendix D for details of the meta-analyses.

#### Endorectal Ultrasound Added to Computed Tomography Staging

Two studies that met the inclusion criteria reported the impact of adding ERUS information to CT results for preoperative staging of rectal cancer (Wickramasinghe and Samarasekera126 and Harewood et al.127). One study reported that 25 percent of patients had a change in management after adding the ERUS information, but whether the change was appropriate was not measured or reported. The other study reported that 31 percent of patients had a change in management after adding the ERUS information, primarily changes from surgery to neoadjuvant therapy. Whether the changes were appropriate was not measured or reported. For more information, see Appendix C. Because of the lack of measuring whether the changes were appropriate, we graded this evidence base as insufficient to support an evidence-based conclusion.

#### Positron Emission Tomography/Computed Tomography Added to Conventional Staging

Two studies that met the inclusion criteria reported the impact of adding PET/CT results to CT results for preoperative staging of colorectal cancer (Engledow et al.128 and Ramos et al.19). Engledow et al. reported that adding PET/CT results changed management for 34 percent of the patients, but whether the change was appropriate was not measured or reported. Ramos et al. reported that adding PET/CT to CT results changed management for 17.5 percent of patients, but after treatment, surgery, and followup, results indicated that only half of the changed treatment plans were the appropriate choice. For more information, see Appendix C.

One study (Eglinton et al.129) examined 19 patients with rectal cancer for preoperative staging with PET/CT, MRI, CT, and clinical information and developed a treatment plan in-house. The information from the MRI, CT, and clinical information, but not the PET/CT information, was sent to a different institution, where a treatment plan was developed. The two treatment plans were compared. Minor changes were made to treatment plans for five patients, most of whom had stage IV cancer. The appropriateness of the changes was not measured or reported. For more information, see Appendix C. Because only one study measured the appropriateness of the treatment plan changes, we graded the evidence base as insufficient to support an evidence-based conclusion.

## Comparative and Additive Impact of Imaging Modalities on Clinical Outcomes

Key Question 1c. What is the impact of alternative imaging techniques on clinical outcomes?

We did not identify any studies that addressed the question of the impact of alternative imaging techniques on clinical outcomes.

## Adverse Effects Associated With Imaging Techniques

Key Question 1d. What are the adverse effects or harms associated with using imaging techniques, including harms of test-directed management?

### Key Points

- Serious adverse effects are rare with ERUS, but patients do report varying degrees of discomfort during the procedure, and some procedures cannot be completed due to presence of strictures, stenosis or angulation of the rectum.
- Rare but potential harms of MRI are associated with use of gadolinium-based contrast agents.
- Harms of CT include radiation exposure and adverse events from intravenous contrast agents.
- Harms from PET/CT include radiation exposure from the CT component and from the tracer used for PET.

### Detailed Synthesis

To address the question of harm associated with using imaging techniques, we abstracted data about harms reported by the included studies (see Appendix C). We supplemented this information with information from narrative reviews and other sources (e.g., U.S. Food and Drug Administration [FDA] alerts). Additionally, we systematically searched for information on harms related to the imaging modalities of interest (regardless of condition or disease state). Our search strategy is shown in Appendix A. Our searches identified 1,961 abstracts; after review of these abstracts, we selected 66 articles to review in full text. Our inclusion criteria for the supplemental harms searches were that the articles must have been published in English and specifically focused on adverse events from CT, MRI, PET/CT, or ERUS in any patient population. Clinical studies must have been published in 2008 or later, and narrative reviews must have been published in 2012 or later. After full-text review, we included 32 studies reporting on general harms from CT130-144, ERUS145-149, MRI140,150-160, and PET/CT.140,161

We did not grade the strength of evidence for harms because we combined information drawn from a wide range of sources.

#### Endorectal Ultrasound

Ultrasound is generally considered to be extremely safe. Ultrasound examinations that use microbubble contrast agents have the potential for patients to react to the agents, but most reactions appear to be transient and mild, consisting of alteration of taste, facial flushing, and pain at the injection site; however, contrast agents are rarely if ever used for ERUS.162 As long as routine practices are followed, ultrasound imaging can generally be considered a safe exam for most patients.

For colorectal imaging, an additional consideration is the fact that an endorectal probe is inserted into the rectum. Possible complications include perforation, bleeding, and pain. The majority of included studies of ERUS did not report any complications; whether this means that none occurred is unclear. Six studies reported adverse events. One study (Rifkin et al.110) reported that all 51 patients experienced mild discomfort during the procedure. One study (Milsom et al.118) measured the level of discomfort experienced using a visual analog scale and reported the mean discomfort level as a 3 (with a 10 representing maximal pain). Three studies (Pomerri et al.163, Huh et al.164, and Brown et al.125) reported that some (11% to 38%) of the patients experienced severe pain during the procedure. Two studies (Rifkin and Wechsler109 and Rifkin et al.110) reported some (4% to 10%) patients had minor rectal bleeding after the procedure. ERUS cannot be performed in some patients because of tight stenosis or the lesion being too far from the anal verge. Four of the studies reported instances of incomplete procedures due to strictures, stenosis or angulations.96,97,105,165 (See Appendix C.)

The supplemental harms searches identified a narrative review of complications of endoscopic ultrasound, including ERUS.17 The authors commented on the rarity of ERUS-related perforation, and noted that only one case had been reported in a prospective registry of the German Society of Ultrasound in Medicine.17 While the multicenter registry includes nearly 12,000 endoscopic ultrasound examinations, the number of ERUS procedures was not reported in the review.

#### Computed Tomography

None of the included studies reported any adverse events related to CT.

CT scans expose the body to x-rays. A typical abdominal CT scan exposes the body to approximately 10 mSv of radiation.166 Cadwallader et al.136 reported results from 198 scans of at-risk patients to determine the risk of fatal cancer induction. Forty-one (20.7%) scans did not alter management of the patient and were thus deemed as unnecessarily exposing patients to CT radiation. According to the National Cancer Institute, the extra risk of one person for developing a fatal cancer from the radiation from a single CT procedure is about 1 in 2,000.^167^

The supplemental harms searches identified 15 studies of more than 190,000 patients reported on CT-related adverse events (all related to the administration of contrast agents).130-144 Most studies administered nonionic contrast agents, whereas two studies administered iothalamate meglumine, an ionic contrast agent.141,143 Nonionic contrast agents, introduced in the 1970s, have a lower osmolarity than blood and are therefore less likely to cause adverse reactions.144 Nonionic contrast agents evaluated included iopromide,130,133,140,141,144 iomeprol,130,131,144 iohexol,130,131,138 iopamidol,131,132,137,139,144 iodixanol,130,139 and ioversol.131,135,141,144

Three of the 15 studies reported only mild-to-moderate harms,130,139,143 but eight of the 15 studies reported serious/severe adverse events.131,134,135,137,140-142,144 Two studies reported 25 deaths within 30^142^ to 45 days134 after CT. Weisbord142 enrolled 421 patients thought to be at increased risk of developing contrast-induced acute kidney injury and reported 10 (2.4% of patients) deaths within 30 days after imaging.

Kobayashi et al.131 reported 23 (0.06%) severe reactions to contrast agents, including shock, hypotension, desaturation, and airway obstruction in a retrospective cohort study of 36,472 patients. Patients received various nonionic low-osmolar contrast agents; approximately half of the study population was diabetic (19.5%) or hypertensive (28.6%). Vogl et al.135 reported anaphylactoid adverse reactions requiring hospitalization in 4 (0.03%) patients receiving ioversol. Jung et al.144 focused on cutaneous adverse reactions in 47,388 patients receiving various nonionic monomers such as iomeprol. Severe reactions such as severe generalized urticaria and facial edema occurred in 16 patients. The three remaining studies reported shortness of breath (5 patients)140 and one case each of atrial fibrillation (patient on peritoneal dialysis),137 cyanosis,141 and severe laryngeal edema.141 See Appendix C for details on CT-related adverse events.

#### Magnetic Resonance Imaging

A patient undergoing an MRI exam faces many well-known safety hazards, including patient heating, pacemaker malfunction, dislodgment of metallic implants, peripheral nerve stimulation, acoustic noise, and radiofrequency-induced burns.168-173 MRI facilities take precautions to routinely screen patients for possible contraindications. Patients are routinely asked to wear earplugs and are given an emergency call button. No adverse effects have been conclusively identified in association with the magnetic fields to which patients are exposed during routine MRI scanning.174-177 Therefore, if routine precautions are followed, MRI can be considered a safe exam for most patients. A search for reports of patient discomfort did not find any reports of severe discomfort. In fact, to decrease patient motion, it is important that the patient be as comfortable as possible.45

Only two of the included studies reported adverse events due to MRI, both of which were of patients refusing the procedure due to severe claustrophobia (Pomerri et al.163 and Bhattacharjya et al.121).

The supplemental harms searches identified 12 studies of more than 157,000 patients reporting on MRI-related harms.140,150-160 Adverse events from contrast-enhanced MRIs were the focus of 11 (92%) of the 12 studies.140,150,151,153-160 See Appendix C for a list and description of the currently marketed contrast agents for MRI. Contrast-enhanced MRIs, widely used for more than 20 years, provide increased sensitivity and specificity of lesion detection.178 Although relatively safe in most patients, contrast agents may be quite harmful to others.

The American College of Radiology's (ACR) “ACR Manual on Contrast Media” (2013) indicates that patients with a history of earlier allergy-like reaction to contrast media, history of asthma, renal insufficiency, significant cardiac disease, and elevated anxiety are at an increased risk for adverse intravenous contrast material reactions.179 Some reactions may be life threatening or potentially fatal. In 2006, some gadolinium-based contrast agents (GBCAs) were linked with nephrogenic systemic fibrosis (NSF), a scleroderma-like, fibrosing condition, that could be potentially fatal in patients with renal failure.180 NSF is a progressive, disabling, and potentially fatal disorder that leads to deposition of excessive connective tissue in the skin and internal organs. The condition was previously unknown; the typical patient is a middle-aged individual with severe renal disease who first exhibits skin changes 2–4 weeks after undergoing an MRI examination that used gadolinium-based contrast agents.181

The ACR manual179 estimates that “patients with end-stage chronic kidney disease (CKD) (CKD5, eGFR <15 ml/min/1.73 m^2^) and severe CKD (CKD4, eGFR 15 to 29 ml/min/1.73 m^2^) have a 1 percent to 7 percent chance of developing NSF after one or more exposures to at least some GBCAs.” In 2010, FDA issued a warning about using GBCAs in patients with kidney dysfunction. Agents such as Magnevist, Omiscan, and OptiMark, FDA states, place certain patients with kidney dysfunction at higher risk for NSF than other GBCAs.182 FDA had previously issued a Public Health Advisory (2006) about the possible link between exposure to GBCAs for magnetic resonance angiography and NSF in patients with kidney failure.183 The FDA later (2007) required a box warning on product labeling of all GBCAs used in MRIs regarding the risk of NSF in patients with severe kidney insufficiency, patients just before or just after liver transplantation, or individuals with chronic liver disease.184

The largest study of MRI adverse events that we identified (n=84,621) included 19,354 (22.9%) patients with renal and liver dysfunctions, history of allergies, hypertension, chronic heart disease, and central nervous system disorders. All patients in this study received injections of gadolinium-based contrast agents.153 Four hundred twenty-one adverse events (65 different types) occurred in 285 out of the 84,621 patients (0.34%). Eight serious (3 life-threatening) adverse events (less than 0.01%) were reported.

See Appendix C for details on MRI-related adverse events.

#### Positron Emission Tomography/Computed Tomography

Using a typical dose of tracer (400 MBq) for a whole-body scan, the effective radiation dose delivered during a typical PET study is 7.6 mSv. The use of a combined CT/PET scanner also exposes the patient to x-rays. A typical abdominal CT scan exposes the body to approximately 10 mSv, for a total of around 18 mSv for a single PET/CT study.166 Studies of atomic-bomb survivors and radiation workers have found a significant increase in the risk of cancer after exposure to as little as 20 mSv.166 Therefore, radiation dose from PET/CT scans may be a health concern. After the exam, the short half‐life of 18F means that additional precautions, such as avoiding public transportation, are not necessary.185

None of the included studies reported any adverse events related to PET/CT.

The supplemental harms searches identified two studies of 3,360 patients that reported on PET/CT-related harms.140,161 Codreanu et al.161 reported mild harms (recurring body rash and itching from 18F‐fluorodeoxyglucose) in one male patient with pyriform sinus cancer and history of allergies. A retrospective review of 3,359 PET/CT scans (106,800 scans overall)140 reported four severe adverse events, including chest pain (2 patients) and shortness of breath (2 patients). See Appendix C for PET/CT-related harms.

## Factors Affecting Accuracy

Key Question 1e. How is the comparative effectiveness of imaging techniques modified by the following factors: patient-level characteristics (e.g., age, sex, body mass index); disease characteristics (e.g., tumor grade); and imaging technique or protocol characteristics (e.g., use of different tracers or contrast agents, radiation dose of the imaging modality, slice thickness, timing of contrast)?

### Key Points

- Only single studies addressed each of several factors affecting accuracy of ERUS for colorectal staging; the evidence was graded as insufficient.
- Only single studies addressed each of several factors affecting accuracy of CT for colorectal cancer staging; the evidence was graded as insufficient.

### Detailed Synthesis

#### Endorectal Ultrasound

Five studies reported factors affecting the accuracy of ERUS for colorectal staging (see Appendix C for details). Kim et al.186 reported that ERUS was more accurate for rectal T and N staging if the rectum was filled with water. Mo et al.165 reported that a miniprobe was slightly less accurate than a conventional probe for colorectal T staging, but the conventional probe was much more accurate than a miniprobe for colorectal N staging. Hunerbein et al.187 reported that three‐dimensional (3D) ERUS was slightly more accurate than two-dimensional (2D) ERUS for rectal T staging. Huh et al.164 reported that ERUS was much more accurate for rectal T staging when the tumor was located closer to the anal verge. Rafaelsen et al.188 reported that experienced readers were more accurate than inexperienced readers for rectal T and N staging. Because only one study reported on each factor, we graded the evidence base as insufficient to support an evidence-based conclusion.

#### Computed Tomography

Three studies reported factors affecting the accuracy of CT for colorectal staging (see Appendix C for more details). Skriver et al.189 reported that using intravenous contrast material did not improve CT's accuracy for rectal T and N staging. Lupo et al.190 reported that filling the rectum with water improved CT's accuracy for rectal T staging. Wicherts et al.191 reported that arterial and equilibrium-phase CT did not add any additional information to hepatic venous-phase CT for colorectal liver M staging. Because only one study reported on each factor, we graded the evidence base as insufficient to support an evidence-based conclusion.

#### Magnetic Resonance Imaging

Nine studies reported factors affecting the accuracy of MRI for colorectal staging (see Appendix C for more details). Rafaelsen et al.188 reported that experienced readers were more accurate than inexperienced readers for rectal T and N staging. Koh et al.192 reported that diffusion-weighted MRI was slightly more accurate than contrast-enhanced T1-/T2-weighted MRI for colorectal M staging. Jao et al. (2010)193 and Vliegen et al. (2005)194 compared gadolinium-enhanced T1-weighted MRI to T2-weighted MRI. Jao reported that the addition of contrast did not improve rectal T and N staging. Vliegen reported that contrast did not improve T staging and did not report data on N staging. Okizuka et al. (1996)195 reported that gadopentetate dimeglumine enhanced fat-suppressed MRI imaging was not better than conventional T1-and T2-weighted MRI for rectal T and N staging.

One study (Kim et al.196) reported that 2D and 3D T2-weighted imaging were equally accurate for rectal N and T staging, but Futterer et al.197 reported that 3D imaging was less accurate than 2D imaging for rectal T staging, and more motion artifacts appeared. Kim et al.196 reported that filling the rectum with water improved the accuracy of rectal T staging but did not affect the accuracy of rectal N staging.

In regard to colorectal M staging, Koh et al.192 reported that diffusion-weighted MRI was slightly more accurate than contrast-enhanced T1-/T2-weighted MRI for colorectal M staging, but that the combination was superior.

For cases in which only one study reported on each factor, we graded the evidence base as insufficient to support an evidence-based conclusion.

Two studies reported on 2D versus 3D imaging; the level of study limitations was judged to be medium, but because the evidence was inconsistent and a quantitative analysis could not be performed, we graded the evidence base as insufficient to support an evidence-based conclusion.

Three studies reported that contrast-enhancement did not improve the accuracy of MRI for rectal T and N staging. The level of study limitations of this evidence base was rated as low, and the evidence was qualitatively consistent and direct; however, a quantitative analysis could not be performed. We did not grade the strength of evidence for this outcome.

#### Positron Emission Tomography/Computed Tomography

No studies reported factors that affected the accuracy of PET/CT.

## Conclusions for Key Question 1

We compiled data from recent, high-quality systematic reviews to estimate the accuracy of each individual imaging modality in isolation (see Table 19 for a summary of these data). Because insufficient data existed on PET/CT from systematic reviews, we examined the studies of PET/CT included in this report to address the comparative questions to obtain an estimate of accuracy.

Table 19 Accuracy of imaging tests as reported by recent systematic reviews

Staging | ERUS | CT | MRI | PET/CT
Rectal T | [underlined: For identifying T1]: Sensitivity: 87.8% (85.3 to 90.0%) Specificity: 98.3% (97.8 to 98.7%) [underlined: For identifying T2]: Sensitivity: 80.5% (77.9 to 82.9%) Specificity: 95.6% (94.9 to 96.3%) [underlined: For identifying T3]: Sensitivity: 96.4% (95.4 to 97.2%) Specificity: 90.6% (89.5 to 91.7%) [underlined: For identifying T4]: Sensitivity: 95.4% (92.4 to 97.5%) Specificity: 98.3% (97.8 to 98.7%) | [underlined: For distinguishing T1/T2 from T3/T4]: Sensitivity: 86% (78 to 92%) Specificity: 78% (71 to 84%) | [underlined: For distinguishing T1/T2 from T3/T4]: Sensitivity: 87% (81 to 92%) Specificity: 75% (68 to 80%) [underlined: For identifying affected CRM]: Sensitivity: 77% (57 to 90%) Specificity: 94% (88 to 97%) | Not reported
Rectal N | [underlined: For identifying affected nodes]: Sensitivity: 73.2% (70.6 to 75.6%) Specificity: 75.8% (73.5 to 78.0%) | [underlined: For identifying affected nodes]: Sensitivity: 70% (59 to 80%) Specificity: 78% (66 to 86%) | [underlined: For identifying affected nodes]: Sensitivity: 77% (69 to 84%) Specificity: 71% (59 to 81%) | [underlined: For identifying affected nodes]: Sensitivity: 61% Specificity: 83%
Colorectal T | Mini-probe only: For identifying T1: Sensitivity: 91% (76 to 97%) Specificity: 98% (97 to 99%) For identifying T2: Sensitivity 78% (62 to 88%) Specificity: 94% (91 to 96%) For identifying T3+T4: Sensitivity: 97% (91 to 99%) Specificity: 90% (85 to 94%) | Not reported | Not reported | Accuracy: 95.0%
Colorectal N | Miniprobe only: For detecting affect nodes: Sensitivity 63% (47 to 77%) Specificity 82% (73 to 89%) | Not reported | Not reported | [underlined: For identifying affected nodes]: Sensitivity: 34.3% Specificity: 100%
Colorectal M | Not reported | [underlined: For identifying liver metastases]: Sensitivity 83.6% | [underlined: For identifying liver metastases]: Sensitivity: 88.2% | [underlined: For identifying liver metastases]: Sensitivity: 72% to 97.9%

CRM=Circumferential resection margin; CT=computed tomography; ERUS=endorectal ultrasound; M=metastases stage; MRI=magnetic resonance imaging; N=nodal stage; PET/CT=positron emission tomography/computed tomography; T=tumor stage; ( ) denotes the 95% confidence interval.

To determine the comparative effectiveness of the different modalities, we examined studies that directly compared modalities. For rectal T staging, ERUS is more accurate than CT (Strength of evidence is low.) ERUS and MRI appear to be similar in accuracy for rectal T staging as do MRI and CT (Strength of evidence is low.) The evidence was insufficient for drawing conclusions about the accuracy of PET/CT compared to either MRI or CT for rectal T staging.

For rectal N staging, ERUS, MRI, and CT all appear to be similar in accuracy, but they all have low sensitivity for detecting affected lymph nodes (upper bound of the confidence intervals for all 3 is less than 70%). MRI is less likely to overstage than is CT. (Strength of evidence is low.) The evidence was insufficient for drawing conclusions about the accuracy of PET/CT compared to either MRI or CT for rectal N staging.

For detecting colorectal liver metastases, MRI is superior to CT. (Strength of evidence is moderate.) The evidence was insufficient for drawing conclusions about the accuracy of PET/CT compared to either MRI or CT for colorectal M staging.

Three studies reported that contrast-enhancement did not improve the accuracy of MRI for rectal T and N staging. The level of study limitations of this evidence base was rated as low, and the evidence was qualitatively consistent and direct; however, a quantitative analysis could not be performed, and we did not assign an evidence grade.

The evidence base is characterized by a lack of studies reporting patient-oriented outcomes. Seven studies reported on the impact of imaging on patient management, but only three of these studies confirmed whether the change in management was appropriate. In general, the included studies reported only on diagnostic accuracy. They were all rated as either low or moderate risk of bias.

Too few studies exist for most of the evidence bases to allow a statistical analysis of the possibility of publication bias. However, because of reports that the ERUS literature, in particular, may be affected by publication bias, we have prepared funnel plots for the two larger ERUS evidence bases and have also run a meta-regression against publication date, all presented in Appendix D. While we recognize the limitations of funnel plots and of visual interpretation of them, the funnel plots do look fairly symmetrical. Also, there does not appear to be any pattern by date in the ERUS-versus-CT evidence base; there may be a tendency to report higher accuracy in older studies in the MRI-versus-ERUS evidence base, but the number of studies in that evidence base is too small to allow any conclusion to be reached.

## Comparative Test Performance of Imaging Modalities for Restaging After Initial Treatment

Key Question 2. What is the comparative effectiveness of imaging techniques for restaging cancer in patients with primary and recurrent colorectal cancer after initial treatment?

Key Question 2a What is the test performance of the imaging techniques used (singly, in combination, or in a specific sequence) to restage colorectal cancer compared with a reference standard?

### Key Points

As noted previously, interim restaging takes place after neoadjuvant chemotherapy and/or radiotherapy and in some cases, surgery. We attempted to address Key Question 2.a. using systematic reviews.

- We identified only one high-quality review of interim restaging that studied CT, MRI, and PET/CT for detecting colorectal liver metastases.
- MRI had a higher sensitivity for this purpose than the other modalities, but its sensitivity was still very low in this setting (69.9%, 95% CI: 65.6 to 73.9%).

### Systematic Reviews

We identified only one recent (2009 or later) high-quality systematic review of interim restaging. Therefore, we searched for older high-quality systematic reviews of interim restaging but found none that that met the inclusion criteria.

The systematic review that met the inclusion criteria, van Kessel et al. 2012, included five studies of CT, two studies of MRI, and two studies of PET/CT. All studies evaluated patients who had undergone neoadjuvant chemotherapy followed by surgery or patient followup (approximately 8% of the patients did not undergo surgery). The sensitivities of detecting liver metastases in the interim restaging setting were calculated and pooled using random-effects or fixed-effects meta-analysis. See tables in Appendix C for details of this review's methodology. The findings are summarized below, in Table 20. The authors used visual analysis of funnel plots to check for publication bias and did not identify any evidence of publication bias in this literature base.

Table 20 Results from included systematic review of interim restaging

Study | Included Articles | Number of Patients | Primary Results | Author's Conclusion
Van Kessel et al. 2012^198^ | 5 CT 3 MRI 2 PET/CT | 221 CT 54 MRI 137 PET/CT | Sensitivity for detecting colorectal liver metastases: CT 54.5% (95% CI, 46.7 to 62.1%) MRI 69.9% (95% CI, 65.6 to 73.9%) PET/CT 51.7% (95% CI, 37.8 to 65.4%) | MRI appears to be the most appropriate imaging modality for interim restaging of colorectal cancer liver metastases.

CT=computed tomography; MRI=magnetic resonance imaging; PET/CT=positron emission tomography/computed tomography

### Detailed Synthesis

#### Interim Rectal Tumor Restaging

We identified four studies of interim rectal T staging (summarized in Table 21). One study compared CT with MRI, one compared CT with ERUS, and two compared MRI, ERUS, and CT.

Table 21 Interim rectal T restaging

Study | Compares | N Patients | Design | Risk of Bias
Blomqvist et al. 2002^115^ | CT to MRI | 15 with locally advanced rectal cancer | Retrospective cohort | Moderate
Huh et al. 2008^164^ | CT to ERUS | 83 with locally advanced rectal cancer within 7 cm of anal verge | Retrospective cohort | Low
Martellucci et al. 2012^199^ | CT to ERUS to MRI | 37 with locally advanced rectal cancer | Prospective cohort | Moderate
Pomerri et al. 2011^163^ | CT to ERUS to MRI | 90 with primary rectal cancer | Prospective cohort | Low

CT=Computed tomography; ERUS=endorectal ultrasound; MRI=magnetic resonance imaging.

The two studies of CT, ERUS, and MRI reported data differently enough that the only measure we were able to pool across the two studies was accuracy (i.e., we could not pool sensitivity, sensitivity, under- or over-staging). See Appendix C for the data reported by the studies. We pooled the reported accuracies using random-effects meta-analysis. See Appendix D for the results of the meta-analysis. Essentially, there was no difference in accuracy across the various modalities (MRI vs. CT, 0.943 (95% CI: 0.652 to 1.34), MRI vs. ERUS, 0.948 (95% CI: 0.471 to 1.907), CT vs. ERUS, 0.907 (95% CI: 0.41 to 2.011)).

Blomqvist et al. compared CT with MRI for restaging locally advanced cancer after neoadjuvant radiochemotherapy. See Appendix C for the data reported by the study. MRI had a better accuracy than CT (60.0% correctly staged vs. 41.7%, respectively), equivalent sensitivity for distinguishing between T1/T2 and T3/T4 stages (90%), but a much lower specificity (33.3% vs. 66.7%, respectively). The authors concluded that MRI was not significantly better than CT.

Huh et al. compared CT to ERUS for restaging locally advanced cancer after neoadjuvant radiochemotherapy. See Appendix C for the data reported by the study. The authors reported that both modalities were inaccurate for T staging (46.3% correctly staged for CT, 38.3% for ERUS), with high rates of both over- and understaging.

Considering all the evidence above together in a narrative fashion, the evidence seems to consistently support the conclusion that no significant difference exists in accuracy across CT, ERUS, and MRI for interim rectal T staging. The the level of study limitations was medium, the evidence was consistent and direct. However, a quantitative analysis cannot be done and the precision cannot be measured; therefore, the strength of evidence is low.

#### Interim Rectal Nodal Restaging

We identified three studies of interim rectal N restaging (summarized in Table 22). One study compared CT with ERUS, and two studies compared MRI, CT, and ERUS.

Table 22 Interim rectal N restaging

Study | Compares | Number of Patients | Design | Risk of Bias
Huh et al. 2008^164^ | CT to ERUS | 83 with locally advanced rectal cancer within 7 cm of anal verge | Retrospective cohort | Low
Martellucci et al. 2012^199^ | CT to ERUS to MRI | 37 with locally advanced rectal cancer | Prospective cohort | Moderate
Pomerri et al. 2011^163^ | CT to ERUS to MRI | 90 with primary rectal cancer | Prospective cohort | Low

CT=Computed tomography; ERUS=endorectal ultrasound; MRI=magnetic resonance imaging.

Huh et al. compared CT with ERUS for restaging locally advanced cancer after neoadjuvant radiochemotherapy. See Appendix C for the data reported by the study. The authors reported that CT was more sensitive than ERUS (56% vs. 50%, respectively) for detecting affected lymph nodes, but CT had a lower specificity than ERUS (74.5% vs. 81.1%, respectively). The authors concluded that neither modality was good for restaging rectal cancer.

The two studies comparing CT, MRI, and ERUS reported data sufficiently differently that only the accuracy data could be pooled quantitatively in a random-effects meta-analysis. See Appendix C for the data reported by these two studies. See Appendix D for the results of the meta-analysis. There were no statistically significant differences across the modalities, but there was a nonsignificant trend for ERUS to be more accurate than MRI and CT, and MRI to be more accurate than CT.

Two of the studies (Huh et al. and Pomerri et al.) concluded that there was no significant difference across modalities, and the third concluded that ERUS was more accurate. Our meta-analysis found a trend towards ERUS being more accurate. To explore the inconsistency further, we have summarized characteristics of the studies, patients, and imaging details that may explain the different results in Table 23, below. There is no obvious reason for the discrepancy, but the study that found ERUS to be more accurate had very low accuracies for MRI and CT compared with the two studies that considered them all approximately equal; in comparison, the reported accuracy for ERUS was similar across studies.

Table 23 Details of studies of interim rectal N restaging

Study | Design | Patients | CT Methods | MRI Methods | ERUS Methods
Huh et al. 2008^164^ | Retrospective, university- based, in Korea; mean 46 days between treatment and restaging | Locally advanced cancer near anal verge, mean age 54, 63% male | Rectal contrast, 2 readers in consensus, 70.4% accuracy | Not done | 360 rotating, 7.5 or 10 MHz, 1 highly experienced reader, 72.6% accuracy
Martellucci et al. 2012^199^ | Prospective, university- based, in Italy; 30–60 days between treatment and restaging | Locally advanced cancer, mean 65.5 years, 73% male | No information reported other than 3 readers in consensus, 56.5% accuracy | No information reported other than 3 readers in consensus, 55% accuracy | Enema before examination, 1 highly experienced reader, 75.5% accuracy
Pomerri et al. 2011^163^ | Prospective, university- based, in Italy; 30 days between treatment and restaging | Primary rectal, median age 61, 61% male | IV contrast, 3 readers in consensus, 62% accuracy | IV contrast, enema, 1 T magnet, T1- and T2-weighted, phased-array surface coil, 3 readers in consensus, 68% accuracy | Enema before examination, rotating radial 5 to 10 MHz, 1 reader, 65% accuracy

CT=Computed tomography; ERUS=endorectal ultrasound; IV=intravenous; MRI=magnetic resonance imaging.

Considering the evidence base as a whole, the level of study limitations is medium. The evidence is somewhat inconsistent; the results of the meta-analysis are imprecise (wide confidence intervals); and the conclusion is unclear. We cannot determine whether there is significant difference across modalities or whether ERUS is slightly more accurate. Therefore, we grade the evidence as insufficient to support a conclusion as to which modality is more accurate.

#### Interim Rectal Metastasis Restaging

No studies that met the inclusion criteria reported on interim rectal M restaging.

#### Interim Rectal Circumferential Margin Status Restaging

We identified one study that reported on interim rectal CRM status. Pomerri et al.163 conducted a prospective comparison of MRI and CT on 86 patients. The MRI was performed on a 1 Tesla machine, T1- and T2-weighted with a phased-array coil and with IV contrast agents. CT was also conducted with IV contrast material. See Appendix C for details on the reported data. MRI was more accurate than CT (85% vs. 71%, respectively) and more specific (88% vs. 74%, respectively). The authors concluded MRI can accurately identify a tumor-free CRM after neoadjuvant therapy. Although the study was rated as being at low risk of bias, a single study is insufficient to support an evidence-based conclusion.

#### Interim Colon Restaging

No studies that met the inclusion criteria reported on interim colon cancer restaging separately (namely, without mixing rectal cancer cases into the enrolled group).

#### Interim Colorectal Tumor and Nodal Restaging

No studies that met the inclusion criteria reported on interim colorectal T and N restaging.

#### Interim Colorectal Metastasis Restaging

We identified four studies of interim colorectal M restaging (summarized in Table 24). Three compared MRI with CT, and one compared PET/CT with CT. The study that compared PET/CT with CT reported that CT had a higher sensitivity (65.3% for CT vs. 49% for PET/CT) but a lower specificity (75% for CT vs. 83.3% for PET/CT) for detecting colorectal liver metastases. See Appendix C for the reported data. Because only one study compared PET/CT to CT, we graded the evidence as insufficient to support an evidence-based conclusion.

Table 24 Interim colorectal M restaging

Study | Compares | Number of Patients | Design | Risk of Bias
Berger-Kulemann et al. 2012^200^ | CT to MRI | With fatty liver, 23 | Prospective cohort | Low
Kulemann et al. 2011^201^ | CT to MRI | With fatty liver, 20 | Retrospective cohort | Moderate
van Kessel et al. 2011^202^ | CT to MRI | 20 | Prospective cohort | Moderate
Lubezky et al. 2007^91^ | CT to PET/CT | 48 | Cohort | Moderate

CT=Computed tomography; MRI=magnetic resonance imaging; PET/CT=positron emission tomography/computed tomography.

We pooled the data reported by the three studies of MRI compared with CT for detecting liver metastases. The results indicated a nonsignificant trend toward MRI being more accurate at detecting colorectal liver metastases than CT, but there was considerable heterogeneity in the data (I^2^=85%). Because the data are inconsistent, we graded the evidence as insufficient to support a conclusion.

## Comparative and Additive Impact of Imaging Modalities on Stage Reclassification and Management

Key Question 2b. What is the impact of alternative imaging techniques on intermediate outcomes, including stage reclassification and changes in therapeutic management?

No studies that met the inclusion criteria addressed this question.

## Comparative and Additive Impact of Imaging Modalities on Clinical Outcomes

Key Question 2c. What is the impact of alternative imaging techniques on clinical outcomes?

No studies that met the inclusion criteria addressed this question.

## Adverse Effects Associated With Imaging Techniques

Key Question 2d. What are the adverse effects or harms associated with using imaging techniques, including harms of test-directed management?

See the answer to Key Question 1d for harms associated with any use of these imaging tests.

## Factors Affecting Accuracy

Key Question 2e. How is the comparative effectiveness of imaging techniques modified by the following factors: patient-level characteristics (e.g., age, sex, body mass index); disease characteristics (e.g., tumor grade); and imaging technique or protocol characteristics (e.g., use of different tracers or contrast agents, radiation dose of the imaging modality, slice thickness, timing of contrast)?

Two studies of MRI reported on factors affecting interim restaging accuracy. Lambregts et al.203 performed MRI using T2 and diffusion weighted imaging after neoadjuvant chemotherapy for rectal cancer. The authors reported that diffusion-weighted MRI was unable to identify malignant lymph nodes. The other study, Macera et al.,204 used MRI to detect liver metastases after neoadjuvant chemotherapy and concluded that a combination of contrast-enhanced T2 and diffusion-weighted MRI was more accurate than either modality in isolation. See Appendix C for more details. Because only one study reported information, the evidence base was graded as insufficient to support an evidence-based conclusion.

## Conclusions for Key Question 2

We attempted to address Key Question 2.a. using systematic reviews but identified only one high-quality review of interim restaging that studied CT, MRI, and PET/CT for detecting colorectal liver metastases. MRI had a higher sensitivity for this purpose than the other modalities, but its sensitivity was probably too low in this setting to be considered clinically useful (69.9%, 95% CI: 65.6 to 73.9%).

We found that there was no significant difference in accuracy across ERUS, CT, and MRI for interim rectal T-staging and that there was a nonsignificant trend for MRI to be more accurate than CT for detecting colorectal liver metastases during restaging.

The primary conclusion to be reached for Key Question 2 is that there are gaps in the research that has been published. The evidence base is small and limited. Nine studies addressed Key Question 2. The studies were all rated as being at moderate or low risk of bias. The risk of bias ratings are provided in Appendix D. Too few studies exist to allow assessment of the possibility of publication bias using either visual analysis of funnel plots or statistical methods.