# References

1 American Cancer Society (ACS). Cancer facts & figures 2012. Atlanta (GA). American Cancer Society (ACS). 2012. 65 p. Also available: http://www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-031941.pdf.
2 American Cancer Society (ACS). Colorectal cancer facts & figures 2011-2013. Atlanta (GA). American Cancer Society (ACS). 2011. 27 p. Also available: http://www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-028323.pdf.
3 Yabroff KR, Lund J, Kepka D, et al. Economic burden of cancer in the United States: estimates, projections, and future research. Cancer Epidemiol Biomarkers Prev. Oct. 2011;20(10):2006-14. [pmid: 21980008].
4 Mariotto AB, Yabroff KR, Shao Y, et al. Projections of the cost of cancer care in the United States: 2010-2020. J Natl Cancer Inst. Jan. 19. 2011;103(2):117-28. [pmid: 21228314].
5 Screening for colorectal cancer. [internet]. Rockville (MD). United States Preventive Task Force (USPSTF). 2009. Mar. 2013 Jan 23. [2 p]. Available: http://www.uspreventiveservicestaskforce.org/uspstf/uspscolo.htm.
6 White CM, Ip S, McPheeters M, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Methods guide for Comparative Effectiveness Reviews. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2009. Sep. Also available: http://effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60. [pmid: 21433402].
7 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
8 Owens D, Lohr K, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality (AHRQ). Methods guide for comparative effectiveness reviews. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2009. Jul. Also available: http://effectivehealthcare.ahrq.gov/ehc/products/122/328/2009_0805_grading.pdf.
9 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. http://effectivehealthcare.ahrq.gov/ehc/products/246/558/Methods-Guide-for-Medical-Test-Reviews_Full-Guide_20120530.pdf.
10 Harbord RM, Deeks JJ, Egger M, et al. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. Apr. 2007;8(2):239-51. [pmid: 16698768].
11 STATA statistics/data analysis. MP parallel edition. College Station (TX). StataCorp. 1984-2007. Single user Stata for Windows. Also available: http://www.stata.com.
12 Zamora J, Abraira V, Muriel A, et al. Meta-DiSc: a software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. [pmid: 16836745].
13 Harewood GC. Assessment of publication bias in the reporting of EUS performance in staging rectal cancer. Am J Gastroenterol. Apr. 2005;100(4):808-16. [pmid: 15784023].
14 Puli SR, Bechtold ML, Reddy JB, et al. How good is endoscopic ultrasound in differentiating various T stages of rectal cancer? Meta-analysis and systematic review. Ann Surg Oncol. Feb. 2009;16(2):254-65. [pmid: 19018597].
15 Niekel MC, Bipat S, Stoker J. Diagnostic imaging of colorectal liver metastases with CT, MR imaging, FDG PET, and/or FDG PET/CT: a meta-analysis of prospective studies including patients who have not previously undergone treatment. Radiology. Dec. 2010;257(3):674-84. [pmid: 20829538].
16 Dighe S, Purkayastha S, Swift I, et al. Diagnostic precision of CT in local staging of colon cancers: a meta-analysis. Clin Radiol. Sep. 2010;65(9):708-19. [pmid: 20696298].
17 Jenssen C, Alvarez-Sanchez MV, Napoleon B, et al. Diagnostic endoscopic ultrasonography: assessment of safety and prevention of complication. World J Gastroenterol. Sep. 14. 2012;18(34):4659-76. [pmid: 23002335].
18 Radiation risk in perspective. Position statement of the Health Physics Society. McLean (VA). Health Physics Society. 2010. Jul. 4 p. Also available: http://hps.org/documents/radiationrisk.pdf.
19 Ramos E, Valls C, Martinez L, et al. Preoperative staging of patients with liver metastases of colorectal carcinoma. Does PET/CT really add something to multidetector CT?. Ann Surg Oncol. Sep. 2011;18(9):2654-61. [pmid: 21431987].
20 Stewart SL, Wike JM, Kato I, et al. A population-based study of colorectal cancer histology in the United States, 1998-2001. Cancer. Sep. 1. 2006;107(5 Suppl):1128-41. [pmid: 16802325].
21 Kelloff GJ, Schilsky RL, Alberts DS, et al. Colorectal adenomas: a prototype for the use of surrogate end points in the development of cancer prevention drugs. Clin Cancer Res. Jun. 1. 2004;10(11):3908-18. Also available: http://clincancerres.aacrjournals.org/content/10/11/3908.full.pdf. [pmid: 15173100].
22 Schatzkin A, Freedman LS, Dawsey SM, et al. Interpreting precursor studies: what polyp trials tell us about large-bowel cancer. J Natl Cancer Inst. Jul. 20. 1994;86(14):1053-7. [pmid: 7802771].
23 Levine JS, Ahnen DJ. Clinical practice. Adenomatous polyps of the colon. N Engl J Med. Dec. 14. 2006;355(24):2551-7. [pmid: 17167138].
24 Cheng X, Chen VW, Steele B, et al. Subsite-specific incidence rate and stage of disease in colorectal cancer by race, gender, and age group in the United States, 1992-1997. Cancer. Nov. 15. 2001;92(10):2547-54. [pmid: 11745188].
25 Cheng L, Eng C, Nieman LZ, et al. Trends in colorectal cancer incidence by anatomic site and disease stage in the United States from 1976 to 2005. Am J Clin Oncol. Dec. 2011;34(6):573-80. [pmid: 21217399].
26 Dukes CE. The classification of cancer of the rectum. J Pathol Bacteriol. 1932;35:323.
27 Astler VB, Coller FA. The prognostic significance of direct extension of carcinoma of the colon and rectum. Ann Surg. Jun. 1954;139(6):846-52. [pmid: 13159135].
28 Halappa VG, Villalobos CPC, Bonekamp S, et al. Rectal imaging: Part 1, high-resolution MRI of carcinoma of the rectum at 3 T. AJR Am J Roentgenol. Jul. 2012;199(1):W35-W42. [pmid: 22733930].
29 Valentini V, Cellini F. Management of local rectal cancer: evidence, controversies and future perspectives in radiotherapy. Colorectal Cancer. Apr. 2012;1(2):163-77.
30 Kaur H, Choi H, You YN, et al. MR imaging for preoperative evaluation of primary rectal cancer: practical considerations. Radiographics. Mar-Apr. 2012;32(2):389-409. [pmid: 22411939].
31 National Comprehensive Cancer Network (NCCN). NCCN clinical practice guidelines in oncology: colon cancer V3.2013 [slide set]. Fort Washington (PA). National Comprehensive Cancer Network (NCCN). 2012. Nov. 26. 120 p. Also available: http://www.nccn.org/professionals/physician_gls/pdf/colon.pdf.
32 Fazel R, Krumholz HM, Wang Y, et al. Exposure to low-dose ionizing radiation from medical imaging procedures. N Engl J Med. Aug. 27. 2009;361(9):849-57. [pmid: 19710483].
33 Cartana ET, Parvu D, Saftoiu A. Endoscopic ultrasound: current role and future perspectives in managing rectal cancer patients. J Gastrointest Liver Dis. Dec. 2011;20(4):407-13. [pmid: 22187707].
34 Burtin P, Rabot AF, Heresbach D, et al. Interobserver agreement in the staging of rectal cancer using endoscopic ultrasonography. Endoscopy. Sep. 1997;29(7):620-5. [pmid: 9360871].
35 Athanasiou A, Tardivon A, Ollivier L, et al. How to optimize breast ultrasound. Eur J Radiol. Jan. 2009;69(1):6-13. [pmid: 18818037].
36 Odegaard S, Nesje LB, Laerum OD, et al. High-frequency ultrasonographic imaging of the gastrointestinal wall. Expert Rev Med Devices. May. 2012;9(3):263-73. [pmid: 22702257].
37 Sehgal CM, Weinstein SP, Arger PH, et al. A review of breast ultrasound. J Mammary Gland Biol Neoplasia. Apr. 2006;11(2):113-23. [pmid: 17082996].
38 Martinoli C, Pretolesi F, Crespi G, et al. Power doppler sonography: clinical applications. Eur J Radiol. May. Suppl 2. 1998;27:S133-40. [pmid: 9652513].
39 Quality and safety: ultrasound accreditation. [internet]. Reston (VA). American College of Radiology (ACR). 2013 May 9. [2 p]. Available: http://www.acr.org/Quality-Safety/Accreditation/Ultrasound.
40 Paakko E, Reinikainen H, Lindholm EL, et al. Low-field versus high-field MRI in diagnosing breast disorders. Eur Radiol. Jul. 2005;15(7):1361-8. [pmid: 15711841].
41 Beets-Tan RG. MRI in rectal cancer: the T stage and circumferential resection margin. Colorectal Dis. Sep. 2003;5(5):392-5. [pmid: 12925068].
42 Buchbender C, Heusner TA, Lauenstein TC, et al. Oncologic PET/MRI, part 1: tumors of the brain, head and neck, chest, abdomen, and pelvis. J Nucl Med. Jun. 2012;53(6):928-38. [pmid: 22582048].
43 de Souza NM, Kyriazi S, Sala E. Diffusion-weighted magnetic resonance imaging in pelvic cancer. Curr Med Imaging Rev. May. 2012;8(2):92-9.
44 Heywang-Kobrunner SH, Bick U, Bradley WG Jr, et al. International investigation of breast MRI: results of a multicentre study (11 sites) concerning diagnostic parameters for contrast-enhanced MRI based on 519 histopathologically correlated lesions. Eur Radiol. 2001;11(4):531-46. [pmid: 11354744].
45 Coulthard A, Potterton AJ. Pitfalls of breast MRI. Br J Radiol. Jun. 2000;73(870):665-71. [pmid: 10911793].
46 Kuhl CK, Schild HH. Dynamic image interpretation of MRI of the breast. J Magn Reson Imaging. Dec. 2000;12(6):965-74. [pmid: 11105038].
47 Lee CH. Problem solving MR imaging of the breast. Radiol Clin North Am. Sep. 2004;42(5):919-34. [pmid: 15337425].
48 Partridge SC, Heumann EJ, Hylton NM. Semi-automated analysis for MRI of breast tumors. Stud Health Technol Inform. 1999;62:259-60. [pmid: 10538368].
49 MedWatch. Information on Gadolinium-containing contrast agents. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). 2009. Aug. 13. 2010 Mar 17. Available: http://www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/ucm142882.htm.
50 Fowler KJ, Linehan DC, Menias CO. Colorectal liver metastases: state of the art imaging. Ann Surg Oncol. Apr. 2013;20(4):1185-93. Epub 2012 Nov 1. [pmid: 23115006].
51 Sardanelli F, Iozzelli A, Fausto A. Contrast agents and temporal resolution in breast MR imaging. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):69-75. [pmid: 12585658].
52 Knopp MV, Bourne MW, Sardanelli F, et al. Gadobenate Dimeglumine-enhanced MRI of the breast: analysis of dose response and comparison with Gadopentetate Dimeglumine. AJR Am J Roentgenol. Sep. 2003;181(3):663-76. [pmid: 12933457].
53 National Cancer Data Base (NCDB) [database online]. Chicago (IL). American College of Surgeons (ACS). 1996-1998. 1999 Mar 5. Relative survival of breast cancer patients by AJCC stage of disease at diagnosis, 1985-1990 cases [table]. [3 p]. Available: http://www.facs.org/about_college/acsdept/cancer_dept/programs/ncdb/breastcancer4.html.
54 Dewhurst CE, Mortele KJ. Magnetic resonance imaging of rectal cancer. Radiol Clin North Am. Jan. 2013;51(1):121-31. [pmid: 23182512].
55 Brice J. Experts put MRI accreditation program to the test. Diagn Imaging. Jul. 2001;23(7):44-7. 49.
56 Quality and safety: computed tomography accreditation. [internet]. Reston (VA). American College of Radiology (ACR). 2013 May 10. [2 p]. Available: http://www.acr.org/Quality-Safety/Accreditation/CT.
57 Fletcher JW, Djulbegovic B, Soares HP, et al. Recommendations on the use of 18F-FDG PET in oncology. J Nucl Med. Mar. 2008;49(3):480-508. [pmid: 18287273].
58 Rosen EL, Eubank WB, Mankoff DA. FDG PET, PET/CT, and breast cancer imaging. Radiographics. Oct. Suppl 1. 2007;27:S215-29. [pmid: 18180228].
59 Bergmann H, Dobrozemsky G, Minear G, et al. An inter-laboratory comparison study of image quality of PET scanners using the NEMA NU 2-2001 procedure for assessment of image quality. Phys Med Biol. May. 21. 2005;50(10):2193-207. [pmid: 15876661].
60 McDonough MD, DePeri ER, Mincey BA. The role of positron emission tomographic imaging in breast cancer. Curr Oncol Rep. Jan. 2004;6(1):62-8. [pmid: 14664763].
61 Avril N, Schelling M, Dose J, et al. Utility of PET in breast cancer. Clin Positron Imaging. Oct. 1999;2(5):261-71. [pmid: 14516650].
62 Yutani K, Tatsumi M, Uehara T, et al. Effect of patients' being prone during FDG PET for the diagnosis of breast cancer. AJR Am J Roentgenol. Nov. 1999;173(5):1337-9. [pmid: 10541114].
63 Katanick SL. Fundamentals of ICANL accreditation. J Nucl Med Technol. Mar. 2005;33(1):19-23. [pmid: 15731016].
64 Dewhurst C, Rosen MP, Blake MA, et al. ACR appropriateness criteria pretreatment staging of colorectal cancer. J Am Coll Radiol. Nov. 2012;9(11):775-81. [pmid: 23122343].
65 Blake MA, McDermott S, Rosen MP, et al. ACR Appropriateness Criteria suspected liver metastases. [online publication]. Reston (VA). American College of Radiology (ACR). 2011. 9 p.
66 Chalmers I, Adams M, Dickersin K, et al. A cohort study of summary reports of controlled trials. JAMA. Mar. 9. 1990;263(10):1401-5. [pmid: 2304219].
67 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. Mar. 1987;8(2):198-203. [pmid: 3818406].
68 Dundar Y, Dodd S, Williamson P, et al. Case study of the comparison of data from conference abstracts and full-text articles in health technology assessment of rapidly evolving technologies: does it make a difference?. Int J Technol Assess Health Care. Jul. 2006;22(3):288-94. [pmid: 16984055].
69 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. Mar. 1992;3(3):187-91. [pmid: 1586615].
70 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. Cochrane Library [Cochrane methodology review]. Oxford. Update Software. 2001;(2). 2001 Apr 23. [35 p]. Available: http://www.cochrane.org/index.htm.
71 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. Jul. 1993;40(7):632-4. [pmid: 8403137].
72 Marx WF, Cloft HJ, Do HM, et al. The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. Jun-Jul. 1999;20(6):1173-7. [pmid: 10445467].
73 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
74 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
75 Li FY, Lai MD. Colorectal cancer, one entity or three?. J Zhejiang Univ Sci B. Mar. 2009;10(3):219-29. [pmid: 19283877].
76 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(1):25. [pmid: 14606960].
77 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sep. 15. 1999;282(11):1061-6. [pmid: 10493205].
78 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
79 Treadwell JR, Tregear SJ, Reston JT, et al. A system for rating the stability and strength of medical evidence. BMC Med Res Methodol. 2006;6:52. Also available: http://www.biomedcentral.com/1471-2288/6/52. [pmid: 17052350].
80 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the risk of bias of individual studies in systematic reviews of health care interventions. Agency for Healthcare Research and Quality methods guide for Comparative Effectiveness Reviews [AHRQ Publication No. 12-EGC047-EF]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Mar. 2012:33. Also available: http://www.effectivehealthcare.ahrq.gov.
81 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
82 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
83 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Epub 2011 Apr 3. [pmid: 21463926].
84 Gall TM, Markar SR, Jackson D, et al. Mini-probe ultrasonography for the staging of colon cancer. A systematic review and meta-analysis. Colorectal Dis. 2013. Oct. 5. [pmid: 24119196].
85 Puli SR, Reddy JB, Bechtold ML, et al. Accuracy of endoscopic ultrasound to diagnose nodal invasion by rectal cancers: a meta-analysis and systematic review. Ann Surg Oncol. May. 2009;16(5):1255-65. [pmid: 19219506].
86 Al-Sukhni E, Milot L, Fruitman M, et al. Diagnostic accuracy of MRI for assessment of T category, lymph node metastases, and circumferential resection margin involvement in patients with rectal cancer: a systematic review and meta-analysis. Ann Surg Oncol. Jul. 2012;19(7):2212-23. [pmid: 22271205].
87 Lu YY, Chen JH, Ding HJ, et al. A systematic review and meta-analysis of pretherapeutic lymph node staging of colorectal cancer by 18F-FDG PET or PET/CT. Nucl Med Commun. Nov. 2012;33(11):1127-33. [pmid: 23000829].
88 Kim DJ, Kim JH, Ryu YH, et al. Nodal staging of rectal cancer: high-resolution pelvic MRI versus 18F-FDGPET/CT. J Comput Assist Tomogr. Sep-Oct. 2011;35(5):531-4. [pmid: 21926843].
89 Uchiyama S, Haruyama Y, Asada T, et al. Role of the standardized uptake value of 18-Fluorodeoxyglucose positron emission tomography-computed tomography in detecting the primary tumor and lymph node metastasis in colorectal cancers. Surg Today. Oct. 2012;42(10):956-61. [pmid: 22711186].
90 Orlacchio A, Schillaci O, Fusco N, et al. Role of PET/CT in the detection of liver metastases from colorectal cancer. Radiol Med. Jun. 2009;114(4):571-85. [pmid: 19444590].
91 Lubezky N, Metser U, Geva R, et al. The role and limitations of 18-fluro-2deoxy-d-glucose positron emission tomography (FDG-PET) scan and computerized tomography (CT) in restaging patients with hepatic colorectal [TRUNC]. J Gastrointest Surg. Apr. 2007;11(4):472-8. [pmid: 17436132].
92 Barbaro B, Savastano M, Sallustio G. Combined modality staging of low risk rectal cancer. Rays. Apr-Jun. 1995;20(2):145-55. [pmid: 7480863].
93 Yimei J, Ren Z, Lu X, et al. A comparison between the reference values of MRI and EUS and their usefulness to surgeons in rectal cancer. Eur Rev Med Pharmacol Sci. Dec. 2012;16(15):2069-77. [pmid: 23280021].
94 Halefoglu AM, Yildirim S, Avlanmis O, et al. Endorectal ultrasonography versus phased-array magnetic resonance imaging for preoperative staging of rectal cancer. World J Gastroenterol. Jun. 14. 2008;14(22):3504-10. [pmid: 18567078].
95 Bianchi PP, Ceriani C, Rottoli M, et al. Endoscopic ultrasonography and magnetic resonance in preoperative staging of rectal cancer: comparison with histologic findings. J Gastrointest Surg. Dec. 2005;9(9):1222-7. discussion 1227-8. [pmid: 16332477].
96 Starck M, Bohe M, Fork FT, et al. Endoluminal ultrasound and low-field magnetic resonance imaging are superior to clinical examination in the preoperative staging of rectal cancer. Eur J Surg. Nov. 1995;161(11):841-5. [pmid: 8749217].
97 Thaler W, Watzka S, Martin F, et al. Preoperative staging of rectal cancer by endoluminal ultrasound vs. magnetic resonance imaging. Preliminary results of a prospective, comparative study. Dis Colon Rectum. Dec. 1994;37(12):1189-93. [pmid: 7995142].
98 Waizer A, Powsner E, Russo I, et al. Prospective comparative study of magnetic resonance imaging versus transrectal ultrasound for preoperative staging and follow-up of rectal cancer. Preliminary report. Dis Colon Rectum. Dec. 1991;34(12):1068-72. [pmid: 1959456].
99 Ju H, Xu D, Li D, et al. Comparison between endoluminal ultrasonography and spiral computerized tomography for the preoperative local staging of rectal carcinoma. Biosci Trends. Apr. 2009;3(2):73-6. [pmid: 20103950].
100 Kim NK, Kim MJ, Yun SH, et al. Comparative study of transrectal ultrasonography, pelvic computerized tomography, and magnetic resonance imaging in preoperative staging of rectal cancer. Dis Colon Rectum. Jun. 1999;42(6):770-5. [pmid: 10378601].
101 Osti MF, Padovan FS, Pirolli C, et al. Comparison between transrectal ultrasonography and computed tomography with rectal inflation of gas in preoperative staging of lower rectal cancer. Eur Radiol. 1997;7(1):26-30. [pmid: 9000390].
102 Ramana KN, Murthy PV, Rao KP, et al. Transrectal ultrasonography versus computed tomography in staging rectal carcinoma. Indian J Gastroenterol. Oct. 1997;16(4):142-3. [pmid: 9357186].
103 Goldman S, Arvidsson H, Norming U, et al. Transrectal ultrasound and computed tomography in preoperative staging of lower rectal adenocarcinoma. Gastrointest Radiol. 1991;16(3):259-63. [pmid: 1879647].
104 Pappalardo G, Reggio D, Frattaroli FM, et al. The value of endoluminal ultrasonography and computed tomography in the staging of rectal cancer: a preliminary study. J Surg Oncol. Apr. 1990;43(4):219-22. [pmid: 2182943].
105 Rotte KH, Kluhs L, Kleinau H, et al. Computed tomography and endosonography in the preoperative staging of rectal carcinoma. Eur J Radiol. Aug. 1989;9(3):187-90. [pmid: 2680490].
106 Waizer A, Zitron S, Ben-Baruch D, et al. Comparative study for preoperative staging of rectal cancer. Dis Colon Rectum. Jan. 1989;32(1):53-6. [pmid: 2642791].
107 Beynon J, Mortensen NJ, Foy DM, et al. Pre-operative assessment of local invasion in rectal cancer: digital examination, endoluminal sonography or computed tomography?. Br J Surg. Dec. 1986;73(12):1015-7. [pmid: 3539255].
108 Kramann B, Hildebrandt U. Computed tomography versus endosonography in the staging of rectal carcinoma: a comparative study. Int J Colorectal Dis. Oct. 1986;1(4):216-8. [pmid: 3298492].
109 Rifkin MD, Wechsler RJ. A comparison of computed tomography and endorectal ultrasound in staging rectal cancer. Int J Colorectal Dis. Oct. 1986;1(4):219-23. [pmid: 3298493].
110 Rifkin MD, McGlynn ET, Marks G. Endorectal sonographic prospective staging of rectal cancer. Scand J Gastroenterol Suppl. 1986;123:99-103. [pmid: 3535046].
111 Romano G, de Rosa P, Vallone G, et al. Intrarectal ultrasound and computed tomography in the pre- and postoperative assessment of patients with rectal cancer. Br J Surg. Sep. Suppl. 1985;72:S117-9. [pmid: 3899251].
112 Matsuoka H, Nakamura A, Masaki T, et al. A prospective comparison between multidetector-row computed tomography and magnetic resonance imaging in the preoperative evaluation of rectal carcinoma. Am J Surg. Jun. 2003;185(6):556-9. [pmid: 12781885].
113 Guinet C, Buy JN, Ghossain MA, et al. Comparison of magnetic resonance imaging and computed tomography in the preoperative staging of rectal cancer. Arch Surg. Mar. 1990;125(3):385-8. [pmid: 2306185].
114 Hodgman CG, MacCarty RL, Wolff BG, et al. Preoperative staging of rectal carcinoma by computed tomography and 0.15T magnetic resonance imaging. Preliminary report. Dis Colon Rectum. Jul. 1986;29(7):446-50. [pmid: 3720456].
115 Blomqvist L, Holm T, Nyren S, et al. MR imaging and computed tomography in patients with rectal tumours clinically judged as locally advanced. Clin Radiol. Mar. 2002;57(3):211-8. [pmid: 11952317].
116 Fleshman JW, Myerson RJ, Fry RD, et al. Accuracy of transrectal ultrasound in predicting pathologic stage of rectal cancer before and after preoperative radiation therapy. Dis Colon Rectum. Sep. 1992;35(9):823-9. [pmid: 1511639].
117 Arii K, Takifuji K, Yokoyama S, et al. Preoperative evaluation of pelvic lateral lymph node of patients with lower rectal cancer: comparison study of MR imaging and CT in 53 patients. Langenbecks Arch Surg. Sep. 2006;391(5):449-54. [pmid: 16847648].
118 Milsom JW, Lavery IC, Stolfi VM, et al. The expanding utility of endoluminal ultrasonography in the management of rectal cancer. Surgery. Oct. 1992;112(4):832-40. discussion 840-1. [pmid: 1411958].
119 Taylor A, Slater A, Mapstone N, et al. Staging rectal cancer: MRI compared to MDCT. Abdom Imaging. May-Jun. 2007;32(3):323-7. [pmid: 16967240].
120 Bartolozzi C, Donati F, Cioni D, et al. Detection of colorectal liver metastases: a prospective multicenter trial comparing unenhanced MRI, MnDPDP-enhanced MRI, and spiral CT. Eur Radiol. Jan. 2004;14(1):14-20. [pmid: 14730384].
121 Bhattacharjya S, Bhattacharjya T, Baber S, et al. Prospective study of contrast-enhanced computed tomography, computed tomography during arterioportography, and magnetic resonance imaging for staging colorectal liver metastases for liver resection. Br J Surg. Oct. 2004;91(10):1361-9. [pmid: 15376205].
122 Bohm B, Voth M, Geoghegan J, et al. Impact of positron emission tomography on strategy in liver resection for primary and secondary liver tumors. J Cancer Res Clin Oncol. May. 2004;130(5):266-72. [pmid: 14767761].
123 Lencioni R, Donati F, Cioni D, et al. Detection of colorectal liver metastases: prospective comparison of unenhanced and Ferumoxides-enhanced magnetic resonance imaging at 1.5 T, dual-phase spiral CT, and spiral CT during arterial portography. Magn Reson Mater Phys Biol Med. Dec. 1998;7(2):76-87.
124 Strotzer M, Gmeinwieser J, Schmidt J, et al. Diagnosis of liver metastases from colorectal adenocarcinoma. Comparison of spiral-CTAP combined with intravenous contrast-enhanced spiral-CT and SPIO-enhanced MR combined with plain MR imaging. Acta Radiol. Nov. 1997;38(6):986-92. [pmid: 9394654].
125 Brown G, Davies S, Williams GT, et al. Effectiveness of preoperative staging in rectal cancer: digital rectal examination, endoluminal ultrasound or magnetic resonance imaging?. Br J Cancer. Jul. 5. 2004;91(1):23-9. [pmid: 15188013].
126 Wickramasinghe DP, Samarasekera DN. A comparison of endoanal ultrasound and computed tomography in staging rectal cancer and in clinical decision making - a preliminary study. Ceylon Med J. Mar. 2012;57(1):33-5. [pmid: 22453708].
127 Harewood GC, Wiersema MJ, Nelson H, et al. A prospective, blinded assessment of the impact of preoperative staging on the management of rectal cancer. Gastroenterology. Jul. 2002;123(1):24-32. [pmid: 12105829].
128 Engledow AH, Skipworth JR, Pakzad F, et al. The role of 18FDG PET/CT in the management of colorectal liver metastases. HPB. Jan. 2012;14(1):20-5. [pmid: 22151447].
129 Eglinton T, Luck A, Bartholomeusz D, et al. Positron-emission tomography/computed tomography (PET/CT) in the initial staging of primary rectal cancer. Colorectal Dis. Jul. 2010;12(7):667-73. [pmid: 19486092].
130 Kim SH, Jo EJ, Kim MY, et al. Clinical value of radiocontrast media skin tests as a prescreening and diagnostic tool in hypersensitivity reaction. Ann Allergy Asthma Immunol. Apr. 2013;110(4):258-62. [pmid: 23535089].
131 Kobayashi D, Takahashi O, Ueda T, et al. Risk factors for adverse reactions from contrast agents for computed tomograph. BMC Med Inform Decis Mak. 2013;13:18. [pmid: 23363607].
132 Davenport MS, Wang CL, Bashir MR, et al. Rate of contrast material extravasations and allergic-like reactions: effect of extrinsic warming of low-osmolality iodinated CT contrast material to 37 degrees. Radiology. Feb. 2012;262(2):475-84. [pmid: 22106356].
133 Kingston RJ, Young N, Sindhusake DP, et al. Study of patients with intravenous contrast extravasation on CT studies, with radiology staff and ward staff cannulation. J Med Imaging Radiat Oncol. Apr. 2012;56(2):163-7. [pmid: 22498188].
134 Mitchell AM, Jones AE, Tumlin JA, et al. Prospective study of the incidence of contrast-induced nephropathy among patients evaluated for pulmonary embolism by contrast-enhanced computed tomograph. Acad Emerg Med. Jun. 2012;19(6):618-25. [pmid: 22687176].
135 Vogl TJ, Wessling J, Buerke B. An observational study to evaluate the efficiency and safety of Ioversol pre-filled syringes compared with Ioversol bottles in contrast-enhanced examination. Acta Radiol. Oct. 1. 2012;53(8):914-20. [pmid: 22983259].
136 Cadwallader RA, Walsh SR, Burrows B, et al. Prospective audit of cross-sectional imaging and radiation exposure in general surgical patients. Ann R Coll Surg Engl. Jan. 2011;93(1):6-8. [pmid: 20955661].
137 Hatakeyama S, Abe A, Suzuki T, et al. Clearance and safety of the radiocontrast medium Iopamidol in peritoneal dialysis patients. Int J Nephrol. 2011;2011:657051. [pmid: 22028966].
138 Loh S, Bagheri S, Katzberg RW, et al. Delayed adverse reaction to contrast-enhanced CT: a prospective single-center study comparison to control group without enhancement. Radiology. Jun. 2010;255(3):764-71. [pmid: 20406882].
139 Ozbulbul NI, Yurdakul M, Tola M. Comparison of a low-osmolar contrast medium, Iopamidol, and an iso-osmolar contrast medium, Iodixanol, in MDCT coronary angiography. Coron Artery Dis. Nov. 2010;21(7):414-9. [pmid: 20671550].
140 Shah-Patel LR, Piraner M, Silberzweig JE. Adverse events in a freestanding radiology office. J Am Coll Radiol. Apr. 2009;6(4):263-7. [pmid: 19327659].
141 Shie RF, Pan KT, Chu SY, et al. Immediate adverse drug reactions in computed tomography with slow injection rate: comparing Iothalamate Meglumine with Iopromide. Chin J Radiol. Dec. 2008;33(4):233-8.
142 Weisbord SD, Mor MK, Resnick AL, et al. Prevention, incidence, and outcomes of contrast-induced acute kidney injury. Arch Intern Med. Jun. 23. 2008;168(12):1325-32. [pmid: 18574090].
143 Yang SC, Liu SH, Chang KM. Lothalamate Meglumine induced transient tachycardia during intravenous bolus injection for CT and parameters related to its discomfort. Chin J Radiol. Sep. 2008;33(3):131-6.
144 Jung KE, Chung J, Park BC, et al. A clinical study of cutaneous adverse reactions to nonionic contrast media in Korea. Ann Dermatol. Feb. 2012;24(1):22-5. [pmid: 22363151].
145 Cote GA, Hovis RM, Ansstas MA, et al. Incidence of sedation-related complications with Propofol use during advanced endoscopic procedures. Clin Gastroenterol Hepatol. Feb. 2010;8(2):137-42. [pmid: 19607937].
146 Kalaitzakis E, Varytimiadis K, Meenan J. Predicting what can go wrong at endoscopic ultrasound: a large series experience. Frontline Gastroenterol. Apr. 2011;2(2):110-6.
147 Niv Y, Gershtansky Y, Kenett RS, et al. Complications in Endoscopic Retrograde Cholangiopancreatography (ERCP) and Endoscopic Ultrasound (EUS): analysis of 7-year physician-reported adverse events. Drug Healthc Patient Saf. 2011;3:21-5. [pmid: 21753900].
148 Schilling D, Rosenbaum A, Schweizer S, et al. Sedation with Propofol for interventional endoscopy by trained nurses in high-risk octogenarians: a prospective, randomized, controlled study. Endoscopy. Apr. 2009;41(4):295-8. [pmid: 19340730].
149 Fatima H, DeWitt J, LeBlanc J, et al. Nurse-administered Propofol sedation for upper endoscopic ultrasonography. Am J Gastroenterol. Jul. 2008;103(7):1649-56. [pmid: 18557709].
150 Semelka RC, Hernandes Mde A, Stallings CG, et al. Objective evaluation of acute adverse events and image quality of Gadolinium-based contrast agents (Gadobutrol and Gadobenate Dimeglumine) by blinded evaluation. Pilot study. Magn Reson Imaging. Jan. 2013;31(1):96-101. [pmid: 22898688].
151 Albiin N, Kartalis N, Bergquist A, et al. Manganese Chloride Tetrahydrate (CMC-001) enhanced liver MRI: evaluation of efficacy and safety in healthy volunteer. MAGMA. Oct. 2012;25(5):361-8. [pmid: 22399275].
152 Bredart A, Kop JL, Fall M, et al. Perception of care and experience of examination in women at risk of breast cancer undergoing intensive surveillance by standard imaging with or without MR. Patient Educ Couns. Mar. 2012;86(3):405-13. [pmid: 21795009].
153 Maurer M, Heine O, Wolf M, et al. Tolerability and diagnostic value of Gadoteric Acid in the general population and in patients with risk factors: results in more than 84,000 patient. Eur J Radiol. May. 2012;81(5):885-90. [pmid: 21555197].
154 Voth M, Rosenberg M, Breuer J. Safety of Gadobutrol, a new generation of contrast agents: experience from clinical trials and postmarketing surveillance. Invest Radiol. Nov. 2011;46(11):663-71. [pmid: 21623211].
155 Forsting M, Palkowitsch P. Prevalence of acute adverse reactions to Gadobutrol--a highly concentrated macrocyclic gadolinium chelate: review of 14,299 patients from observational trials. Eur J Radiol. Jun. 2010;74(3):e186-92. [pmid: 19574008].
156 Ichikawa T, Saito K, Yoshioka N, et al. Detection and characterization of focal liver lesions: a Japanese phase III, multicenter comparison between Gadoxetic Acid Disodium-enhanced magnetic resonance imaging and contrast-enhanced computed tomography predominantly in patients with hepatocellular carcinoma and chronic liver disease. Invest Radiol. Mar. 2010;45(3):133-41. [pmid: 20098330].
157 Ishiguchi T, Takahashi S. Safety of Gadoterate Meglumine (Gd-DOTA) as a contrast agent for magnetic resonance imaging: results of a post-marketing surveillance study in Japan. Drugs R D. 2010;10(3):133-45. [pmid: 20945944].
158 Leander P, Golman K, Mansson S, et al. Orally administered Manganese with and without Ascorbic Acid as a liver-specific contrast agent and bowel marker for magnetic resonance imaging: phase I clinical trial assessing efficacy and safety. Invest Radiol. Sep. 2010;45(9):559-64. [pmid: 20644487].
159 Hammersting R, Adam G, Ayuso J-RA, et al. Comparison of 1.0 M Gadobutrol and 0.5 m Gadopentetate Dimeglumine-enhanced magnetic resonance imaging in five hundred seventy-two patients with known or suspected liver lesions. Invest Radiol. Mar. 2009;44(3):168-76. [pmid: 19169143].
160 Schieren G, Tokmak F, Lefringhausen L, et al. C-reactive protein levels and clinical symptoms following Gadolinium administration in hemodialysis patients. Am J Kidney Dis. Jun. 2008;51(6):976-86. [pmid: 18501785].
161 Codreanu I, Dasanu CA, Weinstein GS, et al. Fluorodeoxyglucose-induced allergic reaction: a case report. J Oncol Pharm Pract. Mar. 2013;19(1):86-8. [pmid: 22267446].
162 Wink MH, Wijkstra H, De La Rosette JJ, et al. Ultrasound imaging and contrast agents: a safe alternative to MRI?. Minim Invasive Ther Allied Technol. Apr. 2006;15(2):93-100. [pmid: 16754192].
163 Pomerri F, Pucciarelli S, Maretto I, et al. Prospective assessment of imaging after preoperative chemoradiotherapy for rectal cancer. Surgery. Jan. 2011;149(1):56-64. [pmid: 20452636].
164 Huh JW, Park YA, Jung EJ, et al. Accuracy of endorectal ultrasonography and computed tomography for restaging rectal cancer after preoperative chemoradiation. J Am Coll Surg. Jul. 2008;207(1):7-12. [pmid: 18589355].
165 Mo LR, Tseng LJ, Jao YT, et al. Balloon sheath miniprobe compared to conventional EUS in the staging of colorectal cancer. Hepatogastroenterology. Jul-Aug. 2002;49(46):980-3. [pmid: 12143258].
166 Brenner DJ, Hall EJ. Computed tomography--an increasing source of radiation exposure. N Engl J Med. Nov. 29. 2007;357(22):2277-84. [pmid: 18046031].
167 Fact sheet: computed tomography (CT) scans and cancer. [internet]. Bethesda (MD). National Cancer Institute (NCI). 2013. Jul. 16. 2013 Jul 30. [9 p]. Available: http://www.cancer.gov/cancertopics/factsheet/detection/CT.
168 Medical magnetic resonance (MR) procedures: protection of patients. Health Phys. Aug. 2004;87(2):197-216. [pmid: 15257220].
169 Shellock FG. Radiofrequency energy-induced heating during MR procedures: a review. J Magn Reson Imaging. Jul. 2000;12(1):30-6. [pmid: 10931562].
170 Fiek M, Remp T, Reithmann C, et al. Complete loss of ICD programmability after magnetic resonance imaging. Pacing Clin Electrophysiol. Jul. 2004;27(7):1002-4. [pmid: 15271024].
171 Shellock FG. Magnetic resonance safety update 2002: implants and devices. J Magn Reson Imaging. Nov. 2002;16(5):485-96. [pmid: 12412025].
172 Foster JR, Hall DA, Summerfield AQ, et al. Sound-level measurements and calculations of safe noise dosage during EPI at 3 T. J Magn Reson Imaging. Jul. 2000;12(1):157-63. [pmid: 10931575].
173 Dempsey MF, Condon B, Hadley DM. Investigation of the factors responsible for burns during MRI. J Magn Reson Imaging. Apr. 2001;13(4):627-31. [pmid: 11276109].
174 Feychting M. Health effects of static magnetic fields--a review of the epidemiological evidence. Prog Biophys Mol Biol. Feb-Apr. 2005;87(2-3):241-6. [pmid: 15556662].
175 Hong CZ, Shellock FG. Short-term exposure to a 1.5 tesla static magnetic field does not affect somato-sensory-evoked potentials in man. Magn Reson Imaging. 1990;8(1):65-9. [pmid: 2325519].
176 Shellock FG, Schaefer DJ, Gordon CJ. Effect of a 1.5 T static magnetic field on body temperature of man. Magn Reson Med. Aug. 1986;3(4):644-7. [pmid: 3747826].
177 Budinger TF. Nuclear magnetic resonance (NMR) in vivo studies: known thresholds for health effects. J Comput Assist Tomogr. Dec. 1981;5(6):800-11. [pmid: 7033311].
178 Chang Y, Lee GH, Kim TJ, et al. Toxicity of magnetic resonance imaging agents: small molecule and nanoparticle. Curr Top Med Chem. 2013;13(4):434-45. [pmid: 23432006].
179 American College of Radiology. ACR manual on contrast media [version 9]. Reston (VA). American College of Radiology. 2013. 128 p.
180 Thomsen HS. Nephrogenic systemic fibrosis. Imaging Decis. Mar. 21. 2008;11(4):13-8.
181 Grobner T. Gadolinium--a specific trigger for the development of nephrogenic fibrosing dermopathy and nephrogenic systemic fibrosis. Nephrol Dial Transplant. Apr. 2006;21(4):1104-8. [pmid: 16431890].
182 FDA drug safety communication: new warnings for using Gadolinium-based contrast agents in patients with kidney dysfunction. [internet]. Silver Spring (MD). U.S. Food and Drug Administration (FDA). 2010. Dec. 23. 2013 Jul 29. [3 p]. Available: http://www.fda.gov/Drugs/DrugSafety/ucm223966.htm.
183 Public health advisory - Gadolinium-containing contrast agents for magnetic resonance imaging (MRI). [internet]. Silver Spring (MD). U.S. Food and Drug Administration (FDA). 2006. Jun. 8. [updated 2010 Jun 22]. 2013 Jul 29. [2 p]. Available: http://www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/DrugSafetyInformationforHeathcareProfessionals/PublicHealthAdvisories/ucm053112.htm.
184 FDA requests boxed warning for contrast agents used to improve MRI images. [internet]. Silver Spring (MD). U.S. Food and Drug Administration (FDA). 2007. May. 23. [updated 2013 Apr 10]. 2013 Jul 29. [2 p]. Available: http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/2007/ucm108919.htm.
185 Cronin B, Marsden PK, O'Doherty MJ. Are restrictions to behaviour of patients required following Fluorine-18 Fluorodeoxyglucose positron emission tomographic studies?. Eur J Nucl Med. Feb. 1999;26(2):121-8. [pmid: 9933345].
186 Kim S, Lim HK, Lee SJ, et al. Depiction and local staging of rectal tumors: comparison of transrectal US before and after water instillation. Radiology. Apr. 2004;231(1):117-22. [pmid: 15068943].
187 Hunerbein M, Pegios W, Rau B, et al. Prospective comparison of endorectal ultrasound, three-dimensional endorectal ultrasound, and endorectal MRI in the preoperative evaluation of rectal tumors. Preliminary results. Surg Endosc. Nov. 2000;14(11):1005-9. [pmid: 11116406].
188 Rafaelsen SR, Sorensen T, Jakobsen A, et al. Transrectal ultrasonography and magnetic resonance imaging in the staging of rectal cancer. Effect of experience. Scand J Gastroenterol. 2008;43(4):440-6. [pmid: 18365909].
189 Skriver EB, Nielsen MB, Qvitzau S, et al. Comparison of precontrast, postcontrast, and delayed CT scanning for the staging of rectal carcinoma. Gastrointest Radiol. 1992;17(3):267-70. [pmid: 1612314].
190 Lupo L, Angelelli G, Pannarale O, et al. Improved accuracy of computed tomography in local staging of rectal cancer using water enema. Int J Colorectal Dis. 1996;11(2):60-4. [pmid: 8739828].
191 Wicherts DA, de Haas RJ, van Kessel CS, et al. Incremental value of arterial and equilibrium phase compared to hepatic venous phase CT in the preoperative staging of colorectal liver metastases: an evaluation with different reference standards. Eur J Radiol. Feb. 2011;77(2):305-11. [pmid: 19695807].
192 Koh DM, Collins DJ, Wallace T, et al. Combining diffusion-weighted MRI with Gd-EOB-DTPA-enhanced MRI improves the detection of colorectal liver metastases. Br J Radiol. Jul. 2012;85(1015):980-9. [pmid: 22167501].
193 Jao SY, Yang BY, Weng HH, et al. Evaluation of Gadolinium-enhanced T1-weighted magnetic resonance imaging in the preoperative assessment of local staging in rectal cancer. Colorectal Dis. Nov. 2010;12(11):1139-48. [pmid: 19548900].
194 Vliegen RF, Beets GL, von Meyenfeldt MF, et al. Rectal cancer: MR imaging in local staging--is Gadolinium-based contrast material helpful?. Radiology. Jan. 2005;234(1):179-88. [pmid: 15550372].
195 Okizuka H, Sugimura K, Yoshizako T, et al. Rectal carcinoma: prospective comparison of conventional and gadopentetate dimeglumine enhanced fat-suppressed MR imaging. J Magn Reson Imaging. May-Jun. 1996;6(3):465-71. [pmid: 8724412].
196 Kim MJ, Lim JS, Oh YT, et al. Preoperative MRI of rectal cancer with and without rectal water filling: an intraindividual comparison. AJR Am J Roentgenol. Jun. 2004;182(6):1469-76. [pmid: 15149992].
197 Futterer JJ, Yakar D, Strijk SP, et al. Preoperative 3T MR imaging of rectal cancer: local staging accuracy using a two-dimensional and three-dimensional T2-weighted turbo spin echo sequence. Eur J Radiol. Jan. 2008;65(1):66-71. [pmid: 18164156].
198 van Kessel CS, Buckens CF, van den Bosch MA, et al. Preoperative imaging of colorectal liver metastases after neoadjuvant chemotherapy: a meta-analysis. Ann Surg Oncol. Sep. 2012;19(9):2805-13. [pmid: 22396005].
199 Martellucci J, Scheiterle M, Lorenzi B, et al. Accuracy of transrectal ultrasound after preoperative radiochemotherapy compared to computed tomography and magnetic resonance in locally advanced rectal cancer. Int J Colorectal Dis. Jul. 2012;27(7):967-73. [pmid: 22297865].
200 Berger-Kulemann V, Schima W, Baroud S, et al. Gadoxetic acid-enhanced 3.0 T MR imaging versus multidetector-row CT in the detection of colorectal metastases in fatty liver using intraoperative ultrasound and histopathology as a standard of reference. Eur J Surg Oncol. Aug. 2012;38(8):670-6. [pmid: 22652037].
201 Kulemann V, Schima W, Tamandl D, et al. Preoperative detection of colorectal liver metastases in fatty liver: MDCT or MRI?. Eur J Radiol. Aug. 2011;79(2):e1-6. [pmid: 20392584].
202 van Kessel CS, van Leeuwen MS, van den Bosch MA, et al. Accuracy of multislice liver CT and MRI for preoperative assessment of colorectal liver metastases after neoadjuvant chemotherapy. Dig Surg. 2011;28(1):36-43. [pmid: 21293130].
203 Lambregts DM, Maas M, Riedl RG, et al. Value of ADC measurements for nodal staging after chemoradiation in locally advanced rectal cancer-a per lesion validation study. Eur Radiol. Feb. 2011;21(2):265-73. [pmid: 20730540].
204 Macera A, Lario C, Petracchini M, et al. Staging of colorectal liver metastases after preoperative chemotherapy. Diffusion-weighted imaging in combination with Gd-EOB-DTPA MRI sequences increases sensitivity and diagnostic accuracy. Eur Radiol. Mar. 2013;23(3):739-47. [pmid: 22976920].
205 Bipat S, Glas AS, Slors FJ, et al. Rectal cancer: local staging and assessment of lymph node involvement with endoluminal US, CT, and MR imaging--a meta-analysis. Radiology. Sep. 2004;232(3):773-83. [pmid: 15273331].
206 Lahaye MJ, Engelen SM, Nelemans PJ, et al. Imaging for predicting the risk factors--the circumferential resection margin and nodal disease--of local recurrence in rectal cancer: a meta-analysis. Semin Ultrasound CT MR. Aug. 2005;26(4):259-68. [pmid: 16152740].
207 Skandarajah AR, Tjandra JJ. Preoperative loco-regional imaging in rectal cancer. ANZ J Surg. Jun. 2006;76(6):497-504. [pmid: 16768778].
208 Kwok H, Bissett IP, Hill GL. Preoperative staging of rectal cancer. Int J Colorectal Dis. Feb. 2000;15(1):9-20. [pmid: 10766086].
209 Trikalinos TA, Hoaglin DC, Small KM, et al. Evaluating practices and developing tools for comparative effectiveness reviews of diagnostic test accuracy: methods for the joint meta-analysis of multiple tests (Prepared by the Tufts Evidence-based Practice Center, under Contract No. 290 2007-10055-I). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jan. 2013:49. Also available: http://www.effectivehealthcare.ahrq.gov/ehc/products/291/1380/Methods%20Report_Evaluating-Practices-Developing-Tools_Final_01-14-2013.pdf.
210 Magne N, Daisne JF, Moretti L, et al. A practice survey of the evolution of rectal cancer management: a Belgian Federal College of radiotherapy study. Bull Cancer (Paris). Jul-Aug. 2009;96(7):E45-51. [pmid: 19617178].
211 Lohsiriwat V, Lohsiriwat D, Thavichaigarn P. Current practices in rectal cancer surgery: a survey of Thai colorectal surgeons. J Med Assoc Thai. Aug. 2009;92(8):1009-15. [pmid: 19694323].
212 Augestad KM, Lindsetmo RO, Stulberg J, et al. International preoperative rectal cancer management: staging, neoadjuvant treatment, and impact of multidisciplinary teams. World J Surg. Nov. 2010;34(11):2689-700. [pmid: 20703471].
213 Melotti G, De Antoni E, Habr-Gama A, et al. Management of distal rectal cancer: results from a national survey. Updates Surg. Mar. 2013;65(1):43-52. Epub 2013 Jan 19. [pmid: 23335049].
214 Habr-Gama A, Perez RO, Sao Juliao GP, et al. Factors affecting management decisions in rectal cancer in clinical practice: results from a national survey. Tech Coloproctol. Mar. 2011;15(1):45-51. [pmid: 21057971].
215 Mroczkowski P, Hac S, Mik M, et al. Preliminary results of the first quality assurance project in rectal cancer in Poland. Pol Przegl Chir. Mar. 2011;83(3):144-9. [pmid: 22166316].
216 Ooi K, Frizelle F, Ong E, et al. Current practice in preoperative therapy and surgical management of locally advanced rectal cancer: a bi-national survey. Colorectal Dis. Jul. 2012;14(7):814-20. [pmid: 21899709].
217 O'Grady MA, Slater E, Sigurdson ER, et al. Assessing compliance with national comprehensive cancer network guidelines for elderly patients with stage III colon cancer: the Fox Chase Cancer Center Partners' initiative. Clin Colorectal Cancer. Jun. 2011;10(2):113-6. [pmid: 21859563].
218 Cunningham R, Sarfati D, Hill S, et al. Colon cancer management in New Zealand: 1996-2003. N Z Med J. May. 8. 2009;122(1294):51-60. [pmid: 19465947].
219 Levine RA, Chawla B, Bergeron S, et al. Multidisciplinary management of colorectal cancer enhances access to multimodal therapy and compliance with National Comprehensive Cancer Network (NCCN) guidelines. Int J Colorectal Dis. Nov. 2012;27(11):1531-8. [pmid: 22645076].
220 McConnell YJ, Inglis K, Porter GA. Timely access and quality of care in colorectal cancer: are they related?. Int J Qual Health Care. Jun. 2010;22(3):219-28. [pmid: 20207714].
221 van der Geest LG, Krijnen P, Wouters MW, et al. Improved guideline compliance after a 3-year audit of multidisciplinary colorectal cancer care in the western part of the Netherlands. J Surg Oncol. Jul. 1. 2012;106(1):1-9. [pmid: 22234959].
222 van Steenbergen LN, Lemmens VE, Straathof JW, et al. Improvable quality of diagnostic assessment of colorectal cancer in southern Netherlands. Eur J Gastroenterol Hepatol. May. 2009;21(5):570-5. [pmid: 19190499].
223 Bipat S, Niekel MC, Comans EF, et al. Imaging modalities for the staging of patients with colorectal cancer. Neth J Med. Jan. 2012;70(1):26-34. [pmid: 22271811].
224 Heriot AG, Grundy A, Kumar D. Preoperative staging of rectal carcinoma. Br J Surg. Jan. 1999;86(1):17-28. [pmid: 10027354].
225 Hartman RI, Chang CY, Wo JY, et al. Optimizing adjuvant treatment decisions for stage T2 rectal cancer based on mesorectal node size. A decision analysis. Acad Radiol. Jan. 2013;20(1):79-89. [pmid: 22947271].
226 Lejeune C, Bismuth MJ, Conroy T, et al. Use of a decision analysis model to assess the cost-effectiveness of 18F-FDG PET in the management of metachronous liver metastases of colorectal cancer. J Nucl Med. Dec. 2005;46(12):2020-8. [pmid: 16330566].
227 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jun. 2011:79. (Methods future research needs report; no. 2). Also available: http://www.effectivehealthcare.ahrq.gov/ehc/products/201/735/FRN2_Frameworks_20110726.pdf.
228 Paul MA, Visser JJ, Mulder C, et al. The use of biliary CEA measurements in the diagnosis of recurrent colorectal cancer. Eur J Surg Oncol. Oct. 1997;23(5):419-23. [pmid: 9393570].
229 Kim H, Lim JS, Choi JY, et al. Rectal cancer: comparison of accuracy of local-regional staging with two- and three-dimensional preoperative 3-T MR imaging. Radiology. Feb. 2010;254(2):485-92. [pmid: 20093520].
230 Yang L, Krefting I, Gorovets A, et al. Nephrogenic systemic fibrosis and class labeling of Gadolinium-based contrast agents by the Food and Drug Administration. Radiology. Oct. 2012;265(1):248-53. Also available: http://pubs.rsna.org/doi/pdf/10.1148/radiol.12112783. [pmid: 22923714].