# Methods

This section describes how the key questions were developed, how the literature was searched, how the included articles were selected, and how the data were analyzed. These methods follow those suggested in the ARHQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm).

## Topic Refinement and Review Protocol

The topic was nominated in a public process. The Tufts Evidence-based Practice Center (EPC) recruited a panel of Key Informants (listed in the Acknowledgements section of the Front Matter) to provide input on the selection and refinement of the questions to be examined.

Upon AHRQ approval, the draft key questions were posted for public comment for four weeks on the AHRQ website. After receipt of public commentary, the SRC finalized the Key Questions and submitted them to AHRQ for approval. These Key Questions are presented in the Scope and Key Questions section of the Introduction.

Our EPC drafted a protocol and recruited a panel of content experts (the Technical Expert Panel, or TEP, listed in the Acknowledgements section of the Front Matter). Working in concert with AHRQ and the TEP, a plan for developing the evidence report was created. The protocol outlining the report's objectives, key questions, and methods was finalized and posted for public viewing. There were no deviations from the protocol during the review.

Individuals with broad expertise and perspectives were sought for the TEP. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

## Literature Search Strategy

### Search Strategy

Medical Librarians in the EPC Information Center performed literature searches following established systematic review protocols. We searched the following databases using controlled vocabulary and text words: EMBASE, MEDLINE, PubMed, and the Cochrane Library from 1980 through November 2013.

The following gray literature sources were searched using text words: ClinicalTrials.gov, Centers for Medicare & Medicaid (CMS) Medicare Coverage Database, ECRI Health Devices, Healthcare Standards, Internet, Medscape, National Guideline Clearinghouse™ (NGC), and the U.S. Food and Drug Administration (FDA).

The full search strategy is shown in Appendix A.

### Inclusion and Exclusion Criteria

As suggested in the “Methods Guide for Comparative Effectiveness Reviews,” we used inclusion criteria, listed below, in categories pertaining to publication type, study design, patient characteristics, test characteristics, and reported data.8

Publication criteria:

a. Full-length articles. The article must have been published as a full-length peer-reviewed study. Abstracts and meeting presentations were not included because they do not include sufficient details about experimental methods to permit an evaluation of study design and conduct, and they may also contain only a subset of measured outcomes.66,67 In addition, it is not uncommon for abstracts that are published as part of conference proceedings to have inconsistencies when compared with the study's final publication or to describe studies that are never published as full articles.68-72
b. Redundancy. To avoid double-counting patients, in cases in which several reports of the same or overlapping groups of patients were available, only outcome data from the report with the largest number of patients were included. We included data from smaller studies when the smaller study reported data on an outcome that was not provided by the largest report or reported longer followup data for an outcome.
c. English language. Moher et al. have demonstrated that excluding non-English-language studies from meta-analyses has little impact on the conclusions drawn.73 Juni et al. found that non-English studies were typically at higher risk of bias and that excluding them had little effect on effect-size estimates in the majority of meta-analyses they examined.74 Although we recognize that in some situations exclusion of non-English studies could lead to bias, we believe that the few instances in which this may occur do not justify the time and cost typically necessary for translation of studies.

Study design criteria:

a. Single test performance. For questions about the performance of a single imaging test against a reference standard, we used a two-stage inclusion process. To avoid duplicating work, we first included only recent (2009 or later) high-quality systematic reviews. We included older reviews and primary studies only if the evidence from recent systematic reviews was insufficient to support an estimate of test performance for a particular imaging test (in this case, only PET/CT).
b. Comparative test performance. For questions about comparative test performance, we considered for inclusion studies of any design—randomized, cross-sectional, case-control, or cohort. Both retrospective and prospective studies were considered for inclusion, but retrospective studies must have used consecutive/all enrollment or enrollment of a random sample of participants. Studies must have directly compared two (or more) tests of interest and must have verified the results with a reference standard. The same reference standard must have been used to verify both (or all) tests.
c. Stage reclassification or clinical decision impact. For questions about stage reclassification or impact on clinician decisionmaking, cross-sectional, cohort, or prospective comparative (randomized or nonrandomized) studies were considered for inclusion.
d. Clinical outcomes. For questions about the impact of testing on patient-oriented clinical outcomes, comparative studies (randomized or nonrandomized) were considered for inclusion.
e. Harms. The adverse events and harms reported by any studies that addressed any of the other questions were used to address questions about harms and adverse events. Additionally, we searched specifically for reports of harms and adverse events associated with the use of each specific imaging modality, such as radiation exposure and reactions to contrast agents. Any study design, including modeling, was acceptable for inclusion for questions about harms.

Patient criteria:

a. Type of patient. To be included, the study must have reported data obtained from groups of patients in which at least 85 percent were from one of the four patient populations of interest. These populations are: (1) patients with newly diagnosed colorectal disease undergoing primary staging, (2) patients with newly diagnosed colorectal disease undergoing interim restaging, (3) patients with newly diagnosed recurrent colorectal disease undergoing primary staging, and (4) patients with newly diagnosed recurrent colorectal disease undergoing interim restaging.
  Although we have grouped all colon and rectal cancers together as “colorectal cancer” as an inclusion criterion, colon and rectal cancer are somewhat different diseases. Although we did not require that studies report only on rectal cancer or only on colon cancer for inclusion in the report, whenever possible (as permitted by the reported data) we analyzed the data for rectal and colon cancer separately; however, the data permitted only analyzing rectal separately from colorectal. The location of the rectal tumor—low, middle, or high—may also affect staging accuracy, so we had also planned, if possible, to analyze the data by subgroups of rectal tumor location. However, the nature of the reported data did not permit these analyses. Some evidence suggests that proximal and distal colon cancers may also be distinctly different conditions,75 so we had planned to analyze data separately by proximal or distal subgroups, but none of the studies reported information separately for such subgroups.
b. Adults. Only studies of adult patients (older than 17 years of age) were considered for inclusion.

Test criteria:

a. Type of test. Only studies of the tests or comparisons of interest were considered for inclusion:
  i. Endoscopic rectal ultrasound (ERUS)
  ii. Magnetic resonance imaging (MRI)
  iii. Computed tomography (CT)
  iv. Positron emission tomography combined with computerized tomography PET/CT
b. Reference standards to assess test performance must have been one of the following:
  i. Histopathologic examination of tissue
  ii. Intraoperative findings
  iii. Clinical followup
c. Obsolete technology. In imaging technologies, there is constant innovation, research, and improvements in technology. Therefore, a need exists to identify and avoid obsolete technologies that have fallen out of routine clinical practice. Using a single cutoff date (for example, 2001) as a mechanism to eliminate obsolete technology is not thought to be appropriate. Instead, the TEP was consulted about which imaging technologies and variants of imaging technologies are now obsolete and not relevant to clinical practice. The imaging technologies that were determined to be obsolete (after discussion and consensus) for staging colorectal cancer are: transabdominal ultrasound, MRI using endorectal coils, nonmultidetector CT, CT arterial portography, CT angiography, CT colonography, and stand-alone PET. Likewise, experimental technology and prototypes were excluded on the grounds that there is currently insufficient evidence to evaluate their use; including them in this current review would serve no useful purpose. The TEP indicated that PET/MRI and PET/fused with CT colonography are considered to be experimental. MRI using ultrasmall paramagnetic iron oxide is also considered experimental.28

Data criteria:

a. The study must have reported data pertaining to one of the outcomes of interest (see the Key Questions section for a list).
b. We included data from time points and outcomes reported from groups of patients with at least 10 patients with the condition of interest who represented at least 50 percent of the patients originally enrolled in the study.

### Study Selection

We screened the literature in duplicate using the database Distiller SR (Evidence Partners Incorporated, Ottawa, Canada). Literature search results were initially screened in duplicate for relevancy, and relevant abstracts were screened against the inclusion and exclusion criteria in duplicate. Studies that appeared from the abstract to meet the inclusion criteria were retrieved and screened again in duplicate against the inclusion and exclusion criteria.

### Data Abstraction

Data were abstracted using the database Distiller SR. Data abstraction forms were constructed in Distiller, and the data were abstracted into these forms. Duplicate abstraction was used to ensure accuracy.

Abstracted elements include general study characteristics, patient characteristics, details of the imaging methodology, risk of bias items, and outcome data.

## Individual Study Quality (Risk of Bias) Evaluation

For studies of test performance, we used an internal validity rating scale for diagnostic studies to assess the risk of bias of each individual study. This instrument is based on a modification of the QUADAS instrument with reference to empirical studies of design-related bias in diagnostic test studies.76-78 Each question in the instrument addresses an aspect of study design or conduct that can help protect against bias, such as enrolling consecutive or a random sampling of patients or blinding image readers to a patient's clinical information. Each question can be answered “yes,” “no,” or “not reported,” and each is phrased such that an answer of “yes” indicates that the study reported a protection against bias on that aspect. The instrument is shown in Appendix D.

Test performance studies were rated as low, medium, or high risk of bias. The rating was defined by selecting critical questions from the rating scale that must be answered “yes.” The critical questions for these ratings for this review were selected after discussions with the TEP. For this topic, for a diagnostic study to be rated as low risk of bias, questions 1 and 3 (patient enrollment methods), question 6 (blinding of readers), and question 10 (avoided verification bias) must all be answered “yes,” and at least six of the other questions must be answered “yes.” The trial was rated at high risk of bias if all four critical questions were answered “no.” The trial was rated at moderate risk of bias if it did not meet the criteria for low or high.

For controlled studies, we used an internal validity rating scale for comparative studies to assess each study's risk of bias. ECRI Institute developed this instrument79 with reference to empirical studies of the impact of study design on bias in comparative studies and is consistent with the guidance in the “Methods Guide for Comparative Effectiveness Reviews.”80 Each question in the instrument addresses an aspect of study design or conduct that can help protect against bias, such as randomization of group assignment, or blinding outcome assessors to patient group assignment. Each question can be answered “yes,” “no,” or “not reported,” and each is phrased such that an answer of “yes” indicates that the study reported a protection against bias on that aspect. The instrument is shown in Appendix D.

Controlled studies were rated as low, medium, or high risk of bias. The rating is defined by selecting critical questions from the rating scale that must be answered “yes.” The critical questions for these ratings for this review were selected after discussions with the TEP. For this topic, for a controlled/comparative study to be rated as low risk of bias, questions 1, 2, and 4 (appropriately randomized or used methods to enhance group comparability) and questions 6 and 7 (group comparability) must all be answered “yes,” and at least 10 of the other questions must be answered “yes.” The trial was rated at high risk of bias if all five critical questions were answered “no.” The trial was rated at moderate risk of bias if it did not meet the criteria for low or high.

As the “Methods Guide for Comparative Effectiveness Reviews” suggests, the quality of systematic reviews used to address Key Questions 1a and 2a was assessed with a modified AMSTAR instrument.6 The instrument is shown in Appendix C.

Systematic reviews were rated as either high quality or not. The rating was defined by selecting critical questions from the rating scale that must be answered “yes.” The critical questions for these ratings for this review were selected after discussions with the TEP. For this topic, for a systematic review to be rated as high quality, questions 2 and 2a (search methods), 4 and 4a (study inclusion), 7, 7a, and 7b (rating of study quality and strength of evidence), 8 (methods of analysis) and 10 (conflicts of interest) all need to be answered “yes.” Only high-quality systematic reviews were included to address Key Questions 1a and 2a.

## Data Analysis and Synthesis

For questions addressing individual test performance (accuracy), we have drawn evidence from prior systematic reviews. As recommended by the “Methods Guide,” we have summarized all relevant high-quality reviews.6

For comparative questions, we synthesized the evidence from the primary studies themselves. We performed meta-analysis as appropriate and possible. Decisions about whether meta-analysis was appropriate were based on the judged clinical homogeneity of the different study populations, imaging and treatment protocols, and outcomes. . In order to avoid the possibility of outcome reporting bias, if fewer than 75% of the studies in an available evidence base could be combined in a quantitative meta-analysis (for any reason(s)), we refrained from performing a quantitative analysis. In cases in which meta-analysis was not possible (because of limitations of reported data) or was judged to be inappropriate, the data were synthesized using a descriptive approach.

For studies of clinical outcomes and analyses of accuracy, we computed effect sizes (odds ratios for paired data of error) and measures of variance using standard methods, and performed DerSimonian and Laird random-effects meta-analysis using Comprehensive Meta-Analysis (CMA) software (Biostat, Inc., Englewood, NJ). . Becasue studies did not report the correlations among tests, we assumed a correlation of 0.5, and performed sensitivity analyses using correlations of 0.1 and 0.9.

We next provide a worked example of how we calculated the accuracy data. Box 1 below shows the hypothetical results from a single study. Each patient was assigned a T stage (1, 2, 3 or 4) by both CT and ERUS, and the correct stage for each patient was determined by the reference standard. The shaded cells indicate patients who have been correctly staged.

Box 1 Sample accuracy data

CT | pT1 | pT2 | pT3 | pT4 | ERUS | pT1 | pT2 | pT3 | pT4
T1 | 0 | 0 | 0 | 0 | T1 | 7 | 2 | 0 | 0
T2 | 7 | 16 | 7 | 0 | T2 | 0 | 21 | 2 | 0
T3 | 0 | 9 | 22 | 3 | T3 | 0 | 2 | 27 | 2
T4 | 0 | 0 | 4 | 10 | T4 | 0 | 0 | 2 | 11

To calculate accuracy (actually the odds ratio of incorrectly staging), the number of correct cases are added and subtracted from the total and then divided by the total:

- Odds of incorrect stage for CT=((78−48)/78)/((78-30)/78)=0.385/0.615=0.625
- Odds of incorrect stage for ERUS=((76−66)/76)/((76−10)/76)=0.132/0.868=0.152
- Odds ratio of incorrect stageCT vs. ERUS=0.625/0.152=4.125

If the odds ratio is 1.0 or close to 1.0, there is no apparent difference between the two modalities in accuracy; for this example, if the result is greater than one, ERUS (the denominator) is more accurate.

To calculate the odds ratio of understaging, note that the cells above the shaded cells represent understaged patients, and they are the only ones treated as errors for the purpose of an understaging analysis:

- Odds of understaging by CT=((78−68)/78)/((78-10)/78)=0.128/0.872=0.147
- Odds of understaging by ERUS=((76−70)/76)/((76−6)/76)=0.079/0.921=0.086
- Odds ratio of understaging for CT vs. ERUS=0.147/0.086=1.716

To calculate odds ratio of overstaging, the calculations are similar to those understaging, above, except the only ones treated as errors are those below the shaded cells.

Because the same patients underwent both tests being compared, and studies did not report the correlations among tests, we assumed a correlation of 0.5, and performed sensitivity analyses using correlations of 0.1 and 0.9.

For studies of test performance, we meta-analyzed the data reported by the studies using a bivariate random-effects binomial regression model as described by Harbord et al.10 All such analyses were computed by the STATA 13.0 statistical software package (StataCorp. LP, College Station, TX) using the metandi command.11 In cases in which a binomial-bivariate normal regression model could not be fit due to insufficient number of studies (n<4), we meta-analyzed the diagnostic data using a random-effects model and the software package Meta-Disc (freeware developed by the Unit of Clinical Biostatistics, Ramón y Cajal Hospital, Madrid, Spain).12

Wherever possible, we have performed calculations of standard diagnostic test characteristics (sensitivity, specificity) and calculations of accuracy, under- and over-staging. If the two different approaches to analysis produced different conclusions about which test is to be preferred for that situation, the data were categorized as inconsistent/ heterogeneous.

Subgroup analysis has been used to explore possible causes of heterogeneity. Covariates include population descriptors, tumor site and type, country and setting of care, variations in imaging technology, and publication date.

## Strength of Evidence Grading

We used a formal grading system that conforms with the “Methods Guide for Comparative Effectiveness Reviews” recommendations on grading the strength of evidence.7-9

The overall strength of evidence supporting each major conclusion was graded as high, moderate, low, or insufficient. The grade was developed by considering four important domains: study limitations, consistency of findings, precision of the results, and directness of the evidence. We assessed the risk of bias of each individual study (see section “Assessing Quality of Individual Studies”) for each outcome and used the aggregate risk of bias to describe the study limitations of the entire evidence base for the comparison and outcome (generally, the median risk of bias across the evidence base—for example, if five studies are rated as low risk of bias and two are rated as moderate risk of bias, the study limitations of the entire evidence base for that outcome would be rated as low). Consistency of the evidence was assessed by considering study populations, imaging and treatment protocols, study designs and outcomes, in addition to statistical heterogeneity. We rated the consistency of conclusions supported by random effects meta-analyses with the statistic I^2^.81,82 Data sets that are found to have an I^2^ of less than 50 percent were rated as being consistent; 50 percent or greater were rated as being inconsistent; and data sets for which I^2^ could not be calculated (e.g., a single study) were rated as consistency unknown. For qualitative comparisons, we rated conclusions as consistent if the effect sizes were all in the same direction. We used the width of the 95 percent confidence intervals around the summary effect sizes to evaluate the precision of the evidence. If the study directly addressed a key question, the evidence was rated as direct.

We used the following process to grade the evidence: the base grade was chosen based on the study limitations for the evidence base. If the level of study limitations was judged to be low, the grade started at highat high; if the study limitations were at a medium level, the grade started at moderate; and if the level of study limitations was high, the grade started at low. If the evidence base consisted of only one study, it was automatically rated as insufficient. If the evidence was not consistent, it was downgraded one step; if it was not precise (or if precision could not be determined), it was downgraded by one step; and if not direct, it also was downgraded by one step. We intended to use an additional criterion (order of magnitude of effect); if the effect was judged to be extremely large, we would upgrade one step; however, this situation did not occur.

Publication bias was addressed by inspection of funnel plots supplemented with information from the included systematic reviews. We also looked for evidence that earlier publications were more likely to report positive findings.

We did not grade the strength of evidence from published systematic reviews, but as described previously, we assessed their quality using the modified AMSTAR instrument.

## Applicability

The applicability of the evidence involves four key aspects: patients, tests or interventions, comparisons and settings.83 After discussions with the TEP, we concluded that age and sex of patients is unlikely to affect the accuracy of staging, but other patient characteristics, such as race, obesity, genetic syndromes predisposing to colorectal cancer, and enrollment of populations with high rates of comorbid conditions, could affect the applicability of study findings, particularly with regard to patient-oriented outcomes. After consulting with the TEP, we addressed test and interventions and comparisons by excluding obsolete and experimental imaging tests from the report.

## Peer Review and Public Commentary

Peer reviewers were invited to provide written comments on the draft based on their clinical, content, or methodologic expertise. AHRQ and an EPC Associate Editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. Reviewer comments on the preliminary draft were considered by the EPC in preparing the final report. Peer reviewers do not participate in writing or editing the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer-review and public comments are documented and will be published 3 months after the publication of the Evidence Report.

Potential reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited peer reviewers may not have any financial conflict of interest greater than $10,000. Peer reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.