# Introduction

## Background

### Colorectal Cancer

In the United States, colon cancer is diagnosed in approximately 100,000 patients and rectal cancer is diagnosed in another 50,000 each year.1 These cancers most commonly affect older adults, with 90 percent of cases diagnosed in individuals older than 50 years.2 Colorectal cancer is often fatal, with approximately 50,000 deaths attributed to it each year in the United States.1 As such, it is the third-most common type of cancer and the third-most common cause of cancer-related death for both men and women. Colorectal cancer is also associated with high health care costs. It has been estimated to be the cancer site with the second-highest associated cost of care (second only to female breast cancer).3,4

Ninety-six percent of colorectal cancers are epithelial adenocarcinomas,20 which develop from the cells that line the interior of the colon and rectum (the large intestine). The large intestine is the final segment of the digestive tract, and its primary function in digestion is to extract water and minerals from the remaining food matter and then store the resulting solid waste in the rectum until it can be excreted. The colon consists of four sections: the ascending colon, which is attached to the small intestine and loops upward on the right side of the abdomen; the transverse colon, which passes horizontally from the right to the left side of the abdomen; the descending colon, which passes downward on the left side of the abdomen; and the sigmoid colon, which is S-shaped and attaches to the rectum.

Most colorectal cancers develop slowly over decades.21 The process involves a gradual accumulation of genetic mutations and epigenetic alterations. The first histologically detectable change is development of aberrant crypt foci in the lining of the intestine. The crypt foci may progress to adenomatous polyps, some of which (an estimated 10 percent) may eventually progress to invasive cancer (adenocarcinomas). Adenomatous polyps are very common, possibly affecting 50 percent of the population. Many individuals form more than one polyp.22 Removing screening-detected polyps may prevent colorectal cancer from forming.23

Although often mentioned together as if they were the same condition, colon and rectal cancer differ significantly in their epidemiology, prognosis, and treatment. Colon cancer is more common than rectal cancer and can be subdivided as proximal (involving the cecum, ascending, and transverse colon) or distal (involving the descending and sigmoid colon) cancer. Men are more likely to develop distal colon and rectal cancer, and women and younger patients of either sex are more likely to develop proximal colon cancer.24,25

Risk factors for developing colorectal cancer include a family history of colorectal cancer or adenomatous polyps, a personal history of chronic inflammatory bowel disease, physical inactivity, obesity, frequent consumption of red meat that has been cooked at a high temperature or for a long time, frequent consumption of processed preserved meats, smoking, and heavy alcohol consumption.2 Regular use of nonsteroidal anti-inflammatory drugs (NSAIDs) may reduce the risk of colorectal cancer, as does the use of postmenopausal hormonal replacement therapy.2 About 5 percent of individuals in whom colorectal cancer has been diagnosed have a well-defined genetic syndrome, such as hereditary nonpolyposis colorectal cancer (Lynch syndrome) or familial adenomatous polyposis.2

Colorectal cancers may be diagnosed during screening of asymptomatic individuals or after the patient has developed symptoms. Colon cancer symptoms can include abdominal discomfort, change in bowel habits (diarrhea or constipation), fatigue due to anemia, and weight loss. Rectal cancer symptoms include bleeding, diarrhea, and pain. The United States Preventive Services Task Force currently recommends screening for colorectal cancer in asymptomatic individuals using fecal occult blood testing, sigmoidoscopy, or colonoscopy, beginning at age 50 years and continuing until age 75 years.5 Diagnosis is usually established through histopathologic examination of tissue samples (obtained through colonoscopy or biopsy).

### Staging

#### Staging Systems

Once the diagnosis has been established, patients with colorectal cancer undergo testing to establish the extent of disease spread, known as clinical staging. Staging is used primarily to determine appropriate treatment strategies. Staging consists of assessing the status of the tumor in regards to various factors, such as depth of tumor invasion into the colorectal wall, fat and fascia involvement, status of circumferential resection margin, invasion into surrounding structures, involvement of local lymph nodes, and distant metastasis. Determining the correct clinical stage for colon and rectal cancer is of the utmost importance because treatment options differ greatly depending on the clinical stage of disease at diagnosis; for example, tumors confined to the rectal wall can be treated by local excision, but tumors that have progressed to involve the fascia and fat usually require preoperative chemotherapy and radiation prior to surgical resection. Similarly, the presence of distant metastases usually leads to a decision to use chemotherapy rather than surgical resection. Stage is not the only determinant of treatment options; patient comorbidities and preferences and clinician and institution preferences are also used in decisionmaking. However, stage is the key determinant of the management strategy. Staging is also used to inform patient prognosis and identify patients at higher risk of relapse or cancer-related mortality.

The American Joint Committee on Cancer (AJCC) endorses the widely accepted “TNM” staging system for colorectal cancer. This system is consistent with the Union for International Cancer Control staging system, allowing direct comparisons across clinical research centers or countries. The AJCC system aims to characterize the anatomic extent of colorectal cancer based on three tumor characteristics: the extent of tumor infiltration into the bowel wall (tumor stage, designated as “T”), the extent of local or regional lymph node spread (nodal stage, designated as “N”), and the presence of distant metastatic lesions (metastatic spread, designated as “M”).

Once the T, N, and M components are determined, they are used to assign the disease into four broad stages of increasingly unfavorable prognosis (denoted I through IV). The categories are mutually exclusive (i.e., a patient can belong to only one category) and exhaustive (i.e., all patients belong to a category). Two other, older colorectal cancer staging systems—the Dukes26 and modified Astler-Coller27 staging systems—are less widely used. One of the challenges we had to overcome in this systematic review was determining how cancer stages can be translated between staging systems or within versions of the AJCC staging system, currently in its 7^th^ edition. The 5^th^ edition was released in 1998, the 6^th^ edition in 2003, and the 7^th^ edition in 2010. The major difference between the 5^th^/6^th^ systems and the 7^th^ system is the earlier versions do not separate stage T4 into subgroups, do not separate stage N1/N2 into subgroups, and do not separate stage M1 into subgroups. The staging systems are summarized below, in Table 1 through Table 4.

Table 1 Tumor-Node-Metastasis (TNM) definitions for colorectal cancer

T | N | M
Tx: No description of the tumor's extent is possible because of incomplete information. Tis: The cancer is in the earliest stage (in situ). It involves only the mucosa. It has not grown beyond the muscularis mucosa (inner muscle layer). T1: The cancer has grown through the muscularis mucosa and extends into the submucosa. T2: The cancer has grown through the submucosa and extends into the muscularis propria (thick outer muscle layer). T3: The cancer has grown through the muscularis propria and into the outermost layers of the colon or rectum but not through them. It has not reached any nearby organs or tissues. T4a: The cancer has grown through the serosa (also known as the visceral peritoneum), the outermost lining of the intestines. T4b: The cancer has grown through the wall of the colon or rectum and is attached to or invades into nearby tissues or organs. | Nx: No description of lymph node involvement is possible because of incomplete information. N0: No cancer in nearby lymph nodes. N1: Cancer cells are found in or near 1 to 3 nearby lymph nodes N1a: Cancer cells are found in 1 nearby lymph node. N1b: Cancer cells are found in 2–3 nearby lymph nodes. N1c: Small deposits of cancer cells are found in areas of fat near lymph nodes, but not in the lymph nodes themselves. N2: Cancer cells are found in 4 or more nearby lymph nodes N2a: Cancer cells are found in 4–6 nearby lymph nodes. N2b: Cancer cells are found in 7 or more nearby lymph nodes. | M0: No distant spread is seen. M1a: The cancer has spread to 1 distant organ or set of distant lymph nodes. M1b: The cancer has spread to more than 1 distant organ or set of distant lymph nodes, or it has spread to distant parts of the peritoneum (the lining of the abdominal cavity).

T: Categories of colorectal cancer describe the extent of spread through the layers that form the wall of the colon and rectum.

N: Categories indicate whether or not the cancer has spread to nearby lymph nodes and, if so, how many lymph nodes are involved.

M: Categories indicate whether or not the cancer has spread (metastasized) to distant organs, such as the liver, lungs, or distant lymph nodes.

Table 2 Dukes system

A | Tumor confined to the intestinal wall
B | Tumor invading through the intestinal wall
C1 | With lymph node involvement, but not apical node
C2 | With lymph node involvement, including apical node
D | Distant metastasis

Table 3 Modified Astler-Coller system

A | Tumor limited to mucosa
B1 | Tumor invading into muscularis
B2 | Tumor invading into serosa
B3 | Tumor invading into adjacent organs
C1, C2, C3 | Relevant B category but with lymph node involvement
D | Distant metastasis

Table 4 Taxonomic and prognostic groups based on the AJCC, Dukes, and Modified Astler-Coller staging systems

Stage | T | N | M | Dukes | MAC
0 | Tis | N0 | M0 | — | —
I | T1 | N0 | M0 | A | A
I | T2 | N0 | M0 | A | B1
IIA | T3 | N0 | M0 | B | B2
IIB | T4a | N0 | M0 | B | B2
IIC | T4b | N0 | M0 | B | B3
IIIA | T1-T2 | N1/N1c | M0 | C | C1
IIIA | T1 | N2a | M0 | C | C1
IIIB | T3-T4a | N1/N1c | M0 | C | C2
IIIB | T2-T3 | N2a | M0 | C | C1/C2
IIIB | T1-T2 | N2b | M0 | C | C1
IIIC | T4a | N2a | M0 | C | C2
IIIC | T3-T4a | N2b | M0 | C | C2
IIIC | T4b | N1-N2 | M0 | C | C3
IVA | Any T | Any N | M1a | D | D
IVB | Any T | Any N | M1b | D | D

MAC=Modified Astler-Coller system; T=tumor stage; N=nodal stage'. M=distant metastasis stage

Besides the factors considered in the TNM system, the circumferential resection margin is an important indicator of prognosis and essential information for treatment planning for rectal cancer.28,29 The circumferential resection margin is defined as the distance from the edge of the tumor to the margin of the resected specimen. Imaging technologies such as magnetic resonance imaging (MRI) are capable of predicting tumor involvement of the surgical circumferential resection margin. Patients with positive margins are at much higher risk of recurrence (19 percent to 22 percent vs. 3 percent to 5 percent risk for those with negative margins).28

The depth of tumor invasion outside the muscularis propria is also thought to be an important factor to consider in rectal cancer staging. The 5-year survival rate drops from 85 percent to 54 percent when the depth of tumor invasion outside the muscularis propria exceeds 5 mm.30 The Radiological Society of North American suggests modifying the T3 stage by adding a letter that describes the depth of invasion (namely, T3a is less than 5 mm of invasion; T3b is 5–10 mm of invasion; T3c is more than 10 mm of invasion).30

#### Staging/Interim Restaging

Staging is performed at two distinct time points in managing colorectal cancer. The first is immediately after diagnosis, before any treatment has been given. Imaging and clinical examination are used to assign the clinical stage, which is used to make decisions about primary treatment and management. The second time point applies only to patients who, on the basis of their primary clinical stage, were treated with neoadjuvant chemotherapy or radiotherapy instead of with immediate surgery. For clinical stage I colon or rectal cancer and clinical stage II, or III colon cancer, surgical resection is the primary treatment. For patients with clinical stage II or III rectal cancer, preoperative chemotherapy and possibly radiation is the preferred initial treatment. Surgery is an option for some patients with clinical stage IV colorectal cancer, but for these patients, primary treatment is chemotherapy.31

Clinical staging after initial treatment with chemotherapy and radiotherapy (interim staging or restaging) is primarily intended to determine whether the tumor has responded to the initial treatment (downstaging). Chemotherapy and radiotherapy affect the metabolism and structure of the tissues such that some kinds of imaging may be less accurate for restaging than in the pretreatment setting. Also, the role of imaging at each of these two time points is very different, and for these two reasons they are addressed in separate key questions in this review.

#### Recurrent Colorectal Cancer

Recurrent colorectal cancer arises in some patients after undergoing apparently successful initial treatment for primary colorectal cancer. Approximately 20 to 30 percent of patients will develop recurrent disease. After completing primary treatment, patients usually enter a routine surveillance program intended to detect signs of recurrence. Typically, this consists of regular tests for biomarkers (such as carcinoembryonic antigen), clinical examination, colonoscopies, and possibly computed tomography (CT) scans.31 After the diagnosis of a possible recurrence, clinical staging aims to assess the extent of disease to guide treatment decisions and determine prognosis. Multiple treatment options (e.g., chemotherapy alone vs. multimodality therapy, including metastasectomy) are available for patients with recurrent disease, and the decision is chiefly based on accurate clinical assessment of the extent of disease.31

### Imaging Technologies

Imaging tests can be broadly divided into two categories: some tests primarily provide anatomic information (e.g., CT), whereas others primarily provide functional information in terms of metabolic activity (e.g., positron emission tomography [PET]). An important characteristic of imaging tests to consider is whether they use ionizing radiation; for patients with colorectal cancer who have a long life expectancy (e.g., those with early-stage disease who undergo treatment with curative intent), the cumulative exposure to ionizing radiation during diagnosis, staging, and subsequent surveillance can be substantial.32

Different imaging tests provide different information for assessing TNM stage. For example, endoscopic ultrasound can provide information on the “local stage” (i.e., the depth of invasion of the cancer into the bowel wall), but not on the presence of distant metastases. In contrast, whole-body CT or PET/CT may not be useful for assessing depth of invasion into the bowel wall, but can provide information on metastatic lesions, even when patients have no symptoms from the lesions. Consequently, no single test may be sufficient for staging, and different combinations of tests are possible.

In the following sections, we discuss endoscopic ultrasound, CT, MRI, and PET/CT techniques.

#### Endoscopic Ultrasound

Endoscopic ultrasound (also referred to as endorectal ultrasound, or endoscopic rectal ultrasound) entered into clinical practice for staging rectal cancer in the early 1980s. As the ultrasound probe is inserted into the rectum and can only visualize the immediate area around the rectum, it is only able to assess the clinical T and N stages (not distant metastatic disease).

The procedure requires an empty rectum, which can be achieved by using standard bowel preparation protocols developed for colonoscopy or laxative enemas. The patient usually does not need to be sedated. Three different types of equipment are commonly used: flexible echoendoscopes, rigid probes with a radial transducer, and high-frequency miniprobes inside standard endoscopes. Variable ultrasound frequencies (5–15 MHz) are used because higher frequencies provide better resolution of the rectal wall, but lower frequencies are better for visualizing lymph nodes and perirectal tissue.33 ERUS is not suitable for use in patients with stenosing tumors, as it may be impossible to advance the probe beyond the tumor.

One of the problems with ERUS is that image quality and interpretation is primarily done by visually inspecting the image. Thus, the diagnostic accuracy varies with the operator's skill and experience level.33 Burtin et al. reported that interobserver agreement was particularly poor for staging T2 rectal tumors.34

Ultrasound employs high-frequency sound waves that reflect at boundaries between tissues with different acoustic properties. B-mode gray-scale ultrasound is the most commonly used type of ultrasound.35 This mode uses differences in the reflection and absorption of sound waves by different tissue types to visualize internal anatomy. The contrast resolution of conventional ultrasound depends distance from the transducer to the structures of interest as well as on the transducer's frequency. Advanced software programs using three-dimensional (3D) reconstruction of the anatomy are becoming more commonly used and may improve recognition of the rectal anatomy and pathologic lesions.36

Doppler ultrasound evaluates blood flow through vessels by observing changes in the pitch of the reflected sound waves (the Doppler effect). Doppler can be helpful when evaluating soft tissue masses because malignant masses usually demonstrate increased vascularity compared with benign tissues. Doppler imaging can also be performed with microbubble contrast agents that enhance evaluation of the vascularity of soft tissue masses which can be helpful in distinguishing between malignancy and benign lesions.37

Two primary types of Doppler imaging exist: color and power. Color Doppler imaging encodes the mean Doppler frequency shifts at particular locations in various colors, whereas power Doppler imaging encodes the power of the signal (extent of the Doppler effect) at particular locations in various colors.38 Color Doppler, therefore, detects the velocity of the blood cells, and power Doppler detects the amount of blood present.38

The American College of Radiology (ACR) has instituted a voluntary general ultrasound accreditation program that offers facilities the opportunity for peer review of their staff qualifications, equipment, and quality control and quality-assurance programs.39

#### Magnetic Resonance Imaging

MRI systems use strong magnetic fields and radiofrequency energy to translate hydrogen nuclei distribution in tissues into computer-generated images of the body. MRI does not expose patients to radiation, but does often involve the use of contrast agents to improve image resolution.

MRI systems are usually described primarily in terms of magnet strength, in the unit tesla (T). Systems in commercial use usually vary from 0.5 T to 3.0 T. In general, increasing the magnet strength increases the spatial resolution of the images. MRI systems that use field strengths below 1 T are usually open gantries and are primarily used for patients who cannot be accommodated inside the bore of a higher-field-strength magnet because of claustrophobia. An additional reason to use open gantry systems is that MRI-guided invasive procedures, such as biopsies, are much easier to perform in open gantries than in closed systems.40

Special coils are routinely used in MRI to increase the efficiency of signal detection and, by extension, the image quality. At one time, endorectal coils were in common use, but problems with these coils (e.g., limited field of view, patient discomfort, difficulty in placing coils in patients with high or stenosing tumors) led to their abandonment in favor of dedicated surface phased array coils. Phased-array coils contain multiple surface coils that increase the signal-to-noise ratio and provide a large field of view with a high spatial resolution.41

Many different imaging protocols can be used on any MRI device, but most anatomic imaging protocols utilize. T1- or T2-weighted pulse sequences. Diffusion-weighted imaging, which measures the movement of water in the tissue, is a commonly performed functional imaging protocol.42,43 While all suppliers of MRI equipment provide suggested protocols for different examination types, users commonly customize these. The degree of protocol customization largely depends on the clinical users, both radiologists and technologists. Even in well-run multi-institutional studies with a limited number of institutions all using equipment supplied by the same manufacturer, differences in technique have been observed.44

MR images are susceptible to a number of artifacts that could cause image distortion and false interpretations. Respiratory motion can be a problem, although when the patient is prone the effect is reduced.45 MRI interpretation requires specialized training.46,47 The accuracy of MR imaging depends on the image reader's experience and skill and is subject to significant inter- and intraobserver variability.30 Computer-assisted imaging devices may reduce subjectivity and decrease time required for image interpretation.48

Gadolinium-based paramagnetic contrast agents accumulate in the vascular system and can aid in tumor visualization by highlighting areas of increased vascularity through differential enhancement. Five slightly different gadolinium-based contrast agents are in common clinical use: gadobenate dimeglumine, gadopentetate dimeglumine, gadodiamide, gadoteridol, and gadoversetamide.49 Besides these general-purpose contrast agents, hepatobiliary-specific contrast agents are available for imaging the liver (e.g., gadoxetic acid).50 These agents differ slightly in molecular structure; however, all consist of the heavy metal gadolinium bound to a chelating molecule.51 Different agents demonstrate different imaging properties.52,53 The exact dose of conventional gadolinium contrast agents is not particularly relevant to image quality when used in the normal range (0.1 to 0.2 mmol/kg). When contrast is taken up by a lesion, one of three characteristic enhancement and wash-out curves are usually observed: continuous enhancement, rapid enhancement followed by a plateau, or rapid enhancement followed by rapid wash-out. Rapid wash-out is considered indicative of malignancy.46 However, many centers do not use intravenous contrast agents for rectal cancer staging because of the perception that it is not helpful.54

For rectal imaging, a contrast agent such as air, water, barium, ferumoxsil, or ultrasound gel may be introduced into the rectum through the anal sphincter after cleansing the rectum by enema.30,54 The patient may be treated with an antispasmodic agent before imaging to reduce bowel motion.54

No nationwide compulsory accreditation exists for MRI facilities. ACR administers a voluntary accreditation program.55

#### Computed Tomography

CT uses x-rays to generate images of internal anatomy. In CT scanning, an x-ray source rotates around the body, scanning narrow “slices” of the body. As the x-rays pass through the body, they are absorbed differentially by different tissues. Opposite the x-ray source are detectors that collect the x-rays that have passed through the “slice” of body. The information collected by the detectors is used to generate images of the internal anatomy. Modern CT machines can scan in both axial and spiral fashion and have multiple detectors to collect information from multiple “slices” of the body simultaneously. As a result, CT examinations are typically performed in a single breath-hold, which reduces artifacts caused by respiratory and organ motion. In addition, with the use of thin section imaging, coronal and sagittal reformats can be generated from the axial images with good resolution; therefore aiding in the localization of primary tumor as well as identification of lymph nodes and metastatic lesions.

Iodinated contrast agents are sometimes used to enhance CT imaging of the vasculature. Intravenous contrast is typically used for staging colorectal cancer as it improves visualization of the tumor, lymph nodes, and metastatic lesions. Oral contrast agents are almost always used as well for staging examinations, as they help to differentiate the bowel from adjacent structures. Another option is to inflate the rectum with air or water to improve contrast.

ACR offers a voluntary accreditation program for CT facilities.56

#### Positron Emission Tomography/Computed Tomography

PET is a nuclear imaging modality that uses radioactive tracers to provide images reflecting metabolic processes. Several different radiopharmaceuticals can be used in PET imaging. The tracer most commonly used is ^18^F-fluorodeoxyglucose (FDG), a glucose analog that accumulates in tissue in proportion to the metabolic activity of the tissue. The uptake of the radioactive tracer can be monitored by PET and provide images of regional glucose metabolism. Since rapidly dividing tumor cells metabolize large amounts of glucose. Areas of elevated metabolism, which may be tumor cells, can be visualized on the PET images. However, infected and inflamed tissue also take up FDG and can cause false-positive results; this can be a particular problem after radiation therapy, when tissues may exhibit a protracted inflammatory response.57

Stand-alone, whole-body PET scanners for oncology indications are rapidly becoming obsolete.58 Combined CT/PET systems are increasingly available and account for almost all the new whole-body PET installations. In this report, we discuss whole-body scanners that combine PET with CT and not stand-alone PET scanners. These systems allow images of metabolism and anatomy to be obtained at the same time. When performing a PET/CT scan, a small amount of FDG is injected into the patient's bloodstream, and the device first performs a CT scan, which provides anatomic information, followed immediately by a PET scan, which provides metabolic information, highlighting areas of high tracer uptake. Whole-body scanners have a ring of detectors that surround the patient and can image the entire body. The 3D anatomic images (CT scanning) are overlaid over the PET images of metabolism on a computer workstation.

The standardized uptake value, which is the mean tracer activity detected normalized for the injected dose of tracer and patient's body weight, depends on an image reconstruction algorithm, which varies by device manufacturer.59 Therefore, diagnostic performance of PET/CT imaging may vary across manufacturers. Diagnostic performance may also vary depending on study-specific factors such as FDG uptake time, patient motion, the size and histology of the lesion(s), patient weight, position and blood glucose level, spatial resolution, and interpretation of the final image.60-62 PET images have a spatial resolution of 4 to 10 mm, limiting detection of very small lesions.57

The Intersocietal Accreditation Commission (formerly the Intersocietal Commission for the Accreditation of Nuclear Medicine Laboratories) offers voluntary accreditation to PET/CT facilities based on a peer review of their staff qualifications, education, equipment, quality control, and volume of clinical procedures.63

## Scope and Key Questions

### Scope of the Review

We have summarized key recommendations from organizations in the United States regarding the use of imaging tests for staging in Table 5. As the table shows, the organizations are not in complete agreement about which modalities should be emphasized for the clinical situations described. Also, no consensus guidance exists about the sequence in which these tests are to be applied in the staging process.

Table 5 Summary of existing guidelines for staging colorectal cancer

Clinical Description | ACR Recommendations | NCCN Recommendations
Colon cancer | Usually appropriate; - CT chest-abdomen-pelvis with or without contrast; - X-ray chest (if chest CT is not performed); - FDG-PET whole body; - MRI abdomen and pelvis with or without contrast | Recommended; - Chest/abdominal/pelvic CT with IV and oral contrast
Colon cancer | May be appropriate; - MRI abdomen and pelvis without contrast; - CT chest-abdomen-pelvis with and without contrast; - CT chest-abdomen-pelvis without contrast
Colon cancer | Usually not appropriate; - None reported | Usually not indicated; - PET scan; - PET-CT does not supplant a contrast-enhanced diagnostic CT
Rectal cancer | Usually appropriate for small lesions; - US pelvis endorectal; - X-ray chest (if chest is not imaged by CT); - CT chest-abdomen-pelvis with or without contrast; - MRI pelvis with or without contrast; Usually appropriate for large lesions; - X-ray chest; - CT chest-abdomen-pelvis with or without contrast; - MRI abdomen with or without contrast; - MRI pelvis with or without contrast; - FDG-PET whole body | Recommended; - Chest/abdominal/pelvic CT; - Endorectal US or endorectal/pelvic MRI
Rectal cancer | May be appropriate for small lesions; - FDG-PET whole body; - MRI abdomen with and without contrast; - MRI abdomen without contrast; - CT chest-abdomen-pelvis without contrast; - CT chest-abdomen-pelvis with and without contrast; - MRI pelvis without contrast; May be appropriate for large lesions; - US pelvis endorectal; - MRI abdomen without contrast; - MRI abdomen with contrast; - CT chest-abdomen-pelvis without contrast; - CT chest-abdomen-pelvis with and without contrast
Rectal cancer | Usually not appropriate; - None reported | Usually not indicated; - PET-CT not routinely indicated
Suspected liver metastases following detection of primary tumor65 | Usually appropriate; - CT abdomen with contrast; - MRI abdomen with and without contrast; - FDG-PET skull base to mid-thigh; May be appropriate; - MRI abdomen without contrast; - CT abdomen with and without contrast; - CT abdomen without contrast; - US abdomen; Usually not appropriate; - CTA abdomen with contrast; - In-111 somatostatin receptor scintigraphy
Suspected or proven metastatic synchronous adenocarcinoma (M1) | | Recommended; - Chest/abdominal/pelvic CT (with IV contrast);; - Consider MRI with IV contrast if CT is inadequate; - Needle biopsy (if indicated); May be appropriate; - PET-CT scan only if potentially curable M1 disease

ACR=American College of Radiology; CT=computed tomography; CTA=computed tomography angiography; FDG=^18^F-fluorodeoxyglucose tracer with positron emission tomography; IV=intravenous; MRI=magnetic resonance imaging; NCCN=National Comprehensive Cancer Network; PET=positron emission tomography; PET-CT=positron emission tomography combined with computerized tomography; US=ultrasonography.

The imaging modalities vary in accuracy as well as in the harms they can potentially cause. To be clinically useful and relevant, these benefits should be weighed against the potential harms of using the modality. The tumor's size may also have a significant effect on the accuracy of the imaging modality. For example, the ACR guidelines64 provide different recommendations for large and small rectal cancer lesions, whereas the National Comprehensive Cancer Network guidelines31 do not make that distinction. The differences in the testing protocols associated with different imaging modalities can affect their test performance and need to be systematically reviewed. Although it is necessary to identify the most accurate test (or combination of tests) for correctly staging the cancer, it is also important to assess the relative impact of testing strategies using different imaging modalities on intermediate outcomes such as stage reclassification (i.e., an indication of how much additional information is obtained by applying a test) and therapeutic decisionmaking (i.e., measures of the impact of tests on clinical decisions), and clinical outcomes. Building on the available scientific data, it is hoped that this systematic review of the available imaging modalities for colorectal cancer staging will uncover evidence to support these questions or highlight any issues not addressed by the currently available evidence that may represent targets for future research.

More accurate staging of colorectal cancer allows clinicians to select more appropriate treatment options. Selection of more appropriate treatment options would be expected to improve clinical outcomes (e.g., by avoiding unnecessarily aggressive treatments for low-risk disease). Besides assisting in treatment selection, staging also provides important prognostic information about chances of short- and long-term survival.

This review's primary objective is to synthesize the available information on using imaging for staging colorectal cancer. The availability of this information will assist clinicians in selecting protocols for staging, may reduce variability across treatment centers in staging protocols, and may improve patient outcomes. A secondary objective is to identify gaps in the evidence base to inform future research needs.

### Key Questions

The draft key questions were posted for public comment in November 2012 on the Web site of the Effective Health Care Program. No comments were received; therefore, no substantive changes were made to the key questions. They are listed below:

Key Question 1. What is the comparative effectiveness of imaging techniques for pretreatment cancer staging in patients with primary and recurrent colorectal cancer?

a. What is the test performance of the imaging techniques used (singly, in combination, or in a specific sequence) to stage colorectal cancer compared with a reference standard?
b. What is the impact of alternative imaging techniques on intermediate outcomes, including stage reclassification and changes in therapeutic management?
c. What is the impact of alternative imaging techniques on clinical outcomes?
d. What are the adverse effects or harms associated with using imaging techniques, including harms of test-directed management?
e. How is the comparative effectiveness of imaging techniques modified by the following factors:
  i. Patient-level characteristics (e.g., age, sex, body mass index)
  ii. Disease characteristics (e.g., tumor grade)
  iii. Imaging technique or protocol characteristics (e.g., use of different tracers or contrast agents, radiation dose of the imaging modality, slice thickness, timing of contrast)

Key Question 2. What is the comparative effectiveness of imaging techniques for restaging cancer in patients with primary and recurrent colorectal cancer after initial treatment?

a. What is the test performance of the imaging techniques used (singly, in combination, or in a specific sequence) to restage colorectal cancer compared with a reference standard?
b. What is the impact of alternative imaging techniques on intermediate outcomes, including stage reclassification and changes in therapeutic management?
c. What is the impact of alternative imaging techniques on clinical outcomes?
d. What are the adverse effects or harms associated with using imaging techniques, including harms of test-directed management?
e. How is the comparative effectiveness of imaging techniques modified by the following factors:
  i. Patient-level characteristics (e.g., age, sex, body mass index)
  ii. Disease characteristics (e.g., tumor grade)
  iii. Imaging technique or protocol characteristics (e.g., use of different tracers or contrast agents, radiation dose of the imaging modality, slice thickness, timing of contrast)

### PICOTS

Populations:

- Adult patients with an established diagnosis of primary colorectal cancer
- Adult patients with an established diagnosis of recurrent colorectal cancer

Interventions:

Noninvasive imaging using the following tests (alone or in combination) for assessing the stage of colorectal cancer:

- Computed tomography (CT)
- Positron emission tomography combined with computerized tomography (PET/CT)
- Magnetic resonance imaging (MRI)
- Endoscopic rectal ultrasound (ERUS

Reference Standards to Assess Test Performance:

- Histopathologic examination of tissue
- Intraoperative findings
- Clinical followup

Histopathology of surgically resected specimens is the reference standard for pretherapy staging. In patients undergoing surgery, the nodal stage and spread of the tumor to nearby regional structures and other organs are assessed intraoperatively either by palpation or ultrasound. However, in patients with metastatic disease who undergo palliative care, a combination of initial biopsy results and clinical followup serves as the reference standard. The results from the imaging modality or modalities are used to arrive at a stage determination that is compared against the stage established by the reference standard. These comparisons indicate how many people were correctly classified as belonging to various stages of the disease, which allows us to calculate the test performance metrics of sensitivity, specificity, accuracy, and over-, and understaging. The selection of the reference standard is important in evaluating the true performance of an imaging modality for staging.

Comparators:

- Any direct comparisons of the imaging tests of interest
- Any direct comparisons of variations of any of the imaging tests of interest (e.g., contrast enhanced MRI vs. not enhanced MRI)

Outcomes:

- Test performance outcomes
  ○ Test performance (e.g., sensitivity, specificity, accuracy, over-, and understaging) against a reference standard test (pathologic examination, clinical followup, or intraoperative findings)
- Intermediate outcomes
  ○ Stage reclassification
  ○ Changes in therapeutic management
- Clinical outcomes
  ○ Overall mortality
  ○ Colorectal cancer–specific mortality
  ○ Quality of life and anxiety
  ○ Need for additional staging tests, including invasive procedures
  ○ Need for additional treatment, including surgery, radiotherapy, or chemotherapy
  ○ Resource use related to testing and treatment (when reported in the included studies)
- Adverse effects and harms
  ○ Harms of testing per se (e.g., radiation exposure)
  ○ Harms from test-directed treatments (e.g., overtreatment, undertreatment)

Timing:

- Primary staging
- Interim restaging
- Duration of followup will vary by outcome (e.g., from no followup for test performance measurements to many years for mortality)

Setting:

Any setting will be considered.

### Conceptual Framework

An analytic framework illustrating the connections between the populations of interest, the staging modalities, and the outcomes is shown in Figure 1. Note the patient populations of interest are patients with newly diagnosed colorectal cancer or recurrent colorectal cancer. Populations that have completed treatment for colorectal cancer and are undergoing surveillance for recurrences are outside the scope of this report, as are asymptomatic individuals who are undergoing screening or individuals suspected of having cancer undergoing diagnostic workup. The use of imaging in diagnosing colorectal cancer is also outside the scope of this report.

Figure 1 Analytical framework of colorectal cancer staging review

Figure 1 shows an analytical framework illustrating the connections between the populations of interest, the staging modalities, and the outcomes. The populations of interest (patients with colorectal cancer) enter the diagram at the left, undergo primary staging (Key Question 1), and then commence treatment. Some patients also undergo restaging after completing pre-surgical treatments such as chemotherapy (Key Question 2), and then proceed with the rest of their treatment. Intermediate and patient-oriented outcomes of staging are shown towards the right side of the figure. Direct and indirect harms of testing are also shown towards the lower right side of the figure. The point in the process at which each Key Question is most relevant is shown on the figure by the placement of the Key Question number (1 or 2) and subpart (e.g., a, b, c). The modifying factors affecting test performance in both the primary staging and re-staging settings are shown in a separate box at the bottom of the figure.

The populations of interest enter the diagram at the left, undergo primary staging (Key Question 1), and then commence treatment. Some patients also undergo restaging after completing presurgical treatments such as chemotherapy (Key Question 2) and then proceed with treatment. Intermediate outcomes such as test performance and harms of testing can be measured immediately after performing the tests, but many of the relevant patient-oriented outcomes (such as mortality) can be measured only after completion of treatment. The point in the process at which each key question is most relevant is shown on the figure by the placement of the key question number (1 or 2) and subpart (e.g., a, b, c). The modifying factors affecting test performance in both the primary staging and restaging settings are shown in a separate box at the bottom of the figure.

Although not specified in the figure for simplicity, the four primary patient populations will be considered separately—patients with recurrent versus primary disease and primary staging versus interim restaging. If the data permitted it, additional groups were to be considered separately—rectal versus colon cancer, proximal colon versus distal colon cancer, and lower rectal versus middle rectal versus upper rectal cancer. However, the data permitted considering only rectal separately from colorectal cancer.

An important factor in selecting an imaging modality for staging is the availability of that modality. Although this factor will not be addressed formally via a key question, we collected and provide relevant information about the availability and accessibility of imaging modalities and information about current patterns of care. This information is presented in the discussion section to help place the evidence review findings in context.

## Organization of This Report

In the remaining three chapters of this report, we present the methods for this systematic review, the results for each key question, and a discussion of the findings. Within the Results chapter, we provide the results of the literature searches and screening procedures, then the results for Key Question 1. Findings for imaging studies of rectal cancer were reported separately, but those of colon cancer were reported in the literature only in mixed populations (rectal plus colon); consequently, we have presented findings specific to rectal cancer first, followed by results for colorectal cancer. We summarize the findings of previous systematic reviews on diagnostic accuracy of individual imaging modalities (ERUS, CT, MRI, and PET/CT) for staging of rectal and colorectal cancer before initial treatment, supplemented by an assessment of primary studies of PET/CT diagnostic accuracy for these indications. Following this, we present our assessment of primary studies comparing accuracy of one of these imaging modalities to another for TNM staging of rectal and colorectal cancer. We also present findings in terms of impact of the imaging results on therapeutic management. We then present reports of adverse events associated with the imaging techniques and finally, the patient, disease, and technical factors that affect the accuracy of the imaging studies. The results for Key Question 2, on restaging cancer in patients with primary and recurrent rectal and colorectal cancer after initial treatment, are presented in a similar order.

A list of acronyms and abbreviations is available following the list of references for this report. The Appendixes include Appendix A. Search Strategy, Appendix B. Excluded Studies, Appendix C. Evidence Tables and Appendix D. Analyses and Risk of Bias Assessments.