# Glossary of Selected Terms

Accuracy: Number of correctly staged cancers divided by the total number of all staged cancers.
Overstaged: Classified by the imaging modality as being of a higher stage than the stage defined by the reference standard.
Odds ratio: The odds of a staging error for a given modality is the rate of errors divided by the inverse of the rate of errors. The odds ratio is the odds of an error by one imaging modality divided by the odds of an error by another imaging modality. If the odds ratio is 1, no difference exists in odds of incorrect staging between the two modalities. If there is a difference, the odds ratio will be larger or smaller than 1 (depending on which imaging modality was selected to be the denominator, usually an arbitrary decision).
Sensitivity: The number of true positives divided by the sum of true positives and false negatives. Sensitivity is the proportion of people with the disease who have a positive test for the disease. A test with high sensitivity will rarely misclassify people with the disease as not having the disease (the test has a low rate of false negatives).
Specificity: The number of true negatives divided by the sum of true negatives and false positives. Specificity is the proportion of people without the disease who have a negative test. A test with high specificity will rarely misclassify people without the disease as diseased (a low rate of false positives).
Understaged: Classified by the imaging modality as being of a lower stage than the stage defined by the reference standard.