# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rongwei (Rochelle) Fu, Ph.D.
  Associate Professor, Department of Public Health and Preventive Medicine
  Oregon Health & Science University
  Portland, OR
- Benjamin Krevsky, M.D., M.P.H.
  Professor of Medicine
  Director of Gastrointestinal Endoscopy
  Temple University School of Medicine
  Philadelphia, PA
- Srinivas Puli, M.D.
  Gastroenterologist
  OSF Medical Group
  Peoria, IL
- Larissa Temple, M.D., FACS, FRCS(C)
  Colorectal Surgeon
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- Joel Tepper, M.D.
  Department of Radiation Oncology
  UNC/Lineberger Comprehensive Cancer Center
  University of North Carolina School of Medicine
  Chapel Hill, NC