# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Al B. Benson, III, M.D., FACP
  Professor of Medicine, Division of Hematology/Oncology
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Bruce J. Giantonio, M.D.
  Associate Professor of Medicine
  University of Pennsylvania Perelman School of Medicine
  Philadelphia, PA
- Najjia Mahmoud, M.D.
  Chief, Division of Colon and Rectal Surgery
  University of Pennsylvania Perelman School of Medicine
  Philadelphia, PA
- Max Rosen, M.D., M.P.H.
  Chairman of Radiology
  UMass Memorial Medical Center
  Boston, MA
- Mark A. Schattner, M.D., FACP, C.N.S.P.
  Department of Gastroenterology and Preventive Oncology
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- Christopher Willett, M.D.
  Chair, Radiation Oncology
  Duke Cancer Center
  Durham, NC
- Sandra L. Wong, M.D., M.S.
  Associate Professor of Surgery
  University of Michigan
  Ann Arbor, MI