# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Ivy Ahmed, M.P.H.
  Vice-President for Education & Outreach
  Research in Training Institute, Cancer Support Community
  Washington, DC
- George J. Chang, M.D., M.S., FACS, FASCRS
  Surgical Oncologist
  MD Anderson Cancer Center
  Houston, TX
- George A. Fisher, Jr., M.D., Ph.D.
  Gastrointestinal Oncologist
  Stanford Cancer Center
  Stanford, CAKoenraad J. Mortele, M.D.
  Radiologist
  Beth Israel Deaconess Medical Center
  Boston, MA
- Nancy Roach
  Chair of Board of Directors, Fight Colorectal Cancer
  Alexandria, VA
- Max Rosen, M.D.
  Chairman of Radiology
  UMass Memorial Medical Center
  Boston, MA
- Roger Snow, M.D., M.P.H.
  Deputy Medical Director,
  Office of Clinical Affairs, Office of Medicaid
  Massachusetts Department of Health and Human Services
  Boston, MA
- Wayne Wild, M.D., Ph.D.
  Medical Director, Tufts Health Plan
  Boston, MASandra L. Wong, M.D., M.S.
  Associate Professor of Surgery
  University of Michigan
  Ann Arbor, MI