# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Rebecca Rishar for conducting the searches and helping to screen abstracts, Gina Giradi for managing the project and recruiting the technical experts and reviewers, Dr. Craig Umscheid for recruiting clinical coauthors and technical reviewers, and for reviewing the final draft, and Lydia Dharia for spending endless hours formatting the report.