# Discussion

## Key Findings and Strength of Evidence

We compiled data from recent, high-quality systematic reviews to estimate the accuracy of each imaging modality in isolation. These data are summarized in Table 25. Because there were insufficient data on positron emission tomography/computed tomography (PET/CT) from systematic reviews, we examined the studies of PET/CT included in this report to address the comparative questions to estimate accuracy. An additional systematic review, Gall et al.,84 studied only one type of endorectal probe, so due to concerns about generalizability we have not included that data in the summary table below but discuss it in the relevant section of the text.

Table 25 Accuracy of imaging tests in isolation as reported by recent systematic reviews

Staging | ERUS | CT | MRI | PET/CT
Rectal T | [underlined: For identifying T1]: Sensitivity: 87.8% (85.3 to 90.0%) Specificity: 98.3% (97.8 to 98.7%) [underlined: For identifying T2]: Sensitivity: 80.5% (77.9 to 82.9%) Specificity: 95.6% (94.9 to 96.3%) [underlined: For identifying T3]: Sensitivity: 96.4% (95.4 to 97.2%) Specificity: 90.6% (89.5 to 91.7%) [underlined: For identifying T4]: Sensitivity: 95.4% (92.4 to 97.5%) Specificity: 98.3% (97.8 to 98.7%) | [underlined: For distinguishing T1/T2 from T3/T4]: Sensitivity: 86% (78 to 92%) Specificity: 78% (71 to 84%) | [underlined: For distinguishing T1/T2 from T3/T4]: Sensitivity: 87% (81 to 92%) Specificity: 75% (68 to 80%) [underlined: For identifying affected CRM]: Sensitivity: 77% (57 to 90%) Specificity: 94% (88 to 97%) | Not reported
Rectal N | [underlined: For identifying affected nodes]: Sensitivity: 73.2% (70.6 to 75.6%) Specificity: 75.8% (73.5 to 78.0%) | [underlined: For identifying affected nodes]: Sensitivity: 70% (59 to 80%) Specificity: 78% (66 to 86%) | [underlined: For identifying affected nodes]: Sensitivity: 77% (69 to 84%) Specificity: 71% (59 to 81%) | [underlined: For identifying affected nodes]: Sensitivity: 61% Specificity: 83%
Colorectal T | Not reported | Not reported | Not reported | Accuracy: 95.0%
Colorectal N | Not reported | Not reported | Not reported | [underlined: For identifying affected nodes]: Sensitivity: 34.3% Specificity: 100%
Colorectal M | Not reported | [underlined: For identifying liver metastases]: Sensitivity 83.6% | [underlined: For identifying liver metastases]: Sensitivity: 88.2% | [underlined: For identifying liver metastases]: Sensitivity: 72% to 97.9%
Interim restaging | Not reported | For identifying liver metastases: Sensitivity 54% (46.7 to 62.1%) | For identifying liver metastases: Sensitivity 69.9% (65.6 to 73.9%) | For identifying liver metastases: Sensitivity 51.7% (37.8 to 65.4%)

CT=Computed tomography; ERUS=endorectal ultrasound; M=metastases stage; MRI=magnetic resonance imaging; N=nodal stage; PET=positron emission tomography; T=tumor stage. ( ) denotes the 95% confidence intervals

Our major conclusions about comparative effectiveness are listed in Table 26.

Table 26 Summary of major conclusions

Conclusion Statement | # Studies (# patients) and Study Limitations | Consistency | Directness | Precision | Strength of Evidence
ERUS is more accurate (less likely to give an incorrect result) (OR=0.36, 95% CI, 0.24 to 0.54), less likely to understage (OR=0.63, 95% CI, 0.44 to 0.89), and less likely to overstage (OR=0.47; 95% CI, 0.28 to 0.80) rectal cancer than CT in the preoperative T staging setting.^a^ | 13 studies, total N=595 Medium | Consistent | Direct | Imprecise | Low
There is no statistically significant difference in accuracy between MRI and ERUS for preoperative rectal T staging. | 6 studies, total N=294 Medium | Consistent | Direct | Imprecise | Low
There is no statistically significant difference in accuracy across CT, MRI, or ERUS for preoperative rectal N staging. | 18 studies, total N=845 Medium | Consistent | Direct | Imprecise | Low
While there is no statistically significant difference in accuracy between CT and MRI for rectal N staging, MRI is less likely to overstage. | 4 studies, total N = 123 Medium | Consistent | Direct | Imprecise | Low
MRI is superior to CT in detecting colorectal liver metastases in the preoperative setting (OR=1.334; 95% CI, 1.012 to 1.761).^b^ | 5 studies, total N=217 Low | Consistent | Direct | Imprecise | Moderate
There is no statistically significant difference in accuracy across MRI, CT, or ERUS for rectal T staging in the interim restaging setting. | 4 studies, total N=225 Medium | Consistent | Direct | Imprecise | Low
The evidence was insufficient for assessing the comparison of PET/CT to CT or MRI for M staging or restaging. | 4 studies, total N=641; 1 study, total N=48 | Inconsistent | Direct | Imprecise | Insufficient

CI=Confidence interval; CT=computed tomography; ERUS=endorectal ultrasound; IV=intravenous; M=distant metastasis stage; MRI=magnetic resonance imaging; N=nodal stage; OR=odds ratio; T=tumor stage #=number.

a OR < 1 indicates a lower risk of error in the first imaging modality listed in the column header; OR > 1 indicates a higher risk of error in the first imaging modality listed in the column header (with the exception of detection of liver metastases. See below)

b This OR > 1 indicates that MRI is more likely to deteict liver metastases than is CT.

All four imaging modalities appear to be reasonably safe. For endorectal ultrasound (ERUS), the most common adverse event appears to be pain and minor bleeding; in theory, the major adverse event of bowel perforation could occur, but no included studies reported such an event had ever occurred. Our supplementary harms searches identified a narrative review of complications of endoscopic ultrasound, including ERUS.17 The authors noted that only one case had been reported in a prospective registry of the German Society of Ultrasound in Medicine, but did not report the number of ERUS procedures in the registry.

Harms from MRI appear to be limited to contrast agent reactions. Many of the included studies did not use intravenous contrast, and the available data suggests that the use of intravenous contrast does not improve the accuracy of MRI for rectal T or N colorectal staging.

Harms from CT include contrast agent reactions and radiation exposure. Many included studies did not use intravenous contrast, and one study suggests that using intravenous contrast does not improve CT's accuracy for rectal T or N staging.

The major harm from PET/CT is radiation exposure. A single PET/CT examination exposes the patient to about 18 mSv. Some experts believe this is a significant exposure; however, in 2010, the Health Physics Society published a position statement recommending against quantitative estimates of health risks below an individual dose of 5 rem per year (approximately 50 mSv) or a lifetime dose of 10 rem in addition to natural background radiation.18 However, if a patient undergoes a PET/CT scan for staging, has surgical treatment, and then has regular CT scans for surveillance, the accumulated radiation dose could approach or exceed the 5 rem limit.

Indirect harms of imaging consist primarily of harms related to incorrect treatment decisions based on inaccurate staging.

## Findings in Relationship to What Is Already Known

We identified a number of systematic reviews whose authors included studies reporting the accuracy of individual imaging modalities, synthesized the data for each imaging modality, and compared these summary accuracies across studies (i.e., making indirect comparisons). Bipat et al. published a systematic review in 2004 comparing the accuracy of pretreatment staging of rectal cancer by ERUS, computed tomography (CT), or magnetic resonance imaging (MRI).205 The review authors concluded that ERUS was the most accurate modality for pretreatment rectal T staging. This finding contrasts with our finding of no statistically significant difference in accuracy of MRI and ERUS in studies that made direct comparisons. The apparent discrepancy may be because most studies in the 2004 review used older, less accurate MRI machines. It may also be due to the presence of publication bias; as indicated previously, Harewood et al. and Puli et al. both noted that the reported accuracy of ERUS declined significantly over time, and that there is evidence of publication bias in the ERUS-specific literature published before 2003.^13,14^ At least one of the peer reviewers for this report noted the belief that ERUS is superior for assessing the extent of early T stage tumors, while MRI is better for assessing the extent of later T-stage tumors, but we were unable to confirm this using the included studies. The review by Bipat et al. agrees with our conclusion that ERUS was superior to CT for pretreatment rectal T staging.205

Lahaye et al. published a systematic review in 2005 comparing the accuracy of pretreatment N staging rectal cancer by ERUS, CT, or MRI,206 including 84 articles. The review authors concluded that for pretreatment N staging of rectal cancer, ERUS is slightly better than MRI or CT. However, we identified no statistically significant difference across modalities for this purpose and speculate that publication bias in the early ERUS literature may have also affected Lahaye et al.'s result.

Lahaye et al. also looked at the accuracy of assessing the circumferential resection margin and included seven studies on that topic, concluding that “MRI is the only modality that predicts the circumferential resection margin with good accuracy.”206 We identified only one direct comparison study on assessing the circumferential resection margin preoperatively. In this study of 42 patients, Taylor et al. concluded that both CT and MRI tended to overstage CRM status; however, they rarely understaged CRM status.119

Niekel et al. published a systematic review in 2010, comparing the accuracy of pretreatment staging of colorectal liver metastases by CT, MRI, PET, or PET/CT.15 The review authors concluded that “MR imaging is the preferred first-line modality for evaluating colorectal liver metastases in patients who have not previously undergone therapy.” We did not identify any PET/CT studies that met our inclusion criteria for comparative studies, but we did find that MRI was more accurate than CT for detecting liver metastases.

Skandarajah and Tjandra published a systematic review in 2006 comparing the accuracy of pretreatment T and N staging of rectal cancer by MRI or ERUS,207 including 31 studies of ultrasound and 8 of MRI. They concluded that ERUS and MRI are complementary and are most accurate for early localized cancers and more advanced cancers, respectively.”

Kwok et al. published a systematic review in 2000, comparing the accuracy of pretreatment staging of rectal cancer by CT, MRI, or ERUS, including 83 studies, and concluding: “MRI with an endorectal coil is the single investigation that most accurately predicts pathological stage in rectal cancer.”208 Endorectal coils have since been abandoned in favor of phased-array surface coils.

The key findings from our review are summarized above, in Table 25 and Table 26. Our findings, derived from studies performing direct comparisons between modalities, seem to be in contradiction to some of the findings from systematic reviews evaluating test performance in isolation.

For example, if one compares across the prior systematic reviews it seems MRI and CT are approximately equal in accuracy, and ERUS is slightly better than either for rectal tumor stage (T) staging; however, we found that MRI and ERUS are approximately equal in accuracy and ERUS is superior to CT (see Appendix D).

A similar situation exists for rectal nodal stage (N) staging. Our analyses found that all modalities had sensitivities for detecting affected lymph nodes in the 40 percent to 50 percent range, whereas all the estimates from earlier systematic reviews found sensitivities at the 70 percent level.

We are unsure of the reason for the differences. It is true that because we included only studies that directly compared modalities that our analysis is examining a different evidence base than systematic reviews that looked at modalities in isolation. Such differences in results have been discussed in a previously published EPC methodology study.209

It also may be that the noncomparative ERUS and CT literature is affected by publication bias. Puli et al. concluded that there was no evidence of publication bias in the ERUS literature in 2009; however, a systematic review published in 2005 (thus, not included to address the key questions) concluded that “the performance of EUS [endoscopic ultrasound] in staging rectal cancer may be overestimated in the literature due to publication bias.”13 The review included 41 studies published between 1985 and 2003. The author, Harewood, performed visual analyses of funnel diagrams and other plots, concluding that there were few smaller studies with lower accuracy rates and that the reported accuracy appeared to be declining over time. Studies published in the surgical literature reported higher accuracies than studies published in other types of journals.13

Puli et al. also analyzed the reported accuracy of endoscopic ultrasound over time and found that the reported accuracy had declined significantly from the 1980s through 2000 and had stabilized or only declined slightly since then.14 Dighe et al. reported that for N staging with CT, evidence existed that smaller studies were reporting higher accuracies (suggesting publication bias), and there was a nonsignificant trend showing the same result for T staging.16

Therefore, it is possible that the estimates of test accuracy for the modalities in isolation may be high due to publication bias in the noncomparative literature. We suggest focusing on the comparative-effectiveness conclusions in Table 25 instead of making indirect comparisons across the estimates of accuracy in Table 26. We derived our estimates of comparative effectiveness from direct comparisons on the same patients which are less prone to bias than indirect comparisons across different studies.

## Applicability

We judged the applicability of the evidence based on the PICO framework (patients, interventions, comparisons, outcomes and settings). The majority of studies reported very little information about patient characteristics. The mean age for patients in most studies was early 60's, with a range from age 20 to as high as 93. Given that 90% of patients with rectal cancer are over age 50, the patients in these studies may be somewhat younger than is typical.

We do have some concerns about applicability with respect to the interventions. Many older studies that may have used technology that is now obsolete. For example, some of the included older MRI studies utilized devices with very low strength magnets by today's standards. Although we concurred with our Technical Expert Panel (TEP) that it did not make sense to set an arbitrary date cut-off for including studies, we did not make an a priori decision about magnet strength for MRI examinations. In addition, ERUS is an operator-dependent test, which may have to be considered when deciding whether to apply our findings in specific settings.

The EPC Methods Guide for medical tests recommends considering the following categories of outcomes in the assessment of diagnostic and prognostic tests: clinical management; direct health effects; emotional, social, cognitive and behavioral responses; legal and ethical; costs.9 The majority of studies in this review reported only test performance outcomes. Only six studies reported changes in management based on test findings. We did not identify information on the impact of testing on emotional, social, cognitive and behavioral responses. We identified information on harms as a result of testing, but to do so, we conducted supplemental searches specifically focused on harms. We did not identify studies reporting health outcomes that resulted from treatment decisions guided by imaging test results.

We also note that most of the studies were set in university-based academic or teaching hospitals, which may limit the applicability of the results to community-based general hospitals. The majority (58%) of included primary studies were conducted in Europe, 27% in Asia and Australia, 6% in the Middle East and 9% in the United States. As we discuss in the next section, there are differences in utilization of imaging studies in the United States as compared to other countries, but we doubt that this would affect the applicability of the test performance results, assuming comparable imaging devices are utilized.

## Implications for Clinical and Policy Decisionmaking

The EPC that performed the topic-refinement phase of this project noted that some stakeholders expressed interest in patterns of care and access to imaging technology for colorectal staging. Therefore, although we did not search systematically for information on this topic, we obtained relevant articles identified through our searches. Recent (2009 or later) published articles were selected for discussion.

Fourteen articles addressed patterns of care for staging of rectal cancer,210-216 colon cancer,217,218 colorectal cancer,219-222 and metastases.223

The majority of the studies discussed using multiple imaging modalities for preoperative staging. Two studies focused only on MRI,216,221 whereas information on PET/CT was limited.213,223 Studies were conducted in Belgium,210 Brazil,214 Canada,220 Italy,213 the Netherlands,221-223 New Zealand,218 Poland,215Thailand,211 and the United States.217,219 One study was conducted in 173 U.S. and non-U.S. locations,212 and one study was conducted in Australia and New Zealand.216 See Appendix C for details.

To determine preoperative management of rectal cancer worldwide, Augestad et al.212 surveyed colorectal surgeons at 173 international colorectal cancer centers from 28 countries in Africa, Asia, Europe, North America, and South America. A majority of responders were located in university hospitals (78%) and had more than 11 years' experience with rectal cancer surgery (70%). Results from 123 (71%) respondents indicated significantly more U.S. surgeons use ERUS for all patients than do non-U.S. surgeons (43.6% vs. 21.1%, respectively; statistically significant); whereas significantly fewer U.S. surgeons use MRI for all patients than do non-U.S. surgeons (20.5% vs. 42.2%, respectively; statistically significant); and similar rates were found for use of CT for all patients (56.4% by U.S. surgeons vs. 53.5% by non-U.S. surgeons; not significant [NS]).212 The decision to use MRI was significantly influenced by multidisciplinary team meetings (relative risk [RR] 3.62, confidence interval 0.93 to 14.03; statistically significant). The authors speculated that low rates for MRI use (50% use in selected cases, 11% never use) may indicate the slow implementation of evidence-based medicine by colorectal surgeons.212

On a narrower geographic level, survey results from 108 members of the Colorectal Surgical Society of Australia & New Zealand indicated that 86.1 percent routinely used MRI preoperatively for suspected T2 rectal cancer, while 13.9 percent used it selectively for tumors in the lower two-thirds of the rectum.216 The study authors noted the need for closer compliance with evidence-based guidelines in managing locally advanced rectal cancer.216

Ninety percent of colorectal surgeons from multidisciplinary teams and advanced facilities surveyed in Thailand routinely used CT or MRI (rectal) while 7.5 percent routinely used ERUS (middle and lower rectal) for preoperative staging. Limited availability of ERUS was noted as the cause of limited use.211

Lastly, a review of records from 709 patients with rectal cancer (about 70% stage III/IV) treated from 2008 to 2009 in Poland indicated that preoperative staging was performed by CT (48.1%), ERUS (23.7%), and MRI (2.5%).215 Note that our review of the evidence indicates that CT is less accurate than ERUS for this use.

For interim staging of rectal cancer, studies conducted in Brazil214 and Belgium210 indicated that CT214 or contrast-enhanced CT210 were generally the first modality of choice. However, Brazilian surgeons and medical oncologists with more than 10 cases of rectal cancer per year preferred MRI or ERUS for local staging,214 whereas specialized centers in Belgium preferred ERUS.210 In Italy, ERUS (T1 and T2) and CT (T3 and T4) were chosen for distal rectal staging with single modalities, whereas CT and ERUS (T1 through T3) and CT and MRI (T4) were chosen for interim staging with combination modalities by members of the Italian Society of Surgery.213 No studies discussed patterns of interim staging for colon cancer.

Studies discussing patients with only colon cancer (i.e., not combined with patients with rectal cancer) were not identified for inclusion in our review. However, we did identify two studies that discussed patterns of care for colon cancer.217,218 O'Grady et al. of Fox Chase Cancer Center Partners217 reviewed records of 124 U.S. patients given a diagnosis of stage III colon cancer (between 2003 and 2006) to determine compliance with May 2006 National Comprehensive Cancer Network (NCCN) guidelines. Compliance of staging with NCCN guidelines was 98 percent. A population-based audit of the New Zealand Cancer Registry (642 patients)218 concluded that CT staging increased considerably from 1996 to 2003 (from 11% to 62%) while use of ultrasound remained stable.

Four studies focused on staging of colorectal cancer;219-222 one study focused on use of MRI only.221 In 2012, Levine et al.219 noted that a significantly higher proportion of 288 U.S. patients with colorectal cancer referred to a multidisciplinary colorectal tumor clinic than patients treated outside the clinic underwent preoperative evaluation (as recommended by NCCN guidelines) with abdominal CT (97.5% vs. 83.1%, respectively; statistically significant), chest CT (95% vs. 37.1%, respectively; p<0.0001) and ERUS for rectal cancer (88% vs. 37.7%, respectively; statistically significant). Results from a multivariate analysis of 392 patients in Nova Scotia, Canada220 indicated that the presence of a rectal tumor (RR 4.4, statistically significant), treatment in a community hospital (RR 1.9; statistically significant), and higher TNM staging (not statistically significant) were associated with undergoing preoperative imaging (53.1% ultimately did). Results also indicated that preoperative staging imaging (liver, pelvis), in turn, was associated with a reduced likelihood of meeting a 4-week benchmark from diagnosis-to-surgery (RR 1.0, not statistically significant). Factors such as length of waiting lists, inpatient bed availability, and mechanisms for preoperative assessment by anesthesia specialists may also have delayed surgical bookings between February 2002 and February 2004.^220^

Two population-based audits of cancer registries were conducted in the Netherlands (n=2,719).221,222 One study noted a statistically significant increase in use of MRI for preoperative staging from 2006 to 2008 for patients with rectal cancer (73% to 85%, statistically significant)221 The other study noted staging by abdominal ultrasound and thoracic radiography (colorectal) was being replaced by abdominal CT (colorectal) and pelvic CT or MRI (rectal) in 2005.^222^

To determine the modality of choice for evaluating metastases, Bipat et al.223 surveyed nuclear medicine physicists, abdominal surgeons, and abdominal radiologists in the Netherlands. CT was the dominant imaging modality for staging metastases (liver, lung, and extrahepatic) despite recommendations by Dutch guidelines to use CT or MRI as a first choice for liver staging. The three most common factors affecting choice of imaging modality by specialists (surgeons and medical oncologists) were evidence in the literature, availability, and expertise. The authors also noted that Dutch guidelines lagged U.S. guidelines, in which PET/CT plays a prominent role.223

For changes in patient management, Melotti et al. noted that 55.6 percent of Italian surgeons surveyed believe that ^18^F-fluorodeoxyglucose (FDG) PET/CT is incapable of modifying rectal staging either before or after chemoradiotherapy compared with other imaging modalities. This opinion, they indicate, differs from most international authors who conclude that “in 31-38 percent of patients FDG PET-CT modifies rectal staging and therefore treatment in 14-27 percent of cases.”213 No studies in our review evaluated the use of PET/CT for interim restaging of rectal cancer, but two studies that met the inclusion criteria reported the impact of adding PET/CT results to CT results for preoperative staging of colorectal cancer. The results of these studies indicate that the addition of PET/CT results did lead to changes in management, but these changes were appropriate in only half of the patients.

## Limitations of the Comparative Effectiveness Review Process

### Impact of Key Assumptions

The major assumption we made—that the reference standard was 100 percent accurate—is unlikely to actually be true. In most of the studies, the reference standard was intraoperative findings and histopathologic examination of tissues removed during surgery. This standard is probably close to being 100 percent accurate, but errors may occur at a low rate. For example, if a patient staged by MRI as having affected lymph nodes is staged by ERUS as not having affected lymph nodes, but has affected lymph nodes that are overlooked during surgery, ERUS would incorrectly be declared “correct.” Errors in the reference standard will, presumably, result in random “noise” in the estimates of comparative effectiveness, widening the confidence intervals around the estimates. We are unaware of any work that has been able to estimate the accuracy of intraoperative findings for staging colorectal cancer.

### Decisions Related to Project Scope

In an effort to keep the systematic review reasonable in scope, we elected to summarize previous systematic reviews to examine evidence on individual imaging tests used in staging evaluations compared to a reference standard. As recommended in the Methods Guide, we evaluated retrieved systematic reviews with a modified version of the AMSTAR checklist, and used the results to select higher quality systematic reviews for discussion. However, we recognize that the assessment is dependent on reporting quality, and may not completely reflect the quality of the actual systematic review. An updated review of the primary studies may yield different results from those reported in the separate systematic reviews.

## Limitations of the Evidence Base

Very few studies reported on any outcomes other than staging accuracy. Among studies reporting only accuracy outcomes, we rarely found complete cross-classifed data (i.e., numbers of patients correctly staged, understaged and overstaged for each stage for all modalities and the reference standard).209 Many of the studies that reported on staging accuracy were quite small and provided limited information on patient characteristics. In particular, the evidence base for Key Question 2, interim restaging, is very sparse even for staging accuracy outcomes.

A few studies reported on how imaging modalities affected patient management, but few of these reported whether management changes were deemed appropriate. No studies reported on patient-oriented outcomes such as survival and quality of life.

The development of a variety of treatment options for colorectal cancer, and particularly those for rectal cancer, such as local excision, sphincter-sparing surgery, total mesorectal excision, and neoadjuvant systemic treatment, has increased the importance of accurate preoperative staging. Decisions about appropriate treatment for each patient depend on the resectability of the tumor and the predicted risk of recurrence. A description of the anatomic spread of the tumor (e.g., its stage) is the most important factor in clinical decisionmaking.224 If a method of staging is truly accurate, this should be reflected in better decisionmaking, which should result in better patient outcomes. For example, Hartman et al. published a decision model in 2013 testing thresholds for determining node positivity by MRI for making adjuvant treatment decisions for stage T2 rectal cancer. The authors found that the model's determination of benefits of treatment was dependent on the accuracy of primary tumor staging.225

The optimal study design for measuring the impact of staging method on patient outcomes is a large randomized controlled trial with long-term followup. In the absence of such trials, modeling can be used to estimate the impact of various staging methods on patient outcomes. For example, Lejeune et al. created a decision model set in the French health care system.226 The model compared the use of CT with PET/CT in the management of metachronous liver metastases from colorectal cancer. The model predicted that using PET/CT instead of CT allowed 6.1 percent of patients to avoid exploratory surgery. There was no impact on overall survival, however.

## Research Gaps

For characterizing gaps, we used the Hopkins EPC framework proposed by Robinson et al. (2011).227 That system suggests that reviewers identify a set of important gaps and determine the most important reason for each gap. Each gap should be assigned one of the following reasons for the inability to draw conclusions:

- Insufficient or imprecise information: no studies, limited number of studies, sample sizes too small, estimate of effect is imprecise
- Information at risk of bias: inappropriate study design; major methodological limitations in studies
- Inconsistency or unknown consistency: consistency unknown (only 1 study); inconsistent results across studies
- Not the right information: results not applicable to population of interest; inadequate duration of interventions/comparisons; inadequate duration of followup; optimal/most important outcomes not addressed; results not applicable to setting of interest

The majority of the evidence gaps on the questions in this review fall into the category of insufficient information.

There is practically no literature on interim restaging of either colon or rectal cancer, and very few studies of staging of colon cancer; most of the literature identified was about rectal cancer. This likely reflects the relatively greater importance of clinical locoregional staging in rectal vs. colon cancer. Specifically, most studies of staging in colon cancer seemed to focus on looking for metastases, particularly to the liver.

Few studies examined the impact of combining different imaging modalities on pretreatment and interim staging assessments, which may provide more clinically relevant results than studies that examine the accuracy of one imaging modality in isolation. Given that patients often undergo multiple imaging studies for staging purposes, such information would be valuable.

Very few studies of PET/CT are available, which is a concern because, as noted above in “Patterns of Care,” many experts appear to believe its addition to staging leads to useful changes in management. Also, its use for primary and interim clinical staging of patients is on the rise, despite the lack of convincing evidence to support its widespread adoption. We identified one study of changes in management after addition of PET/CT that concluded that only half of the changes in management triggered by PET/CT were appropriate, suggesting that using PET/CT for staging may result in significant patient harm.19 Further study on this topic needs to be performed before any firm conclusions about the accuracy and clinical usefulness of PET/CT can be drawn.

“Not the right information” is another consideration. Insufficient information is available about changes in management triggered by imaging studies and about patient-oriented outcomes downstream of staging. Ideally, randomized controlled trials would be designed to test different staging and management strategies, capturing health outcomes that occur following treatment.

Studies of the impact of imaging on patient management decisions are potentially helpful and can be accomplished in shorter time frames than studies measuring health outcomes. However, it is critical to confirm whether the changes in management were appropriate. From the limited information in the studies in our review, it appears that such changes were not always appropriate.

## Conclusions

Low-strength evidence suggests ERUS is more accurate than CT for preoperative rectal cancer T staging, and MRI is similar in accuracy to ERUS. Moderate-strength evidence suggests MRI is more likely to detect colorectal liver metastases than CT. Insufficient evidence was available to allow us reach any evidence-based conclusions about the use of PET/CT for colorectal cancer staging. Low-strength evidence suggests that CT, MRI, and ERUS are comparable for rectal cancer N staging, but all are limited in sensitivity. Low strength evidence suggests that they are also comparable for interim rectal cancer T restaging, but both sensitivity and specificity are suboptimal. Long-range harm from radiation exposure with repeat examinations is particularly of concern with PET/CT.