# Analyses and Risk of Bias Assessments

## Preoperative Rectal T Staging

### CT Versus ERUS

Table D-1 Pooled random effects meta-analysis: CT versus ERUS for preoperative primary rectal T staging

Measure | Correct | Understaged | Overstaged
Summary OR | 0.359^a^ | 0.656 | 0.472
95% CI | 0.238 to 0.541 | 0.438 to 0.894 | 0.28 to 0.798
I^2^ | 67% | 0% | 50%
Favors | ERUS | ERUS | ERUS

a Odds ratio of getting an incorrect result

### MRI Versus ERUS

Table D-2 Bivariate model MRI versus ERUS for preoperative primary rectal T staging

Test Characteristics | MRI | ERUS
Sensitivity (95% CI) | 88.9% (79.0% to 94.4%) | 88.0% (80.0% to 93.1%)
Specificity (95% CI) | 85.3% (70.6% to 93.4%) | 85.6% (65.8% to 94.9%)
Diagnostic OR (95% CI) | 46.3 (17.8 to 120.4) | 43.6 (11.6% to 164.5%)
+ Likelihood ratio (95% CI) | 6.1 (2.9 to 12.6) | 6.1 (2.3 to 16.3)
- Likelihood ratio (95% CI) | 0.13 (0.069 to 0.25) | 0.14 (0.079 to 0.25)
Favors | No apparent difference | No apparent difference

Table D-3 Pooled random effects meta-analysis: MRI versus ERUS for preoperative primary rectal T staging

Measure | Correct | Understaged | Overstaged
Summary OR^a^ | 1.24 | 1.571 | 1.05
95% CI | 0.835 to 1.84 | 0.605 to 4.083 | 0.518 to 2.16
I^2^ | 24% | 64% | 42%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference

a OR of getting an incorrect result

Figure D-1 HSROC of MRI for preoperative primary rectal T staging

Figure D-1. This figure shows the hierarchical model fitted to the diagnostic data. Data points are shown in large open circles, the confidence intervals are shown as dotted lines encompassing an area of 95% confidence in the results, and the summary ROC curve is shown as a dark line, with the summary sensitivity and specificity shown as a dark box. The closer the dark box gets to the upper left hand corner, the closer to perfect the test is. In this figure, the dark box is very close to being in the middle of the graph, indicating a not very accurate test.

Figure D-2 HSROC of ERUS for preoperative primary rectal T staging

Figure D-2. This figure shows the hierarchical model fitted to the diagnostic data. Data points are shown in large open circles, the confidence intervals are shown as dotted lines encompassing an area of 95% confidence in the results, and the summary ROC curve is shown as a dark line, with the summary sensitivity and specificity shown as a dark box. The closer the dark box gets to the upper left hand corner, the closer to perfect the test is. In this figure, the dark box is close to the left hand side of the figure, indicating a highly specific test, but is very low down on the figure, indicating a not very sensitive test.

### MRI Versus CT

Table D-4 Pooled random effects meta-analysis: MRI versus CT for preoperative rectal T staging

Measure | Correct | Understaged | Overstaged
Summary OR | 0.317^a^ | 0.317 | 0.317
95% CI | 0.056 to 1.784 | 0.027 to 3.646 | 0.028 to 3.653
I^2^ | 0% | 0% | 0%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference I

a Odds ratio of an incorrect result

## Preoperative Rectal N Staging

### CT Versus ERUS

Table D-5 Bivariate model CT versus ERUS for preoperative primary rectal N staging

Test Characteristics | CT | ERUS
Sensitivity (95% CI) | 39.6% (28.1% to 52.4%) | 49.1% (34.9% to 63.5%)
Specificity (95% CI) | 93.2% (58.8% to 99.2%) | 71.7% (56.2% to 83.4%)
Diagnostic OR (95% CI) | 9.0 (1.17 to 69.11) | 2.45 (1.19 to 5.04)
+ Likelihood ratio (95% CI) | 5.8 (0.82 to 41.5) | 1.7 (1.1 to 2.8)
- Likelihood ratio (95% CI) | 0.65 (0.54 to 0.77) | 0.71 (0.53 to 0.94)
Favors | CT for specificity | ERUS for sensitivity

Figure D-3 HSROC of CT for preoperative primary rectal N staging

Figure D-3. This figure shows the hierarchical model fitted to the diagnostic data. Data points are shown in large open circles, the confidence intervals are shown as dotted lines encompassing an area of 95% confidence in the results, and the summary ROC curve is shown as a dark line, with the summary sensitivity and specificity shown as a dark box. The closer the dark box gets to the upper left hand corner, the closer to perfect the test is. In this figure, the dark box is fairly close to the upper left hand corner, indicating a fairly accurate test.

Figure D-4 HSROC of ERUS for preoperative primary rectal N staging

Figure D-4. This figure shows the heirarchical model fitted to the diagnostic data. Data points are shown in large open circles, the confidence intervals are shown as dotted lines encompassing an area of 95% confidence in the results, and the summary ROC curve is shown as a dark line, with the summary sensitivity and specificity shown as a dark box. The closer the dark box gets to the upper left hand corner, the closer to perfect the test is. In this figure, the dark box is fairly close to the upper left hand corner, indicating a fairly accurate test.

Table D-6 Pooled random effects meta-analysis: CT versus ERUS for preoperative primary rectal N staging

Measure | Correct | Understaged | Overstaged
Summary OR | 1.13^a^ | 1.453 | 1.015
95% CI | 0.85 to 1.503 | 0.854 to 2.473 | 0.571 to 1.801
I^2^ | 29% | 67% | 57%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference

a Odds ratio of getting an incorrect result

### MRI Versus ERUS

Table D-7 Bivariate model MRI versus ERUS for preoperative primary rectal N staging

Test Characteristics | MRI | ERUS
Sensitivity (95% CI) | 49.5% (36.0% to 63.1%) | 63.7% (51.0% to 74.8%)
Specificity (95% CI) | 69.7% (51.9% to 83.0%) | 75.9% (46.1% to 92.1%)
Diagnostic OR (95% CI) | 2.3 (0.73 to 6.9) | 5.5 (1.5 to 19.9)
+ Likelihood ratio (95% CI) | 1.6 (0.81 to 3.3) | 2.6 (1.0 to 6.9)
- Likelihood ratio (95% CI) | 0.72 (0.47 to 1.1) | 0.48 (0.32 to 0.71)
Favors | ERUS | ERUS

Figure D-5 HSROC of MRI for preoperative primary rectal N staging

Figure D-5. This figure shows the heirarchical model fitted to the diagnostic data. Data points are shown in large open circles, the confidence intervals are shown as dotted lines encompassing an area of 95% confidence in the results, and the summary ROC curve is shown as a dark line, with the summary sensitivity and specificity shown as a dark box. The closer the dark box gets to the upper left hand corner, the closer to perfect the test is. In this figure, the dark box is very close to being in the middle of the graph, indicating a not very accurate test.

Figure D-6 HSROC of ERUS for preoperative primary rectal N staging

Figure D-6. This figure shows the hierarchical model fitted to the diagnostic data. Data points are shown in large open circles, the confidence intervals are shown as dotted lines encompassing an area of 95% confidence in the results, and the summary ROC curve is shown as a dark line, with the summary sensitivity and specificity shown as a dark box. The closer the dark box gets to the upper left hand corner, the closer to perfect the test is. In this figure, the dark box is very close to being in the middle of the graph, indicating a not very accurate test.

Table D-8 Pooled random effects meta-analysis: MRI versus ERUS for preoperative primary rectal N staging

Measure | Correct | Understaged | Overstaged
Summary odds ratio | 0.882^a^ | 0.972 | 0.752
95% CI | 0.542 to 1.408 | 0.563 to 1.679 | 0.457 to 1.237
I^2^ | 51% | 42% | 14%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference

a Odds ratio of getting an incorrect result

## Change in Management

### MRI Versus ERUS

Table D-9 Pooled random effects meta-analysis: MRI versus ERUS for preoperative primary rectal staging changes in management

Measure | Correct | Undertreated | Overtreated
Summary OR | 0.326^a^ | 0.396 | 0.203
95% CI | 0.052 to 2.045 | 0.129 to 1.216 | 0.011 to 3.847
I^2^ | 95% | 59% | 85%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference

a Odds ratio of getting an incorrect result

### CT Versus MRI

Table D-10 Pooled random effects meta-analysis: CT versus MRI for preoperative rectal N staging

Measure | Correct | Understaged | Overstaged
Summary OR | 1.023^a^ | 0.573 | 2.0
95% CI | 0.465 to 2.245 | 0.338 to 0.973 | 1.233 to 3.229
I^2^ | 73% | 0% | 0%
Favors | No statistically significant difference | CT | MRI

a OR of an incorrect result; OR < 1 indicates lower risk of error on CT; OR > 1 indicates higher risk of error on CT.

## Preoperative Rectal M Staging

### MRI Versus CT

Table D-11 Pooled random effects meta-analysis: MRI versus CT for preoperative colorectal M staging (per lesion)

Measure | Lesion Detection Rate
Summary OR^a^ | 1.334
95% CI | 1.012 to 1.761
I^2^ | 36%
Favors | MRI

a OR of detecting metastases

## Rectal M Restaging

### MRI Versus CT

Table D-12 Pooled random effects meta-analysis: MRI versus CT for interim colorectal M restaging (per lesion)

Measure | Lesion Detection Rate
Summary OR^a^ | 0.397
95% CI | 0.111 to 1.418
I^2^ | 85%
Favors | No statistically significant difference

a OR of getting an incorrect result

## Colorectal M Staging

### CT Versus PET/CT

Table D-13 Pooled data: CT versus PET/CT for preoperative colorectal M staging (per lesion)

Test Characteristics | CT | PET/CT
Sensitivity (95% CI) | 83.6% (78.1% to 88.2%) | 60.4% (53.7% to 66.9%)
I^2^ | 0.0% | 95.1%
Specificity (95% CI) | Not calculated | Not calculated
Favors | Insufficient | Insufficient

## Interim Rectal T Restaging

### MRI Versus CT Versus ERUS

Table D-14 Pooled random effects meta-analysis: MRI versus CT versus ERUS for interim rectal T restaging

Measure | Accuracy MRI Versus CT | Accuracy MRI Versus ERUS | Accuracy CT Versus ERUS
Summary OR^a^ | 0.943 | 0.948 | 0.907
95% CI | 0.652 to 1.34 | 0.471 to 1.907 | 0.41 to 2.011
I^2^ | 0% | 67% | 74%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference

a Odds ratio of getting an inaccurate result

## Interim Rectal N Restaging

### MRI Versus CT Versus ERUS

Table D-15 Pooled random effects meta-analysis: MRI versus CT versus ERUS for interim rectal N restaging

Measure | Accuracy MRI Versus CT | Accuracy MRI Versus ERUS | Accuracy CT Versus ERUS
Summary OR^a^ | 0.874 | 1.457 | 1.531
95% CI | 0.609 to 1.253 | 0.487 to 4.362 | 0.727 to 3.224
I^2^ | 0% | 86% | 70%
Favors | No statistically significant difference | No statistically significant difference | No statistically significant difference

a Odds ratio of getting an inaccurate result

## Publication Bias

Figure D-7 Funnel plot of CT versus ERUS, accuracy of rectal T staging

Figure D-7. This figure shows a funnel plot of the data. The effect size (log odds ratio) is shown on the x-axis, with larger effect sizes to the right, and the standard error of the study is shown on the y-axis, with larger errors to the top. The data points are shown as open circles, scattered around the summary effect size. The symmetrical scattering pattern seen in this figure suggests there is no publication bias.

Figure D-8 Effect size by publication date, CT versus ERUS, accuracy of rectal T staging

Figure D-8. This figure shows a regression of study date (of publication) on effect size. Study date is shown on the x-axis, and effect size on the y-axis. The regression line is almost flat across the graph, suggesting that there has not been a systematic change in effect size reported over the years.

Figure D-9 Funnel plot of MRI versus ERUS, accuracy of rectal T staging

Figure D-9. This figure shows a funnel plot of the data. The effect size (log odds ratio) is shown on the x-axis, with larger effect sizes to the right, and the standard error of the study is shown on the y-axis, with larger errors to the top. The data points are shown as open circles, scattered around the summary effect size. The symmetrical scattering pattern seen in this figure suggests there is no publication bias.

Figure D-10 Effect size by publication date, MRI versus ERUS, accuracy of rectal T staging

Figure D-10. This figure shows a regression of study date (of publication) on effect size. Study date is shown on the x-axis, and effect size on the y-axis. There is a slight downward slope of the line over time, suggesting a possible systematic change (reduction) in effect size over time, but there are only 6 data points (shown as open circles), so this may simply be a coincidence.

## Sensitivity Analyses on External Correlations

Table D-16 Sensitivity analyses using different test-test correlations

Timing | Rectal or Colorectal | Type of Staging | Comparison | Primary Analysis using correlation=0.5 (Summary OR and 95% Confidence Interval) | Sensitivity Analysis using correlation=0.1 (Summary OR and 95% Confidence Interval) | Sensitivity Analysis using correlation=0.9 (Summary OR and 95% Confidence Interval) | Important Change Upon Sensitivity Analysis? | Nature of the Change
Pretreatment | Rectal | T stage | MRI vs. ERUS | 1.24 (0.835 to 1.84) | 1.22 (0.78 to 1.93) | 1.30 (0.89 to 1.89) | No | NA
Pretreatment | Rectal | T stage | MRI vs. ERUS | 1.571 (0.605 to 4.083) | 1.605 (0.605 to 4.255) | 1.342 (0.477 to 3.774) | No | NA
Pretreatment | Rectal | T stage | MRI vs. ERUS | 1.05 (0.518 to 2.16) | 0.992 (0.498 to 1.976) | 1.149 (0.481 to 2.747) | No | NA
Pretreatment | Rectal | T stage | ERUS vs. CT | 0.359 (0.238 to 0.541) | 0.376 (0.250 to 0.566) | 0.322 (0.215 to 0.482) | No | NA
Pretreatment | Rectal | T stage | ERUS vs. CT | 0.626 (0.438 to 0.894) | 0.619 (0.386 to 0.993) | 0.621 (0.451 to 0.855) | No | NA
Pretreatment | Rectal | T stage | ERUS vs. CT | 0.472 (0.28 to 0.798) | 0.487 (0.29 to 0.817) | 0.465 (0.292 to 0.739) | No | NA
Pretreatment | Rectal | T stage | MRI vs. CT | 0.317 (0.056 to 1.784) | 0.317 (0.035 to 2.867) | 0.317 (0.11 to 0.914) | Yes | Became statistically significant if a correlation of 0.9 was used
Pretreatment | Rectal | T stage | MRI vs. CT | 0.317 (0.027 to 3.646) | 0.317 (0.014 to 7.139) | 0.317 (0.071 to 1.413) | No | NA
Pretreatment | Rectal | T stage | MRI vs. CT | 0.318 (0.028 to 3.653) | 0.318 (0.014 to 7.135) | 0.318 (0.071 to 1.421) | No | NA
Pretreatment | Rectal | N stage | MRI vs. ERUS | 0.882 (0.542 to 1.408) | 0.853 (0.537 to 1.357) | 0.915 (0.584 to 1.435) | No | NA
Pretreatment | Rectal | N stage | MRI vs. ERUS | 0.972 (0.563 to 1.679) | 1.011 (0.591 to 1.727) | 0.932 (0.557 to 1.561) | No | NA
Pretreatment | Rectal | N stage | MRI vs. ERUS | 0.752 (0.457 to 1.237) | 0.743 (0.409 to 1.349) | 0.809 (0.504 to 1.296) | No | NA
Pretreatment | Rectal | N stage | ERUS vs. CT | 1.13 (0.85 to 1.503) | 1.11 (0.826 to 1.504) | 1.2 (0.923 to 1.548) | No | NA
Pretreatment | Rectal | N stage | ERUS vs. CT | 1.453 (0.854 to 2.473) | 1.369 (0.803 to 2.332) | 1.561 (0.959 to 2.542) | No | NA
Pretreatment | Rectal | N stage | ERUS vs. CT | 1.015 (0.571 to 1.801) | 1.013 (0.548 to 1.872) | 1.092 (0.718 to 1.66) | No | NA
Pretreatment Accuracy | Rectal | N stage | MRI vs. CT | 1.316 (0.709 to 2.243) | 1.379 (0.752 to 2.529) | 1.256 (0.680 to 2.322) | No | NA
Pretreatment Understaging | Rectal | N stage | MRI vs. CT | 1.743 (1.028 to 2.957) | 1.743 (0.859 to 1.538) | 1.585 (0.958 to 2.625) | Yes | Became non-statistically significant if either correlation of 0.1 or 0.9 were used or if Hodgman study removed (0.15T magnet)
Pretreatment Overstaging | Rectal | N stage | MRI vs. CT | 0.498 (0.308 to 0.806) | 0.498 (0.262 to 0.947) | 0.499 (0.399 to 0.625) | No | NA
Pretreatment | Colorectal | Detection of metastases | MRI vs. CT | 1.334 (1.012 to 1.761) | 1.349 (1.023 to 1.778) | 1.331 (1.012 to 1.749) | No | NA
Restaging | Rectal | T stage | CT vs. MRI | 0.943 (0.652 to 1.34) | 0.934 (0.576 to 1.516) | 0.934 (0.795 to 1.098) | No | NA
Restaging | Rectal | T stage | CT vs. ERUS | 0.907 (0.410 to 2.011) | 0.879 (0.400 to 1.931) | 0.937 (0.421 to 2.085) | No | NA
Restaging | Rectal | T stage | MRI vs. ERUS | 0.948 (0.471 to 1.907) | 0.914 (0.460 to 1.817) | 0.983 (0.486 to 1.988) | No | NA
Restaging | Rectal | N stage | MRI vs. CT | 0.874 (0.609 to 1.253) | 0.874 (0.538 to 1.418) | 0.919 (0.651 to 1.298) | No | NA
Restaging | Rectal | N stage | CT vs. ERUS | 1.531 (0.727 to 3.224) | 1.469 (0.709 to 3.045) | 1.596 (0.753 to 3.384) | No | NA
Restaging | Rectal | N stage | MRI vs. ERUS | 1.457 (0.487 to 4.362) | 1.418 (0.476 to 4.225) | 1.497 (0.499 to 4.493) | No | NA
Restaging | Colorectal | Detection of metastases | CT vs. MRI | 0.397 (0.111 to 1.418) | 0.402 (0.104 to 1.551) | 0.409 (0.157 to 1.062) | No | NA
Treatment selection | Rectal | Correct treatment | MRI vs. ERUS | 0.326 (0.052 to 2.045) | 0.324 (0.052 to 2.032) | 0.329 (0.052 to 2.058) | No | NA
Treatment selection | Rectal | Correct treatment | MRI vs. ERUS | 0.396 (0.129 to 1.216) | 0.341 (0.128 to 0.91) | 0.46 (0.142 to 1.489) | Yes , but no change to conclusion | Became statistically significant if a correlation of 0.1 was used
Treatment selection | Rectal | Correct treatment | MRI vs. ERUS | 0.203 (0.011 to 3.847) | 0.196 (0.01 to 3.721) | 0.21 (0.11 to 3.97) | No | NA

ERUS=endorectal ultrasound; MRI=magnetic resonance imaging; NR=not reported; pT=pathologic tumor stage; T=tumor stage.

## Risk of Bias of Individual Studies

### ECRI Instrument for Controlled/Comparative Studies

1. Were patients randomly assigned to the study's groups?
2. Did the study use appropriate randomization methods?
3. Was there concealment of group allocation?
4. For nonrandomized trials, did the study employ any other methods to enhance group comparability?
5. Was the process of assigning patients to groups made independently from physician and patient preference?
6. Did the patients in different study groups have similar levels of performance on the outcome of interest at the time they were assigned to groups?
7. Were the study groups comparable for all other important factors at the time they were assigned to groups?
8. Did the study enroll all suitable patients or consecutive suitable patients?
9. Was the comparison of interest prospectively planned?
10. If the patients received ancillary treatment(s), was there a ≤5 percent difference between groups in the proportion of patients receiving each specific ancillary treatment?
11. Were the two groups treated concurrently?
12. Was compliance with treatment ≥85 percent in both of the study's groups?
13. Were patients blinded to the treatment they received?
14. Was the healthcare provider blinded to the groups to which the patients were assigned?
15. Were those who assessed the patient's outcomes blinded to the group to which the patients were assigned?
16. Was the integrity of blinding of patients, physicians, or outcome assessors tested and found to be preserved?
17. Was the outcome measure of interest objective and was it objectively measured?
18. Was a standard instrument used to measure the outcome?
19. Was there ≤15 percent difference in the length of followup for the two groups?
20. Did ≥85 percent of the patients complete the study?
21. Was there a ≤15 percent difference in completion rates in the study's groups?
22. Was the funding for this study derived from a source that would not benefit financially from results in a particular direction?

Table D-17 Risk of bias of individual studies with two or more groups

Study | 1. RCT? | 2. Appropriate RCT? | 3. Concealment? | 4. Group comparability? | 5. Group assignment? | 6. Groups similar on outcome? | 7. Groups similar? | 8. All/consecutive enrollment? | 9. Prospective? | 10. Ancillary treatments? | 11. Concurrent? | 12. Compliance? | 13. Patients blinded? | 14. Provider blinded? | 15. Assessor blinded? | 16. Blinding tested? | 17. Objective? | 18. Standard? | 19. Followup? | 20. Completion? | 21. Attrition? | 22. Funding? | Risk of Bias
Yimei et al. 2012^93^ | No | No | No | No | No | NR | Yes | Yes | No | Yes | Yes | Yes | No | No | No | No | No | Yes | Yes | Yes | Yes | Yes | Moderate
Mo et al. 2002^165^ | No | No | No | No | NR | No | No | Yes | Yes | Yes | Yes | Yes | No | No | NR | NR | No | Yes | Yes | Yes | Yes | NR | High
Lupo et al. 1996^190^ | No | No | No | No | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | No | No | Yes | No | No | Yes | Yes | Yes | Yes | NR | Moderate

### Instrument for Single-Group Diagnostic Test Performance Studies

1. Did the study enroll all, consecutive, or a random sample of patients?
2. Were more than 85 percent of the approached/eligible patients enrolled?
3. Were the patient inclusion and exclusion criteria applied consistently to all patients?
4. Was the study affected by obvious spectrum bias?
5. Did the study account for inter-reader differences?
6. Were readers of the diagnostic test of interest blinded to the results of the reference standard?
7. Were readers of the reference standard blinded to the results of the diagnostic test of interest?
8. Were readers of the diagnostic test of interest blinded to all other clinical information?
9. Were readers of the reference standard blinded to all other clinical information?
10. Were patients assessed by a reference standard regardless of the test's results?
11. Were all patients assessed by the same reference standard regardless of the test's results?
12. If the study reported data for a single diagnostic threshold, was the threshold chosen a priori?
13. Were the study results unaffected by intervening treatments or disease progression/regression?
14. Were at least 85 percent of the enrolled patients accounted for?
15. Was the funding for the study derived from a source that does not have a financial interest in its results?

Table D-18 Risk of bias of individual studies: single-group studies

Study | 1. All/consecutive enrollment? | 2. 85% enrolled? | 3. Consistent inclusion? | 4. No spectrum bias? | 5. Inter-reader difference? | 6. Reader blinded standard? | 7. Reader standard blinded test? | 8. Reader blinded clinical? | 9. Reader standard blinded clinical? | 10. All standard? | 11. Same standard? | 12. Threshold? | 13. Intervening treatment? | 14. Attrition? | 15. Funding? | Risk of Bias
Halefoglu et al. 2008^94^ | Yes | Yes | Yes | Yes | No | Yes | NR | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Rafaelsen et al. 2008^188^ | Yes | Yes | Yes | Yes | Yes | No | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Bianchi et al. 2005^95^ | Yes | Yes | Yes | No | No | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Brown et al. 2004^125^ | Yes | NR | Yes | No | No | NR | NR | NR | NR | Yes | No | Yes | No | Yes | Yes | Moderate
Starck et al. 1995^96^ | Yes | NR | NR | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | Yes | NR | Moderate
Thaler et al. 1994^97^ | Yes | Yes | Yes | Yes | No | Yes | No | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Waizer et al. 1991^98^ | NR | NR | Yes | No | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Berger-Kulemann et al. 2012^200^ | Yes | Yes | Yes | No | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Kulemann et al. 2011^201^ | Yes | Yes | Yes | No | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Yes | NR | Moderate
van Kessel et al. 2011^202^ | No | NR | NR | Yes | Yes | Yes | No | No | No | Yes | No | Yes | NR | Yes | NR | Moderate
Taylor et al. 2007^119^ | Yes | Yes | Yes | No | No | Yes | Yes | NR | NR | Yes | Yes | Yes | NR | Yes | NR | Moderate
Arii et al. 2006^117^ | Yes | Yes | Yes | Yes | Yes | No | NR | NR | NR | Yes | No | Yes | Yes | Yes | Yes | Moderate
Bartolozzi et al. 2004^120^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes | Yes | NR | Yes | NR | Low
Bhattacharjya et al. 2004^121^ | Yes | Yes | Yes | Yes | No | NR | Yes | Yes | NR | Yes | No | Yes | No | Yes | NR | Moderate
Bohm et al. 2004^122^ | Yes | NR | Yes | No | NR | NR | NR | NR | NR | Yes | No | Yes | NR | Yes | NR | Moderate
Matsuoka et al. 2003^112^ | NR | NR | NR | Yes | NR | NR | NR | Yes | NR | Yes | Yes | Yes | NR | Yes | NR | Moderate
Blomqvist et al. 2002^115^ | Yes | NR | NR | No | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | No | Yes | Yes | Moderate
Lencioni et al. 1998^123^ | Yes | Yes | Yes | Yes | NR | Yes | NR | No | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Strotzer et al. 1997^124^ | Yes | Yes | Yes | Yes | Yes | Yes | NR | Yes | NR | Yes | Yes | Yes | NR | Yes | NR | Low
Guinet et al. 1990^113^ | NR | NR | Yes | No | No | Yes | NR | NR | NR | Yes | Yes | Yes | NR | Yes | NR | Moderate
Hodgman et al. 1986^114^ | No | NR | Yes | No | NR | Yes | No | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Wickramasinghe and Samarasekera 2012^126^ | Yes | Yes | Yes | Yes | No | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Ju et al. 2009^99^ | NR | NR | NR | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Huh et al. 2008^164^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Yes | NR | Low
Harewood et al. 2002^127^ | Yes | NR | Yes | Yes | No | Yes | No | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Kim et al. 1999^100^ | Yes | Yes | Yes | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Osti et al. 1997^101^ | NR | NR | NR | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Ramana et al. 1997^102^ | NR | NR | Yes | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Fleshman et al. 1992^116^ | NR | NR | Yes | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | No | Yes | NR | Moderate
Milsom et al. 1992^118^ | Yes | Yes | Yes | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Goldman et al. 1991^103^ | NR | NR | NR | Yes | No | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Pappalardo et al. 1990^104^ | Yes | Yes | Yes | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Rotte et al. 1989^105^ | NR | NR | NR | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Waizer et al. 1989^106^ | NR | NR | NR | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Beynon et al. 1986^107^ | NR | NR | NR | Yes | No | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Kramann and Hildebrandt 1986^108^ | NR | NR | NR | Yes | No | Yes | No | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Rifkin and Wechsler 1986^109^ | NR | NR | NR | Yes | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Rifkin and Marks 1986^110^ | NR | NR | NR | Yes | NR | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Romano et al. 1985^111^ | NR | NR | NR | Yes | NR | NR | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Engledow et al. 2012^128^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NR | NR | No | No | Yes | Yes | Yes | Yes | Moderate
Uchiyama et al. 2012^89^ | Yes | NR | NR | No | No | NR | No | NR | NR | Yes | Yes | Yes | NR | Yes | NR | Moderate
Ramos et al. 2011^19^ | Yes | Yes | Yes | Yes | No | Yes | NR | NR | No | Yes | No | Yes | NR | Yes | Yes | Moderate
Orlacchio et al. 2009^90^ | Yes | NR | NR | NR | No | Yes | NR | NR | NR | Yes | No | Yes | NR | Yes | NR | Moderate
Lubezky et al. 2007^91^ | Yes | Yes | NR | Yes | Yes | NR | NR | NR | NR | Yes | No | Yes | No | Yes | NR | Moderate
Kim et al. 2011^88^ | Yes | NR | NR | NR | No | NR | NR | NR | NR | Yes | NR | Yes | Yes | Yes | Yes | Moderate
Martellucci et al. 2012^199^ | Yes | Yes | Yes | Yes | No | Yes | NR | NR | NR | Yes | Yes | Yes | No | Yes | NR | Moderate
Pomerri et al. 2011^163^ | Yes | NR | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | No | Yes | Yes | Low
Barbaro et al. 1995^92^ | NR | NR | NR | No | NR | NR | NR | NR | NR | Yes | Yes | Yes | NR | Yes | NR | Moderate
Kim et al. 2004^186^ | Yes | No | Yes | Yes | Yes | No | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Hunerbein et al. 2000^187^ | Yes | Yes | Yes | Yes | No | No | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Wicherts et al. 2011^191^ | Yes | No | Yes | Yes | Yes | Yes | No | No | NR | Yes | Yes | Yes | No | Yes | NR | Moderate
Skriver et al. 1992^189^ | NR | NR | NR | Yes | NR | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Koh et al. 2012^192^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | No | Yes | No | Yes | Yes | Low
Lambregts et al. 2011^203^ | Yes | No | Yes | Yes | Yes | Yes | No | NR | NR | Yes | Yes | Yes | No | Yes | NR | Moderate
Jao et al. 2010^193^ | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Kim et al. 2010^229^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | Yes | Low
Futterer et al. 2008^197^ | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate
Vliegen et al. 2005^194^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Low
Kim et al. 2004^196^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | Yes | Low
Okizuka et al. 1996^195^ | Yes | NR | NR | Yes | Yes | No | Yes | NR | NR | Yes | Yes | Yes | Yes | Yes | NR | Moderate