# Evidence Tables

## Systematic Reviews

Table C-1 Included systematic reviews: design

Table C-2 Included systematic reviews: results

Table C-3 Included systematic reviews: quality assessment

## CT Versus ERUS

Table C-4 Study design: CT versus ERUS

Table C-5 Patient details: CT versus ERUS

Table C-6 Imaging details: CT versus ERUS

Table C-7 Reported data: CT versus ERUS for preoperative primary rectal staging T

Table C-8 Reported data: CT versus ERUS for rectal staging N

Table C-9 Reported data: CT versus ERUS for rectal staging with intervening radiation therapy

Table C-10 Reported data: CT versus ERUS for preoperative primary rectal staging changes in management

Table C-11 Reported data: CT versus ERUS for preoperative recurrent rectal staging

Table C-12 Reported data: CT versus ERUS for preoperative interim rectal restaging

Table C-13 Reported data: factors affecting CT versus ERUS for preoperative interim rectal restaging

## MRI Versus ERUS

Table C-14 Study design: MRI versus ERUS

Table C-15 Patient details: MRI versus ERUS

Table C-16 Imaging details: MRI versus ERUS

Table C-17a Reported data: MRI versus ERUS for rectal staging T

Table C-17b Reported data: MRI versus ERUS for rectal staging T

Table C-18a Reported data: MRI versus ERUS for rectal staging N

Table C-18b Reported data: MRI versus ERUS for rectal staging N

Table C-19 Reported data: MRI versus ERUS for preoperative primary rectal staging changes in management

Table C-20 Reported data: factors affecting MRI versus ERUS for preoperative rectal staging

## MRI Versus PET/CT

Table C-21 Study design: MRI versus PET/CT

Table C-22 Patient details: MRI versus PET/CT

Table C-23 Imaging details: MRI versus PET/CT

Table C-24 Reported data: MRI versus PET/CT for rectal staging N

## PET/CT Versus MRI Plus CT

Table C-25 Study design: PET/CT versus MRI+CT

Table C-26 Patient details: PET/CT versus MRI+CT

Table C-27 Imaging details: PET/CT versus MRI+CT

Table C-28 Reported data: PET/CT versus MRI+CT for preoperative primary rectal staging changes in management

## PET/CT Versus CT

Table C-29 Study design: CT versus PET/CT

Table C-30 Patient details: PET/CT versus CT

Table C-31 Imaging details: PET/CT versus CT

Table C-32 Reported data: CT versus PET/CT for colorectal staging T

Table C-33 Reported data: CT versus PET/CT for colorectal staging N

Table C-34 Reported data: CT versus PET/CT for colorectal staging M

Table C-35 Reported data: CT versus PET/CT for interim colorectal restaging M

Table C-36 Reported data: CT versus PET/CT for preoperative colorectal staging changes in management

## MRI Versus CT

Table C-37 Study design: MRI versus CT

Table C-38 Patient details: MRI versus CT

Table C-39 Imaging details: MRI versus CT

Table C-40 Reported data: CT versus MRI for preoperative rectal staging T

Table C-41a Reported data: CT versus MRI for preoperative rectal staging N

Table C-41b Reported data: CT versus MRI for preoperative rectal staging N

Table C-42 Reported data: CT versus MRI for preoperative rectal staging CRM status

Table C-43 Reported data: CT versus MRI for pre-radiochemotherapy rectal staging T

Table C-44 Reported data: CT versus MRI for interim rectal restaging T

Table C-45 Reported data: CT versus MRI for colorectal staging M

Table C-46 Reported data: CT versus MRI for interim colorectal restaging M

## CT Versus MRI Versus ERUS

Table C-47 Study design: CT versus MRI versus ERUS

Table C-48 Patient details: CT versus MRI versus ERUS

Table C-49 Imaging details: MRI versus CT versus ERUS

Table C-50 Reported data: CT versus MRI versus ERUS rectal cancer staging T

Table C-51 Reported data: CT versus MRI versus ERUS interim rectal restaging T

Table C-52 Reported data: CT versus MRI versus ERUS interim rectal restaging N

Table C-53 Reported data: CT versus MRI versus ERUS interim rectal restaging CRM status

## Factors Affecting Individual Modalities

### Endorectal Ultrasound

Table C-54 Study design: factors affecting ERUS accuracy

Table C-55 Patient details: ERUS factors

Table C-56 Imaging details: ERUS factors

Table C-57 Reported data: factors affecting ERUS for preoperative colorectal staging

### Computed Tomography

Table C-58 Study design: factors affecting CT accuracy

Table C-59 Patient details: CT factors

Table C-60 Reported data: factors affecting CT for preoperative colorectal staging

### Magnetic Resonance Imaging

Table C-61 Study design: factors affecting MRI accuracy

Table C-62 Patient details: MRI factors

Table C-63 Imaging details: MRI factors

Table C-64 Reported data: factors affecting MRI for colorectal staging

## Harms, Device Failure, and Adverse Events

Table C-65 Adverse events reported by included studies from CT, ERUS, and MRI staging

Table C-66 Device failures

Table C-67 MRI-related adverse events

Table C-68 CT-related adverse events

Table C-69 PET/CT-related adverse events

Table C-70 Physical and chemical characteristics of all currently marketed Gadolinium agents for MRI

## Patterns of Care

Table C-71 Patterns of care for colorectal patients worldwide