# Excluded Studies

## Systematic Review Inclusion Criteria

### Not a Systematic Review

Bipat S, Zwinderman AH, Bossuyt PM, et al. Multivariate random-effects approach: for meta-analysis of cancer staging studies. Acad Radiol. Aug. 2007;14(8):974-84. [pmid: 17659244].
Dedemadi G, Wexner SD. Complete response after neoadjuvant therapy in rectal cancer: to operate or not to operate. Dig Dis. Suppl 2. 2012;30:109-17. [pmid: 23207942].
Hartman RI, Chang CY, Wo JY, et al. Optimizing adjuvant treatment decisions for stage T2 rectal cancer based on mesorectal node size. A decision analysis. Acad Radiol. Jan. 2013;20(1):79-89. [pmid: 22947271].
Heriot AG, Grundy A, Kumar D. Preoperative staging of rectal carcinoma. Br J Surg. Jan. 1999;86(1):17-28. [pmid: 10027354].
Lejeune C, Bismuth MJ, Conroy T, et al. Use of a decision analysis model to assess the cost-effectiveness of 18F-FDG PET in the management of metachronous liver metastases of colorectal cancer. J Nucl Med. Dec. 2005;46(12):2020-8. [pmid: 16330566].
Sautter-Bihl ML, Hohenberger W, Fietkau R, et al. MRI-based treatment of rectal cancer: is prognostication of the recurrence risk solid enough to render radiation redundant?. Ann Surg Oncol. 2013. Sept. 4. Epub ahead of Print.

### Not High Quality

Leufkens AM, van den Bosch MA, van Leeuwen MS, et al. Diagnostic accuracy of computed tomography for colon cancer staging: a systematic review. Scand J Gastroenterol. Jul. 2011;46(7-8):887-94. [pmid: 21504379].
Parnaby CN, Bailey W, Balasingam A, et al. Pulmonary staging in colorectal cancer: a review. Colorectal Dis. Jun. 2012;14(6):660-70. [pmid: 21689294].
Puli SR, Bechtold ML, Reddy JB, et al. Can endoscopic ultrasound predict early rectal cancers that can be resected endoscopically? A meta-analysis and systematic review. Dig Dis Sci. May. 2010;55(5):1221-9. [pmid: 19517233].
van der Parrdt MP, Zagers MB, Beets-Tan RGH, et al. Patients who undergo preoperative chemoradiotherapy for locally advanced rectal cancer restaging by using diagnostic MR imaging: a systematic review and meta-analysis. Radiology. Oct. 2013;269(1):101-12. [pmid: 23801777].
Vriens D, de Geus-Oei LF, van der Graaf WT, et al. Tailoring therapy in colorectal cancer by PET-CT. Q J Nucl Med Mol Imaging. Apr. 2009;53(2):224-44. [pmid: 19293770].

### Patients Not Diagnosed With Cancer Before Enrollment

Brush J, Boyd K, Chappell F, et al. The value of FDG positron emission tomography/computerised tomography (PET/CT) in pre-operative staging of colorectal cancer: a systematic review and economic evaluation. Health Technol Assess. Sep. 2011;15(35):1-192. iii. iv. [pmid: 21958472].

### Not Reporting Staging Outcomes

Nordholm-Carstensen A, Wille-Jorgensen PA, Jorgensen LN, et al. Indeterminate pulmonary nodules at colorectal staging: a systematic review of predictive parameters for malignancy. Ann Surg Oncol. Nov. 2013;20(12):4022-30. [pmid: 23812771].

### Mixed Types of Cancer, Colorectal Not Reported Separately

Gao G, Gong B, Shen W. Meta-analysis of the additional value of integrated ^18^FDG PET-CT for tumor distant metastasis staging: comparison with ^18^FDG PET alone and CT alone. Surg Oncol. Sept. 2013;22(3):195-200. [pmid: 23886614].

### Published Prior to 2009

Bipat S, Glas AS, Slors FJ, et al. Rectal cancer: local staging and assessment of lymph node involvement with endoluminal US, CT, and MR imaging--a meta-analysis. Radiology. Sep. 2004;232(3):773-83. [pmid: 15273331].
Facey K, Bradbury I, Laking G, et al. Overview of the clinical effectiveness of positron emission tomography imaging in selected cancers. Health Technol Assess. Oct. 2007;11(44):iii-iv. [pmid: 17999839].
Harewood GC. Assessment of publication bias in the reporting of EUS performance in staging rectal cancer. Am J Gastroenterol. Apr. 2005;100(4):808-16. [pmid: 15784023].
Kwok H, Bissett IP, Hill GL. Preoperative staging of rectal cancer. Int J Colorectal Dis. Feb. 2000;15(1):9-20. [pmid: 10766086].
Lahaye MJ, Engelen SM, Nelemans PJ, et al. Imaging for predicting the risk factors--the circumferential resection margin and nodal disease--of local recurrence in rectal cancer: a meta-analysis. Semin Ultrasound CT MR. Aug. 2005;26(4):259-68. [pmid: 16152740].
Purkayastha S, Tekkis PP, Athanasiou T, et al. Diagnostic precision of magnetic resonance imaging for preoperative prediction of the circumferential margin involvement in patients with rectal cancer. Colorectal Dis. Jun. 2007;9(5):402-11. [pmid: 17504336].
Skandarajah AR, Tjandra JJ. Preoperative loco-regional imaging in rectal cancer. ANZ J Surg. Jun. 2006;76(6):497-504. [pmid: 16768778].
Tytherleigh MG, Warren BF, Mortensen NJ. Management of early rectal cancer. Br J Surg. Apr. 2008;95(4):409-23. [pmid: 18314929].
Wiering B, Krabbe PF, Jager GJ, et al. The impact of Fluor-18-deoxyglucose-positron emission tomography in the management of colorectal liver metastases: a systematic review and metaanalysis. Cancer. Dec. 15. 2005;104(12):2658-70. [pmid: 16315241].

## Primary Article Inclusion Criteria

### All Patients Reported on Already in Pomerri et al. 2011^163^

Maretto I, Pomerri F, Pucciarelli S, et al. The potential of restaging in the prediction of pathologic response after preoperative chemoradiotherapy for rectal cancer. Ann Surg Oncol. Feb. 2007;14(2):455-61. [pmid: 17139456].

### Different Reference Standards for Different Groups of Patients

Squillaci E, Manenti G, Mancino S, et al. Staging of colon cancer: whole-body MRI vs. whole-body PET-CT--initial clinical experience. Abdom Imaging. Nov-Dec. 2008;33(6):676-88. [pmid: 18373114].

### Does Not Report on One of the Test Comparisons of Interest

Adi-Atmaka T. Transrectal ultrasonography; preoperative staging of rectal cancer. Croat J Gastroenterol Hepatol. 1992;1(1):35-9.
Agrawal N, Fowler AL, Thomas MG. The routine use of intra-operative ultrasound in patients with colorectal cancer improves the detection of hepatic metastases. Colorectal Dis. Mar. 2006;8(3):192-4. [pmid: 16466558].
Badger SA, Devlin PB, Neilly PJ, et al. Preoperative staging of rectal carcinoma by endorectal ultrasound: is there a learning curve?. Int J Colorectal Dis. Oct. 2007;22(10):1261-8. [pmid: 17294198].
Faneyte IF, Dresen RC, Edelbroek MA, et al. Pre-operative staging with positron emission tomography in patients with pelvic recurrence of rectal cancer. Dig Surg. 2008;25(3):202-7. [pmid: 18577865].
Heneghan JP, Salem RR, Lange RC, et al. Transrectal sonography in staging rectal carcinoma: the role of gray-scale, color-flow, and Doppler imaging analysis. AJR Am J Roentgenol. 1997;169(5):1247-52. [pmid: 9353436].
Huppertz A, Franiel T, Wagner M, et al. Whole-body MRI with assessment of hepatic and extraabdominal enhancement after administration of Gadoxetic acid for staging of rectal carcinoma. Acta Radiol. Oct. 2010;51(8):842-50. [pmid: 20698804].
Itano S, Fuchimoto S, Hamada F, et al. The clinical significance of CT in the preoperative diagnosis of colon and rectal cancer. Hiroshima J Med Sci. Dec. 1986;35(4):309-15. [pmid: 3570842].
Kalantzis Ch, Markoglou C, Gabriel P, et al. Endoscopic ultrasonography in the preoperative staging of colorectal cancer. Hepatogastroenterology. May-Jun. 2002;49(45):683-6. [pmid: 12063969].
Petersen H, Nielsen MJ, Hoilund-Carlsen M, et al. PET/CT may change diagnosis and treatment in cancer patients. Dan Med Bull. Sep. 2010;57(9).
Ruers TJ, Wiering B, van der Sijp JR, et al. Improved selection of patients for hepatic surgery of colorectal liver metastases with (18)F-FDG PET: a randomized study. J Nucl Med. Jul. 2009;50(7):1036-41. [pmid: 19525451].
Sabbagh C, Fuks D, Joly JP, et al. Is there a role for endoscopic ultrasonography in evaluation of the left liver in colorectal liver metastasis patients selected for right hepatectomy. Surg Endosc. Dec. 2009;23(12):2816-21. [pmid: 19440793].
Spatz J, Holl G, Sciuk J, et al. Neoadjuvant chemotherapy affects staging of colorectal liver metastasis--a comparison of PET, CT and intraoperative ultrasound. Int J Colorectal Dis. Feb. 2011;26(2):165-71. [pmid: 20960208].
Steele SR, Martin MJ, Place RJ. Flexible endorectal ultrasound for predicting pathologic stage of rectal cancers. Am J Surg. Aug. 2002;184(2):126-30. [pmid: 12169355].
Tamandl D, Herberger B, Gruenberger B, et al. Adequate preoperative staging rarely leads to a change of intraoperative strategy in patients undergoing surgery for colorectal cancer liver metastases. Surgery. May. 2008;143(5):648-57. [pmid: 18436013].
Tytherleigh MG, Ng VV, Pittathankal AA, et al. Preoperative staging of rectal cancer by magnetic resonance imaging remains an imprecise tool. ANZ J Surg. Mar. 2008;78(3):194-8. [pmid: 18269488].
Zacherl J, Scheuba C, Imhof M, et al. Current value of intraoperative sonography during surgery for hepatic neoplasms. World J Surg. May. 2002;26(5):550-4. [pmid: 12098044].

### Does Not Report One of the Outcomes of Interest

Chun HK, Choi D, Kim MJ, et al. Preoperative staging of rectal cancer: comparison of 3-T high-field MRI and endorectal sonography. AJR Am J Roentgenol. Dec. 2006;187(6):1557-62. [pmid: 17114550].
Phang PT, Gollub MJ, Loh BD, et al. Accuracy of endorectal ultrasound for measurement of the closest predicted radial mesorectal margin for rectal cancer. Dis Colon Rectum. Jan. 2012;55(1):59-64. [pmid: 22156868].
Shinya S, Sasaki T, Nakagawa Y, et al. The efficacy of diffusion-weighted imaging for the detection of colorectal cancer. Hepatogastroenterology. Jan-Feb. 2009;56(89):128-32. [pmid: 19453043].

### Experimental Technology

Fuchsjager MH, Maier AG, Schima W, et al. Comparison of transrectal sonography and double-contrast MR imaging when staging rectal cancer. AJR Am J Roentgenol. Aug. 2003;181(2):421-7. [pmid: 12876020].
Giovannini M, Bories E, Pesenti C, et al. Three-dimensional endorectal ultrasound using a new freehand software program: results in 35 patients with rectal cancer. Endoscopy. Apr. 2006;38(4):339-43. [pmid: 16680631].
Haji A, Ryan S, Bjarnason I, et al. Colonoscopic high frequency mini-probe ultrasound is more accurate than conventional computed tomography in the local staging of colonic cancer. Colorectal Dis. Aug. 2012;14(8):953-9. [pmid: 22053753].
Kam MH, Wong DC, Siu S, et al. Comparison of magnetic resonance imaging-Fluorodeoxyglucose positron emission tomography fusion with pathological staging in rectal cancer. Br J Surg. Feb. 2010;97(2):266-8. [pmid: 20035542].
Lahaye MJ, Beets GL, Engelen SM, et al. Locally advanced rectal cancer: MR imaging for restaging after neoadjuvant radiation therapy with concomitant chemotherapy. Part II. What are the criteria to predict involved lymph nodes?. Radiology. Jul. 2009;252(1):81-91. [pmid: 19403848].
Maier AG, Kersting-Sommerhoff B, Reeders JW, et al. Staging of rectal cancer by double-contrast MR imaging using the rectally administered superparamagnetic iron oxide contrast agent Ferristene and IV gadodiamide injection: results of a multicenter phase II trial. J Magn Reson Imaging. Nov. 2000;12(5):651-60. [pmid: 11050634].
Mezzi G, Arcidiacono PG, Carrara S, et al. Endoscopic ultrasound and magnetic resonance imaging for restaging rectal cancer after radiotherapy. World J Gastroenterol. Nov. 28. 2009;15(44):5563-7. [pmid: 19938195].
Veit-Haibach P, Kuehle CA, Beyer T, et al. Diagnostic accuracy of colorectal cancer staging with whole-body PET/CT colonography. JAMA. Dec. 6. 2006;296(21):2590-600. [pmid: 17148724].
Wallengren NO, Holtas S, Andren-Sandberg A, et al. Rectal carcinoma: double-contrast MR imaging for preoperative staging. Radiology. Apr. 2000;215(1):108-14. [pmid: 10751475].
Wang X, Lv D, Song H, et al. Multimodal preoperative evaluation system in surgical decision making for rectal cancer: a randomized controlled trial. Int J Colorectal Dis. Mar. 2010;25(3):351-8. [pmid: 19921223].

### Fewer Than 10 Patients

Tio TL, Tytgat GN. Comparison of blind transrectal ultrasonography with endoscopic transrectal ultrasonography in assessing rectal and perirectal diseases. Scand J Gastroenterol Suppl. 1986;123:104-11. [pmid: 3535025].

### Mixed Group of Patient Types, Data Not Reported Separately by Group

Adeyemo D, Hutchinson R. Preoperative staging of rectal cancer: pelvic MRI plus abdomen and pelvic CT. Does extrahepatic abdomen imaging matter? A case for routine thoracic CT. Colorectal Dis. Mar. 2009;11(3):259-63. [pmid: 18513197].
Blomqvist L, Machado M, Rubio C, et al. Rectal tumour staging: MR imaging using pelvic phased-array and endorectal coils vs endoscopic ultrasonography. Eur Radiol. 2000;10(4):653-60. [pmid: 10795550].
Boutkan H, Luth W, Meyer S, et al. The impact of intraoperative ultrasonography of the liver on the surgical strategy of patients with gastrointestinal malignancies and hepatic metastases. Eur J Surg Oncol. Aug. 1992;18(4):342-6. [pmid: 1521627].
Butch RJ, Stark DD, Wittenberg J, et al. Staging rectal cancer by MR and CT. AJR Am J Roentgenol. Jun. 1986;146(6):1155-60. [pmid: 3486559].
Fernandez-Esparrach G, Ayuso-Colella JR, Sendino O, et al. EUS and magnetic resonance imaging in the staging of rectal cancer: a prospective and comparative study. Gastrointest Endosc. Aug. 2011;74(2):347-54. [pmid: 21802588].
Georgakopoulos A, Pianou N, Kelekis N, et al. Impact of 18F-FDG PET/CT on therapeutic decisions in patients with colorectal cancer and liver metastases. Clin Imaging. May-June. 2013;37(3):536-41. [pmid: 23116727].
Grassetto G, Fornasiero A, Bonciarelli G, et al. Additional value of FDG-PET/CT in management of “solitary” liver metastases: preliminary results of a prospective multicenter study. Mol Imaging Biol. Apr. 2010;12(2):139-44. [pmid: 19626378].
Haijnen LA, Lambregts DMJ, Mondal D, et al. Diffusion-weighted MR imaging in primary rectal cancer staging demonstrates but does not characterize lymph nodes. Eur Radiol. 2013. July. 3. Epub ahead of print.
Harnsberger JR, Charvat P, Longo WE, et al. The role of intrarectal ultrasound (IRUS) in staging of rectal cancer and detection of extrarectal pathology. Am Surg. Aug. 1994;60(8):571-6. discussion 576-7. [pmid: 8030810].
Hunerbein M, Schlag PM. Three-dimensional endosonography for staging of rectal cancer. Ann Surg. Apr. 1997;225(4):432-8. [pmid: 9114803].
Kim JC, Cho YK, Kim SY, et al. Comparative study of three-dimensional and conventional endorectal ultrasonography used in rectal cancer staging. Surg Endosc. Sep. 2002;16(9):1280-5. [pmid: 11988797].
Kulinna C, Eibel R, Matzek W, et al. Staging of rectal cancer: diagnostic potential of multiplanar reconstructions with MDCT. AJR Am J Roentgenol. Aug. 2004;183(2):421-7. [pmid: 15269036].
Manenti G, Ciccio C, Squillaci E, et al. Role of combined DWIBS/3D-CE-T1w whole-body MRI in tumor staging: comparison with PET-CT. Eur J Radiol. Aug. 2012;81(8):1917-25. [pmid: 21908120].
Mathur P, Smith JJ, Ramsey C, et al. Comparison of CT and MRI in the pre-operative staging of rectal adenocarcinoma and prediction of circumferential resection margin involvement by MRI. Colorectal Dis. Sep. 2003;5(5):396-401. [pmid: 12925069].
Mizukami Y, Ueda S, Mizumoto A, et al. Diffusion-weighted magnetic resonance imaging for detecting lymph node metastasis of rectal cancer. World J Surg. Apr. 2011;35(4):895-9. [pmid: 21327602].
Rifkin MD, Ehrlich SM, Marks G. Staging of rectal carcinoma: prospective comparison of endorectal US and CT. Radiology. Feb. 1989;170(2):319-22. [pmid: 2643135].
Sinha R, Verma R, Rajesh A, et al. Diagnostic value of multidetector row CT in rectal cancer staging: comparison of multiplanar and axial images with histopathology. Clin Radiol. Nov. 2006;61(11):924-31. [pmid: 17018304].
Swartling T, Kalebo P, Derwinger K, et al. Stage and size using magnetic resonance imaging and endosonography in neoadjuvantly-treated rectal cancer. World J Gastroenterol. June. 2013;19(21):3263-71. [pmid: 23745028].
Thomson V, Pialat JB, Gay F, et al. Whole-body MRI for metastases screening: a preliminary study using 3D VIBE sequences with automatic subtraction between noncontrast and contrast enhanced images. Am J Clin Oncol. Jun. 2008;31(3):285-92. [pmid: 18525309].

### More Than 50 Percent of Patients Lost

Barbaro B, Valentini V, Manfredi R. Combined modality staging of high risk rectal cancer. Rays. Apr-Jun. 1995;20(2):165-81. [pmid: 7480865].
Caseiro-Alves F, Goncalo M, Cruz L, et al. Water enema computed tomography (WE-CT) in the local staging of low colorectal neoplasms: comparison with transrectal ultrasound. Abdom Imaging. Jul-Aug. 1998;23(4):370-4. [pmid: 9663271].
Cho YB, Chun HK, Kim MJ, et al. Accuracy of MRI and 18F-FDG PET/CT for restaging after preoperative concurrent chemoradiotherapy for rectal cancer. World J Surg. Dec. 2009;33(12):2688-94. [pmid: 19823904].
Holdsworth PJ, Johnston D, Chalmers AG, et al. Endoluminal ultrasound and computed tomography in the staging of rectal cancer. Br J Surg. Oct. 1988;75(10):1019-22. [pmid: 3064866].
Panzironi G, De Vargas Macciucca M, et al. Preoperative locoregional staging of rectal carcinoma: comparison of MR, TRUS and Multislice CT. Personal experience. Radiol Med. Apr. 2004;107(4):344-55. [pmid: 15103286].
Shami VM, Parmar KS, Waxman I. Clinical impact of endoscopic ultrasound and endoscopic ultrasound-guided fine-needle aspiration in the management of rectal carcinoma. Dis Colon Rectum. Jan. 2004;47(1):59-65. [pmid: 14719152].

### No Reference Standard

Aljebreen AM, Azzam NA, Alzubaidi AM, et al. The accuracy of multi-detector row computerized tomography in staging rectal cancer compared to endoscopic ultrasound. Saudi J Gastroenterol. May. 2013;19(3):108-12. [pmid: 23680707].
Cipe G, Ergul N, Hasbahceci M, et al. Routine use of positron-emission tomography/computed tomography for staging of primary colorectal cancer: does it affect clinical management?. World J Surg Oncol. Feb. 2013;11(1):49-56. [pmid: 23445625].
Maizlin ZV, Brown JA, So G, et al. Can CT replace MRI in preoperative assessment of the circumferential resection margin in rectal cancer?. Dis Colon Rectum. Mar. 2010;53(3):308-14. [pmid: 20173478].
Vliegen R, Dresen R, Beets G, et al. The accuracy of Multi-detector row CT for the assessment of tumor invasion of the mesorectal fascia in primary rectal cancer. Abdom Imaging. Sep-Oct. 2008;33(5):604-10. [pmid: 18175167].

### Not a Clinical Study

MRI better than FDG-PET at detecting liver tumors. Oncology (Huntingt). Aug. 2005;19(9):1176.
Beets-Tan RG, Beets GL, Van De Velde CJ. Staging in colorectal cancer. Eur J Cancer Suppl. Oct. 2005;3(3):361-6.
Fasih N, Virmani V, Walsh C, et al. Double-contrast magnetic resonance imaging in preoperative evaluation of rectal cancer: use of aqueous jelly as luminal contrast. Can Assoc Radiol J. May. 2011;62(2):122-4. [pmid: 20362411].
Garcia-Aguilar J. Transanal endoscopic microsurgery following neoadjuvant chemoradiation therapy in rectal cancer: a word of caution about patient selection?. Dis Colon Rectum. Jan. 2013;56(1):1-3. [pmid: 23222272].
Hamm B. Multi-detector CT of the abdomen. Eur Radiol. 2003;13.
Husband JE, Sharma B. Radiological staging of gastrointestinal and breast tumours. Br J Surg. May. 2006;93(5):513-5. [pmid: 16607685].
Iyer R. Imaging colorectal cancer. Semin Roentgenol. Apr. 2006;41(2):113-20. [pmid: 16697890].
Low RN. MRI of colorectal cancer. Abdom Imaging. Jul-Aug. 2002;27(4):418-24. [pmid: 12066240].
McCarthy S. Proper staging and monitoring of colonic carcinoma. Postgrad Radiol. 1986;6(3):195-201.
Moadel RM, Feng J, Freeman LM. PET/CT in the evaluation of colorectal carcinoma. Appl Radiol. Nov. 2008;37(11):33-42.
Moss AA. Imaging of colorectal carcinoma. Radiology. Feb. 1989;170(2):308-10. [pmid: 2643134].
Rembacken BJ, Cairns A, Kudo S, et al. Images of early rectal cancer. Endoscopy. Mar. 2004;36(3):223-33. [pmid: 14986222].
Romanini A, Cellini N, Coco C. Combined diagnostic techniques for clinical staging of cancer of the rectum. Rays. 1982;7(1):39-51.
Wiggers T. Staging of rectal cancer. Br J Surg. Aug. 2003;90(8):895-6. [pmid: 12905539].
Wong WD. Transrectal ultrasound: accurate staging for rectal cancer. J Gastrointest Surg. Jul-Aug. 2000;4(4):338-9. [pmid: 11185448].

### Not Colorectal Cancer

Kim JC, Kim HC, Yu CS, et al. Efficacy of 3-dimensional endorectal ultrasonography compared with conventional ultrasonography and computed tomography in preoperative rectal cancer staging. Am J Surg. Jul. 2006;192(1):89-97. [pmid: 16769283].
Koch J, Halvorsen RA Jr, Levenson SD, et al. Prospective comparison of catheter-based endoscopic sonography versus standard endoscopic sonography: evaluation of gastrointestinal-wall abnormalities and staging of gastrointestinal malignancies. J Clin Ultrasound. Mar-Apr. 2001;29(3):117-24. [pmid: 11329153].
Lai DT, Fulham M, Stephen MS, et al. The role of whole-body positron emission tomography with [18F]fluorodeoxyglucose in identifying operable colorectal cancer metastases to the liver. Arch Surg. Jul. 1996;131(7):703-7. [pmid: 8678767].
Miyake KK, Nakamoto Y, Togashi K. Dual-time-point 18F-FDG PET/CT in patients with colorectal cancer: clinical value of early delayed scanning. Ann Nucl Med. Jul. 2012;26(6):492-500. [pmid: 22492392].
Suzuki C, Torkzad MR, Tanaka S, et al. The importance of rectal cancer MRI protocols on interpretation accuracy. World J Surg Oncol. Aug. 20. 2008;6:89. [pmid: 18715510].
Yamashita S, Masui T, Katayama M, et al. T2-weighted MRI of rectosigmoid carcinoma: comparison of respiratory-triggered fast spin-echo, breathhold fast-recovery fast spin-echo, and breathhold single-shot fast spin-echo sequences. J Magn Reson Imaging. Mar. 2007;25(3):511-6. [pmid: 17326094].

### Not in English

Balena V, Martino D, Lorusso F, et al. Endorectal ultrasound and magnetic resonance imaging (MRI) scan in rectal cancer: a comparative study. Arch Ital Urol Androl. Dec. 2010;82(4):259-61. [pmid: 21341576].
Bianchi P, Ceriani C, Palmisano A, et al. A prospective comparison of endorectal ultrasound and pelvic magnetic resonance in the preoperative staging of rectal cancer. Ann Ital Chir. Jan-Feb. 2006;77(1):41-6. [pmid: 16910358].
Dinter DJ, Hofheinz RD, Hartel M, et al. Preoperative staging of rectal tumors: comparison of endorectal ultrasound, hydro-CT, and high-resolution endorectal MRI. Onkologie. May. 2008;31(5):230-5. [pmid: 18497511].
Feifel G. Does endorectal sonography influence treatment of rectal cancer?. Z Gastroenterol. 1989;27:102-7.
Palko A, Gyulai C, Fedinecz N, et al. Water enema CT examination of rectum cancer by reduced amount of water. ROFO Fortschr Geb Rontgenstr Nuklearmed. Nov. 2000;172(11):901-4. [pmid: 11142122].
Rifkin MD, Marks G. Endorectal sonography in prospective staging of rectal cancer. Z Gastroenterol. 1989;27(Spec Iss):98-101.
Siegel R, Dresel S, Koswig S, et al. Response to preoperative short-course radiotherapy in locally advanced rectal cancer: Value of 18F-Fluorodeoxyglucose positron emission tomography. Onkologie. 2008;31(4):166-72. [pmid: 18418017].

### Obsolete Technology

Cellini N, Coco C, Maresca G, et al. Clinical staging of rectal cancer: a study on 126 patients. Rays. Jan-Apr. 1986;11(1):69-79. [pmid: 3299501].
Gearhart SL, Frassica D, Rosen R, et al. Improved staging with pretreatment positron emission tomography/computed tomography in low rectal cancer. Ann Surg Oncol. Mar. 2006;13(3):397-404. [pmid: 16485158].
Kwak JY, Kim JS, Kim HJ, et al. Diagnostic value of FDG-PET/CT for lymph node metastasis of colorectal cancer. World J Surg. Aug. 2012;36(8):1898-905. [pmid: 22526032].
Pegios W, Vogl J, Mack MG, et al. MRI diagnosis and staging of rectal carcinoma. Abdom Imaging. May-Jun. 1996;21(3):211-8. [pmid: 8661545].
Reed WP, Haney PJ, Elias EG. Ethiodized oil emulsion enhanced computerized tomography in the preoperative assessment of metastases to the liver from the colon and rectum. Surg Gynecol Obstet. 1986;162(2):131-6. [pmid: 3003941].
Ruhlmann J, Schomburg A, Bender H, et al. Fluorodeoxyglucose whole-body positron emission tomography in colorectal cancer patients studied in routine daily practice. Dis Colon Rectum. Oct. 1997;40(10):1195-204. [pmid: 9336115].
Yu SL, Tsang YM, Liang PC, et al. Application of magnetic resonance images in gastrointestinal malignancies. Chin J Radiol. Oct. 2003;28(5):269-75.
Zagoria RJ, Schlarb CA, Ott DJ, et al. Assessment of rectal tumor infiltration utilizing endorectal MR imaging and comparison with endoscopic rectal sonography. J Surg Oncol. Apr. 1997;64(4):312-7. [pmid: 9142189].
Zerhouni EA, Rutter C, Hamilton SR, et al. CT and MR imaging in the staging of colorectal carcinoma: report of the Radiology Diagnostic Oncology Group II. Radiology. Aug. 1996;200(2):443-51. [pmid: 8685340].

### Off Topic

Baumann T, Ludwig U, Pache G, et al. Continuously moving table MRI with sliding multislice for rectal cancer staging: image quality and lesion detection. Eur J Radiol. Mar. 2010;73(3):579-87. [pmid: 19179029].
Fischer MA, Nanz D, Hany T, et al. Diagnostic accuracy of whole-body MRI/DWI image fusion for detection of malignant tumours: a comparison with PET/CT. Eur Radiol. Feb. 2011;21(2):246-55. [pmid: 20717828].
Ippolito D, Monguzzi L, Guerra L, et al. Response to neoadjuvant therapy in locally advanced rectal cancer: assessment with diffusion-weighted MR imaging and 18FDG PET/CT. Abdom Imaging. Dec. 2012;37(6):1032-40. [pmid: 22270580].
Izadpanah A, Hosseini SV, Jalli R, et al. Efficacy of endorectal ultrasonography in preoperative staging of rectal carcinoma. Saudi Med J. Aug. 2005;26(8):1308-10. [pmid: 16127540].
Killeen T, Banerjee S, Vijay V, et al. Magnetic resonance (MR) pelvimetry as a predictor of difficulty in laparoscopic operations for rectal cancer. Surg Endosc. Dec. 2010;24(12):2974-9. [pmid: 20464426].
Kim SH, Lee JM, Hong SH, et al. Locally advanced rectal cancer: added value of diffusion-weighted MR imaging in the evaluation of tumor response to neoadjuvant chemo- and radiation therapy. Radiology. Oct. 2009;253(1):116-25. [pmid: 19789256].
Lambregts DM, Vandecaveye V, Barbaro B, et al. Diffusion-weighted MRI for selection of complete responders after chemoradiation for locally advanced rectal cancer: a multicenter study. Ann Surg Oncol. Aug. 2011;18(8):2224-31. [pmid: 21347783].

### Patients Not Diagnosed With Cancer Before Enrollment

Arulampalam T, Costa D, Visvikis D, et al. The impact of FDG-PET on the management algorithm for recurrent colorectal cancer. Eur J Nucl Med. Dec. 2001;28(12):1758-65. [pmid: 11734912].
Dirisamer A, Halpern BS, Flory D, et al. Performance of integrated FDG-PET/contrast-enhanced CT in the staging and restaging of colorectal cancer: comparison with PET and enhanced CT. Eur J Radiol. Feb. 2010;73(2):324-8. [pmid: 19200683].
Kim CK, Kim SH, Choi D, et al. Comparison between 3-T magnetic resonance imaging and multi-detector row computed tomography for the preoperative evaluation of rectal cancer. J Comput Assist Tomogr. Nov-Dec. 2007;31(6):853-9. [pmid: 18043346].
Rollven E, Holm T, Glimelius B, et al. Potentials of high resolution magnetic resonance imaging versus computed tomography for preoperative local staging of colon cancer. Acta Radiol. Aug. 2013;54(7):722-30. [pmid: 23550186].
Soyka JD, Veit-Haibach P, Strobel K, et al. Staging pathways in recurrent colorectal carcinoma: is contrast-enhanced 18F-FDG PET/CT the diagnostic tool of choice?. J Nucl Med. Mar. 2008;49(3):354-61. [pmid: 18287263].
Sudakoff GS, Gasparaitis A, Michelassi F, et al. Endorectal color Doppler imaging of primary and recurrent rectal wall tumors: preliminary experience. AJR Am J Roentgenol. Jan. 1996;166(1):55-61. [pmid: 8571905].

### Retrospective Study That Did Not Enroll All or Consecutive Patients

Beer-Gabel M, Assouline Y, Zmora O, et al. A new rectal ultrasonographic method for the staging of rectal cancer. Dis Colon Rectum. Aug. 2009;52(8):1475-80. [pmid: 19617763].
Maas M, Lambregts DM, Lahaye MJ, et al. T-staging of rectal cancer: accuracy of 3.0 Tesla MRI compared with 1.5 Tesla. Abdom Imaging. Jun. 2012;37(3):475-81. [pmid: 21674192].
Tateishi U, Maeda T, Morimoto T, et al. Non-enhanced CT versus contrast-enhanced CT in integrated PET/CT studies for nodal staging of rectal cancer. Eur J Nucl Med Mol Imaging. Oct. 2007;34(10):1627-34. [pmid: 17530248].