# Search Strategy

## Resources Searched

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for each resource appear below.

Table A-1 Databases searched for relevant information

Name | Date Limits | Platform/Provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | 1990 through February 21, 2013 | Wiley
The Cochrane Database of Methodology Reviews (Methodology Reviews) | 1990 through February 21, 2013 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | 1990 through February 21, 2013 | Wiley
Database of Abstracts of Reviews of Effects (DARE) | 1990 through February 21, 2013 | Wiley
EMBASE (Excerpta Medica) | 1980 through October 23, 2013 for main search & 2008 through May 31, 2013 for safety search | OVIDSP
Health Technology Assessment Database (HTA) | 1990 through February 21, 2013 | Wiley
MEDLINE | 1980 through October 23, 2013 for main search & 2008 through May 31, 2013 for safety search | OVIDSP
PubMed (PreMEDLINE) | Searched on October 23, 2013 for main search & 2008 through May 31, 2013 for safety search | NLM
U.K. National Health Service Economic Evaluation Database (NHS EED) | 1990 through February 21, 2013 | Wiley

## Topic-Specific Search Terms

The search strategies employed combinations of free-text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. Strategies for each bibliographic database follow this table.

Table A-2 Medical Subject Headings (MeSH), EMTREE, and keywords

Concept | Controlled Vocabulary | Keywords
Cancer | MeSH Colorectal Neoplasms EMTREE Colon Cancer Colon Tumor Rectum Cancer Rectum Tumor | Adenocarcinoma$ Cancer$ Carcinoma$ Colon$ Colorectal Neoplas$ Rect$ Tumo$
Staging | MeSH Neoplasm Staging EMTREE Cancer Staging | Re-stag$ Restag$ Stag$
Imaging | MeSH Diagnostic Imaging Endoscopy, Gastrointestinal Magnetic Resonance Imaging Tomography, Emission-Computed Tomography, X-Ray Computed Radiography, Thoracic Ultrasonography EMTREE Computer Assisted Emission Tomography Computer Assisted Tomography Echography Gastrointestinal Endoscopy Positron Emission Tomography Multidetector Computed Tomography Nuclear Magnetic Resonance Imaging Thorax Radiography | Computed tomography Computerized tomography CT Endorectal Endoscop$ ERUS EUS Imag$ Magnetic resonance imaging MD-CT MRI Multidetector computerized tomography PET Positron emission tomography Transabdominal Transrectal TRUS TUS Ultrasound X-ray
Imaging Agents | MeSH Contrast Media EMTREE Contrast Medium | Agent$ Contrast Medium$
Radiation | MeSH Radiation Injuries EMTREE Radiation Injury | Injury Radiation
Harms & Adverse Events | MeSH Medical Errors EMTREE Medical Error | Adverse Effect$ Error$ Event$ Harm$ Outcome$ Reaction$

## Search Strategies

Table A-3 EMBASE/MEDLINE (presented in OVID syntax)

Set # | Concept | Search Statement
1 | Colorectal Cancer | exp Colorectal Neoplasms/ or exp colon cancer/ or exp colon tumor/ or exp rectum cancer/ or exp rectum tumor/ or ((Colon$ or colorectal or rect$) adj2 (cancer$ or tumo$ or neoplas$ or carcinoma$ or adenocarcinoma$)).ti,ab.
2 | Staging | neoplasm staging/ or cancer staging/ or (stag$ or restag$ or re-stag$).ti,ab.
3 | Imaging Controlled Vocabulary | exp Diagnostic Imaging/ or exp Tomography, Emission-Computed/ or exp Tomography, X-Ray Computed/ or exp Magnetic Resonance Imaging/ or exp Ultrasonography/ or Radiography, Thoracic/ or exp computer assisted tomography/ or positron emission tomography/ or multidetector computed tomography/ or exp nuclear magnetic resonance imaging/ or Thorax radiography/ or exp echography/ or computer assisted emission tomography/ or Endoscopy, Gastrointestinal/ or gastrointestinal endoscopy/ or (“computed tomography” or “computerized tomography” or “multidetector computerized tomography” or “magnetic resonance imaging” or “positron emission tomography” or (CT or PET or MRI or TRUS or TUS or ERUS or EUS or MD-CT or x-ray) or ((endorectal or endoscop$ or transrectal or transabdominal) and ultrasound) or imag$).mp
4 | Combine | 1 and 2 and 3
5 | English | limit 4 to english language
6 | Human | limit 5 to human
7 | 1980–2013 | limit 6 to yr=“1980 - 2013”
8 | Humans | limit 7 to humans
9 | Publication Types | 8 not (letter/ or editorial/ or news/ or comment/ or case report.mp. or case reports/ or note/ or conference paper/ or (letter or editorial or news or comment or case reports or conference abstract$).pt.)
10 | Publication Types | 8 and case series
11 | Combine | 9 or 10
12 | Dedupe | remove duplicates from 11

Table A-4 EMBASE/MEDLINE (presented in OVID syntax) – safety search

Set # | Concept | Search Statement
1 | Imaging technology controlled vocabulary | exp Tomography, Emission-Computed/ae, mo or exp Tomography, X-Ray Computed/ae, mo or exp Magnetic Resonance Imaging/ae, mo or Endosonography/ae, mo or nuclear magnetic resonance imaging/ae or nuclear magnetic resonance imaging agent/ae, to or endoscopic echography/ae
2 | Imaging technology keywords | (“computed tomography” or “computerized tomography” or “magnetic resonance imaging” or “positron emission tomography” or (endoscop$ adj ultrasound)).ti,ab.
3 | Imaging technology set | 1 or 2
4 | Radiation & contrast media controlled vocabulary | Radiation injury/ or Contrast Medium/ae or Radiation Injuries/ or Contrast Media/ae, to
5 | Radiation & contrast media injuries related to imaging technologies | 3 and 4
6 | Imaging technologies and related harms | 3 or 5
7 | Harms & adverse events controlled vocabulary and keywords | Medical error/ or Medical errors/ or (harm or harms or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))).ti,ab.
8 | Technologies and harms/adverse events | 6 and 7
9 | English | limit 8 to English language
10 | Human | limit 9 to human
11 | Date | limit 10 to yr=””2008 – 2013”
12 | Humans | limit 11 to humans
13 | Dedupe | remove duplicates from 12
14 | Eliminate certain publication types | 13 not (letter/ or editorial/ or news/ or comment/ or case report.mp. or case reports/ or note/ or conference paper/ or (letter or editorial or news or comment or case reports or conference abstract$).pt.)
15 | Add in case series | 13 and case series.mp.
16 | Combine for final set | 14 or 15

OVID Syntax
- $ or * = truncation character (wildcard)
- ADJn = search terms within a specified number (n) of words from each other in any order
- / = search as a subject heading (note that terms preceded by an asterisk are searched as a major subject headings)
- exp = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
- .de. = limit controlled vocabulary heading
- .fs. = floating subheading
- .hw. = limit to heading word
- .md. = type of methodology (PsycINFO)
- .mp. = combined search fields (default if no fields are specified)
- .pt. = publication type
- .ti. = limit to title
- .tw. = limit to title and abstract fields

Table A-5 PubMed

Set # | Concept | Search Statement
1 | Subsets | (inprocess[sb] OR publisher[sb] OR pubmednotmedline[sb])
2 | Colorectal cancer keywords | (Colon*[tiab] OR colorectal[tiab] OR rect*[tiab] OR rectal[tiab] OR rectum[tiab]) AND (cancer*[tiab] OR tumo*[tiab] OR tumor*[tiab] OR tumour*[tiab] OR neoplas*[tiab] OR carcinoma*[tiab] OR Adenocarcinoma[tiab])
3 | Staging title keywords | (stag*[tiab] OR restag*[tiab] OR re-stag*[tiab])
4 | Imaging technologies keywords | ((“computerized tomography” OR “multidetector computerized tomography” OR “magnetic resonance imaging” OR “positron emission tomography”) OR (intraoperative OR laparoscopic OR surgical) OR (CT OR PET OR MRI OR US OR ERUS OR EUS OR MD-CT OR x-ray) OR ((endorectal OR endoscopic OR laparoscopic OR transrectal OR transabdominal) and (ultrasound OR US)) OR imag* OR image OR imaging)
5 | Combine | #1 AND #2 AND #3 AND #4

Table A-6 PubMed – safety search

Set # | Concept | Search Statement
1 | Imaging technology | ((computed tomography OR computerized tomography OR magnetic resonance imaging OR positron emission tomography OR (endoscop* AND ultrasound)))
2 | Contrast/imaging agents | ((imaging OR imag* OR contrast) AND (medium* OR agent*)
3 | Radiation | ((Radiation AND (image OR imaging OR imag* OR injury)))
4 | Combine | #1 AND (#2 OR #3)
5 | Safety | ((medical error* OR harm* OR harm OR harms OR (adverse AND (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes))))
6 | Combine | (#1 OR #4) AND #5
7 | Subsets | #6 AND (inprocess[sb] OR publisher[sb] OR pubmednotmedline[sb])
8 | Date filter | Filters: published in the last 5 years

PubMed Syntax
- * = truncation character (wildcard)
- [ti] = limit to title field
- [tiab] = limit to title and abstract fields
- [tw] = text word

Table A-7 Cochrane Library databases

Set # | Concept | Search Statement
1 | Colorectal Cancer MeSH | MeSH descriptor: [Colorectal Neoplasms] explode all trees
2 | Staging MeSH | MeSH descriptor: [Neoplasm Staging] explode all trees
3 | Imaging Technologies MeSH | MeSH descriptor: [Diagnostic Imaging] explode all trees
4 | Staging MeSH and keywords | #2 or (stag* or restag* or re-stag*):ti,ab,kw
5 | Colorectal cancer MeSH and keywords | #1 or ((Colon or colorectal or rect*) and (cancer* or tumo* or neoplas* or carcinoma* or adenocarcinoma*)):ti,kw,ab
6 | Imaging technologies MeSH and keywords | #3 or (“computed tomography” or “computerized tomography” or “multidetector computerized tomography” or “magnetic resonance imaging” or “positron emission tomography” or ultrasound or CT or PET or MRI or US or ERUS or EUS or MD-CT or MDCT or x-ray or imag*):ti,ab,kw
7 | Combine | #4 and #5 and #6

Cochrane Library Syntax
- * = truncation character (wildcard)

The Cochrane Library via the Wiley platform is menu-driven.