# Abbreviations and Acronyms

95% CI: 95% confidence interval
ACR: American College of Radiology
AJCC: American Joint Committee on Cancer
ASA: American Society of Anesthesiologists
ASA III: American Society of Anesthesiologists Class III
ASA IV: American Society of Anesthesiologists Class IV
bpm: beats per minute
CER: comparative effectiveness review
CIAKI: contrast-induced acute kidney injury
CINAHL: Cumulative Index to Nursing and Allied Health Literature database
cm: centimeter
CRM: circumferential resection margin
CT: computed tomography
CTPA: computed tomography pulmonary angiography
DARE: Database of Reviews of Effectiveness
DBE: double-balloon endoscopy
EPC: Evidence-based Practice Center
ERCP: endoscopic retrograde cholangiopancreatography
ERUS: endorectal ultrasound
EUS: endoscopic ultrasound
FDA: U.S. Food and Drug Administration
FDG: ^18^F-fluorodeoxyglucose
GBCA: gadolinium-based contrast agent
IV: intravenous
kg: kilogram
M: metastases stage
MDCT: multiphase detector computed tomography
MHz: megahertz
mg: milligram
ml: milliliter
mm: millimeter
mm Hg: millimeters of Mercury
MRI: magnetic resonance imaging
N: number
N stage: nodal stage
NR: not reported
NS: not significant
NY: New York
OR: odds ratio
PET: positron emission tomography
PET/CT: positron emission tomography/computed tomography
pN: pathologic nodal stage
pT: pathologic tumor stage
QUADAS: quality assessment tool for diagnostic accuracy studies
SD: standard deviation
SpO_2_: oxygen saturation measured by pulse oximetry
SROC: summary receiver operating characteristic
T stage: tumor stage
T: Tesla
USA: United States of America