# References

1 American Cancer Society (ACS). Cancer facts & figures 2012. Atlanta, GA: American Cancer Society (ACS); 2012. 65 p. www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-031941.pdf.
2 Sharma C, Eltawil KM, Renfrew PD, . Advances in diagnosis, treatment and palliation of pancreatic carcinoma: 1990–2010. World J Gastroenterol. 2011 Feb 21;17(7):867–97. PMID: 21412497.21412497
3 Siegel R, Ma J, Zou Z, . Cancer Statistics, 2014. CA Cancer J Clin. 2014 Jan–Feb;64(1):9–29. PMID: 24399786.24399786
4 Dabizzi E, Assef MS, Raimondo M. Diagnostic management of pancreatic cancer. Cancers. 2011 Mar;3(1):494–509.24212626
5 SEER stat fact sheets: pancreas. Bethesda, MD: National Cancer Institute (NCI), National Institutes of Health (NIH). http://seer.cancer.gov/statfacts/html/pancreas.html. Accessed 2012 Nov 8.
6 Pancreatic cancer treatment (PDQ). Health professional version. Bethesda, MD: National Cancer Institute (NCI); 2012 Jul 17. www.cancer.gov/cancertopics/pdq/treatment/pancreatic/HealthProfessional/page1/AllPages/Print. Accessed 2012 Nov 8.
7 Benson AB III, Myerson RJ, Sasson AR. Pancreatic, neuroendocrine GI, and adrenal cancers. In: Cancer management: a multidisciplinary approach. 14th ed. New York, NY: UBM Medica LLC; 2011 Oct 28. www.cancernetwork.com/cancer-management/pancreatic/article/10165/1802606. Accessed 2013 Feb 28.
8 Fernandez-del Castillo C. Clinical manifestations, diagnosis, and staging of exocrine pancreatic cancer. Waltham (MA): UpToDate, Inc; 2013 Jan 14. www.uptodate.com/contents/clinical-manifestations-diagnosis-and-staging-of-exocrine-pancreatic-cancer?source=search_result&search=Clinical+manifestations%2C+diagnosis%2C+and+staging+of+exocrine+pancreatic+cancer&selectedTitle=1%7E134. Accessed 2013 Feb 28.
9 DiMagno EP, Malagelada JR, Taylor WF, . A prospective comparison of current diagnostic tests for pancreatic cancer. N Engl J Med. 1977 Oct 6;297(14):737–42. PMID: 895803.895803
10 Edge SB, Byrd DR, Compton CC, ., editors. AJCC cancer staging manual. 7th ed. New York, NY: Springer; 2010.
11 National Comprehensive Cancer Network (NCCN). Pancreatic adenocarcinoma version 2.2012. Fort Washington, PA: National Comprehensive Cancer Network (NCCN); 2012. 94 p. www.nccn.org/professionals/physician_gls/f_guidelines.asp.
12 Tamm EP, Balachandran A, Bhosale PR, . Imaging of pancreatic adenocarcinoma: update on staging/resectability. Radiol Clin North Am. 2012 May;50(3):407–28. PMID: 22560689.22560689
13 Hidalgo M. Pancreatic cancer. N Engl J Med. 2010 Apr 29;362(17):1605–17. PMID: 20427809.20427809
14 Vincent A, Herman J, Schulick R, . Pancreatic cancer. Lancet. 2011 Aug 13;378(9791):607–20. PMID: 21620466.21620466
15 Al-Hawary MM, Francis IR, Chari ST, . Pancreatic ductal adenocarcinoma radiology reporting template: consensus statement of the Society of Abdominal Radiology and the American Pancreatic Association. Gastroenterology. 2014 Jan;146(1):291–304.e1. 10.1053/j.gastro.2013.11.004. PMID: 24355035.24355035
16 U.S. Preventive Services Task Force (USPSTF). Screening for pancreatic cancer: recommendation statement. Rockville, MD: Agency for Healthcare Research and Quality; 2004 Feb. 3.
17 Canto MI, Harinck F, Hruban RH, Offerhaus GJ, Poley JW, Kamel I, Nio Y, Schulick RS, Bassi C, Kluijt I, Levy MJ, Chak A, Fockens P, Goggins M, Bruno M. International Cancer of the Pancreas Screening (CAPS) Consortium summit on the management of patients with increased risk for familial pancreatic cancer. Gut. 2013 Mar;62(3):339–47. Epub 2012 Nov 7. PMID: 23135763.23135763
18 Callery MP, Chang KJ, Fishman EK, . Pretreatment assessment of resectable and borderline resectable pancreatic cancer: expert consensus statement. Ann Surg Oncol. 2009 Jul;16(7):1727–33. PMID: 19396496.19396496
19 Wong JC, Lu DS. Staging of pancreatic adenocarcinoma by imaging studies. Clin Gastroenterol Hepatol. 2008 Dec;6(12):1301–8. PMID: 18948228.18948228
20 Quality and safety: computed tomography accreditation. Reston, VA: American College of Radiology (ACR). www.acr.org/Quality-Safety/Accreditation/CT. Accessed 2013 May 10.
21 Fang CH, Zhu W, Wang H, . A new approach for evaluating the resectability of pancreatic and periampullary neoplasms. Pancreatology. 2012 Jul–Aug;12(4):364–71. PMID: 22898639.22898639
22 Quality and safety: ultrasound accreditation. Reston, VA: American College of Radiology (ACR). www.acr.org/Quality-Safety/Accreditation/Ultrasound. Accessed 2013 May 9.
23 Kedia P, Gaidhane M, Kahaleh M. Technical advances in endoscopic ultrasound (EUS)-guided tissue acquisition for pancreatic cancers: how can we get the best results with EUS-guided fine needle aspiration? Clin Endosc. 2013 Sep;46(5):552–62. PMID: 24143320.24143320
24 Schima W, Ba-Ssalamah A, Goetzinger P, . State-of-the-art magnetic resonance imaging of pancreatic cancer. Top Magn Reson Imaging. 2007 Dec;18(6):421–9. PMID: 18303400.18303400
25 Vachiranubhap B, Kim YH, Balci NC, . Magnetic resonance imaging of adenocarcinoma of the pancreas. Top Magn Reson Imaging. 2009 Feb;20(1):3–9. PMID: 19687720.19687720
26 Brice J. Experts put MRI accreditation program to the test. Diagn Imaging. 2001 Jul;23(7):44–7, 49.
27 Katanick SL. Fundamentals of ICANL accreditation. J Nucl Med Technol. 2005 Mar;33(1):19–23. PMID: 15731016.15731016
28 Dewitt J, Devereaux BM, Lehman GA, . Comparison of endoscopic ultrasound and computed tomography for the preoperative evaluation of pancreatic cancer: a systematic review. Clin Gastroenterol Hepatol. 2006 Jun;4(6):717–25; quiz 664. PMID: 16675307.16675307
29 Moher D, Liberati A, Tetzlaff J, . Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009 Jul 21;6(7):e1000097. PMID: 19621072.19621072
30 Chalmers I, Adams M, Dickersin K, . A cohort study of summary reports of controlled trials. JAMA. 1990 Mar 9;263(10):1401–5. PMID: 2304219.2304219
31 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. 1987 Mar;8(2):198–203. PMID: 3818406.3818406
32 Dundar Y, Dodd S, Williamson P, . Case study of the comparison of data from conference abstracts and full-text articles in health technology assessment of rapidly evolving technologies: does it make a difference? Int J Technol Assess Health Care. 2006 Jul;22(3):288–94.16984055
33 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. 1992 Mar;3(3):187–91. PMID: 1586615.1586615
34 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. In: Cochrane Library [Cochrane methodology review]. Issue 2. Oxford: Update Software; 2001. www.cochrane.org/index.htm. Accessed 2001 Apr 23.
35 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. 1993 Jul;40(7):632–4. PMID: 8403137.8403137
36 Marx WF, Cloft HJ, Do HM, . The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. 1999 Jun–Jul;20(6):1173–7. PMID: 10445467.10445467
37 Moher D, Pham B, Klassen TP, . What contributions do languages other than English make on the results of meta-analyses? J Clin Epidemiol. 2000 Sep;53(9):964–72. PMID: 11004423.11004423
38 Juni P, Holenstein F, Sterne J, . Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. 2002 Feb;31(1):115–23. PMID: 11914306.11914306
39 White CM, Ip S, McPheeters M, . Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. In: Agency for Healthcare Research and Quality. Methods guide for comparative effectiveness reviews [posted September 2009]. Rockville, MD: Agency for Healthcare Research and Quality; 2009 Sep. http://effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60. PMID: 2143340221433402.
40 Singh S, Chang S, Matchar DB, Bass EB. Grading a body of evidence on diagnostic tests (AHRQ publication no. 12-EHC079-EF). Chapter 7 of Methods guide for medical test reviews (AHRQ publication no. 12-EHC017). Rockville, MD: Agency for Healthcare Research and Quality; 2012 Jun 1. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Also published as a special supplement to the Journal of General Internal Medicine, July 2012.
41 STATA statistics/data analysis. MP parallel edition. College Station (TX): StataCorp; 1984–2007. Single user Stata for Windows. www.stata.com.
42 Zamora J, Abraira V, Muriel A, . Meta-DiSc: a software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. PMID: 16836745.16836745
43 Trikalinos TA, Hoaglin DC, Small KM, Schmid CH. Evaluating practices and developing tools for comparative effectiveness reviews of diagnostic test accuracy: methods for the joint meta-analysis of multiple tests. Methods research report. (Prepared by the Tufts Evidence-based Practice Center, under Contract No. 290-2007-10055-I.) AHRQ publication no. 12(13)-EHC151-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2013 Jan. http://effectivehealthcare.ahrq.gov.
44 Madhoun MF, Wani SB, Rastogi A, . The diagnostic accuracy of 22-gauge and 25-gauge needles in endoscopic ultrasound-guided fine needle aspiration of solid pancreatic lesions: a meta-analysis. Endoscopy. 2013;45(2):86–92. PMID: 23307148.23307148
45 Puli SR, Bechtold ML, Buxbaum JL, . How good is endoscopic ultrasound-guided fine-needle aspiration in diagnosing the correct etiology for a solid pancreatic mass? A meta-analysis and systematic review. Pancreas. 2013 Jan;42(1):20–6. PMID: 23254913.23254913
46 Chen J, Yang R, Lu Y, . Diagnostic accuracy of endoscopic ultrasound-guided fine-needle aspiration for solid pancreatic lesion: a systematic review. J Cancer Res Clin Oncol. 2012 Sep;138(9):1433–41. PMID: 22752601.22752601
47 Hewitt MJ, McPhail MJW, Possamai L, . EUS-guided FNA for diagnosis of solid pancreatic neoplasms: A meta-analysis. Gastrointest Endosc. 2012 Feb;75(2):319–31.22248600
48 Wu LM, Hu JN, Hua J, . Diagnostic value of diffusion-weighted magnetic resonance imaging compared with Fluorodeoxyglucose positron emission tomography/computed tomography for pancreatic malignancy: a meta-analysis using a hierarchical regression model. J Gastroenterol Hepatol. 2012 Jun;27(6):1027–35. PMID: 22414092.22414092
49 Wu LM, Xu JR, Hua J, . Value of diffusion-weighted imaging for the discrimination of pancreatic lesions: a meta-analysis. Eur J Gastroenterol Hepatol. 2012 Feb;24(2):134–42. PMID: 22241215.22241215
50 Tang S, Huang G, Liu J, . Usefulness of 18F-FDG PET, combined FDG-PET/CT and EUS in diagnosing primary pancreatic carcinoma: a meta-analysis. Eur J Radiol. 2011 Apr;78(1):142–50. PMID: 19854016.19854016
51 Zhao WY, Luo M, Sun YW, . Computed tomography in diagnosing vascular invasion in pancreatic and periampullary cancers: a systematic review and meta-analysis. Hepatobiliary Pancreat Dis Int. 2009 Oct;8(5):457–64. PMID: 19822487.19822487
52 Hartwig W, Schneider L, Diener MK, . Preoperative tissue diagnosis for tumours of the pancreas. Br J Surg. 2009 Jan;96(1):5–20. PMID: 19016272.19016272
53 Bipat S, Phoa SS, van Delden OM, . Ultrasonography, computed tomography and magnetic resonance imaging for diagnosis and determining resectability of pancreatic adenocarcinoma: a meta-analysis. J Comput Assist Tomogr. 2005 Jul–Aug;29(4):438–45. PMID: 16012297.16012297
54 Hebert-Magee S, Bae S, Varadarajulu S, . The presence of a cytopathologist increases the diagnostic accuracy of endoscopic ultrasound-guided fine needle aspiration cytology for pancreatic adenocarcinoma: a meta-analysis. Cytopathology. 2013 Jun;24(3):159–71. PMID: 23711182.23711182
55 Affolter KE, Schmidt RL, Matynia AP, . Needle size has only a limited effect on outcomes in EUS-guided fine needle aspiration: a systematic review and meta-analysis. Dig Dis Sci. 2013 Apr;58(4):1026–34. PMID: 23086117.23086117
56 Wang Z, Chen JQ, Liu JL, . FDG-PET in diagnosis, staging and prognosis of pancreatic carcinoma: a meta-analysis. World J Gastroenterol. 2013 Aug 7;19(29):4808–17.23922481
57 Chen G, Liu S, Zhao Y, . Diagnostic accuracy of endoscopic ultrasound-guided fine-needle aspiration for pancreatic cancer: a meta-analysis. Pancreatology. 2013 May–Jun;13(3):298–304. PMID: 23719604.23719604
58 DeWitt J, Devereaux B, Chriswell M, . Comparison of endoscopic ultrasonography and multidetector computed tomography for detecting and staging pancreatic cancer. Ann Intern Med. 2004 Nov 16;141(10):753–63. PMID: 15545675.15545675
59 Tamm EP, Loyer EM, Faria SC, . Retrospective analysis of dual-phase MDCT and follow-up EUS/EUS-FNA in the diagnosis of pancreatic cancer. Abdom Imaging. 2007 Sep–Oct;32(5):660–7. PMID: 17712589.17712589
60 Agarwal B, Abu-Hamda E, Molke KL, . Endoscopic ultrasound-guided fine needle aspiration and multidetector spiral CT in the diagnosis of pancreatic cancer. Am J Gastroenterol. 2004 May;99(5):844–50.15128348
61 Rao SX, Zeng MS, Cheng WZ, . Small solid tumors (< or = 2 cm) of the pancreas: relative accuracy and differentiation of CT and MR imaging. Hepatogastroenterology. 2011 May–Jun;58(107–108):996–1001. PMID: 21830431.21830431
62 Takakura K, Sumiyama K, Munakata K, . Clinical usefulness of diffusion-weighted MR imaging for detection of pancreatic cancer: comparison with enhanced multidetector-row CT. Abdom Imaging. 2011 Aug;36(4):457–62. PMID: 21643939.21643939
63 Motosugi U, Ichikawa T, Morisaka H, . Detection of pancreatic carcinoma and liver metastases with Gadoxetic Acid-enhanced MR imaging: comparison with contrast-enhanced multi-detector row CT. Radiology. 2011 Aug;260(2):446–53. PMID: 21693662.21693662
64 Koelblinger C, Ba-Ssalamah A, Goetzinger P, . Gadobenate Dimeglumine-enhanced 3.0-T MR imaging versus multiphasic 64-detector row CT: prospective evaluation in patients suspected of having pancreatic cancer. Radiology. 2011 Jun;259(3):757–66. PMID: 21436084.21436084
65 Kauhanen SP, Komar G, Seppanen MP, . A prospective diagnostic accuracy study of 18F-fluorodeoxyglucose positron emission tomography/computed tomography, multidetector row computed tomography, and magnetic resonance imaging in primary diagnosis and staging of pancreatic cancer. Ann Surg. 2009 Dec;250(6):957–63. PMID: 19687736.19687736
66 Mehmet Erturk S, Ichikawa T, Sou H, . Pancreatic adenocarcinoma: MDCT versus MRI in the detection and assessment of locoregional extension. J Comput Assist Tomogr. 2006 Jul–Aug;30(4):583–90. PMID: 16845288.16845288
67 Rieber A, Tomczak R, Nussle K, . MRI with Mangafodipir Trisodium in the detection of pancreatic tumours: comparison with helical CT. Br J Radiol. 2000 Nov;73(875):1165–9. PMID: 11144793.11144793
68 Lee JK, Kim AY, Kim PN, . Prediction of vascular involvement and resectability by multidetector-row CT versus MR imaging with MR angiography in patients who underwent surgery for resection of pancreatic ductal adenocarcinoma. Eur J Radiol. 2010 Feb;73(2):310–6. PMID: 19070981.19070981
69 Casneuf V, Delrue L, Kelles A, . Is combined 18F-fluorodeoxyglucose-positron emission tomography/computed tomography superior to positron emission tomography or computed tomography alone for diagnosis, staging and restaging of pancreatic lesions. Acta Gastroenterol Belg. 2007 Oct–Dec;70(4):331–8. PMID: 18330088.18330088
70 Herrmann K, Erkan M, Dobritz M, . Comparison of 3’-deoxy-3’-[18F]fluorothymidine positron emission tomography (FLT PET) and FDG PET/CT for the detection and characterization of pancreatic tumours. Eur J Nucl Med Mol Imaging. 2012 May;39(5):846–51. PMID: 22278320.22278320
71 Saif MW, Cornfeld D, Modarresifar H, . 18F-FDG positron emission tomography CT (FDG PET-CT) in the management of pancreatic cancer: initial experience in 12 patients. J Gastrointest Liver Dis. 2008 Jun;17(2):173–8. PMID: 18568138.18568138
72 Heinrich S, Goerres GW, Schafer M, . Positron emission tomography/computed tomography influences on the management of resectable pancreatic cancer and its cost-effectiveness. Ann Surg. 2005 Aug;242(2):235–43.16041214
73 Lemke AJ, Niehues SM, Hosten N, . Retrospective digital image fusion of multidetector CT and 18F-FDG PET: Clinical value in pancreatic lesions - A prospective study with 104 patients. J Nucl Med. 2004 Aug 1;45(8):1279–86.15299049
74 Schick V, Franzius C, Beyna T, . Diagnostic impact of 18F-FDG PET-CT evaluating solid pancreatic lesions versus endosonography, endoscopic retrograde cholangio-pancreatography with intraductal ultrasonography and abdominal ultrasound. Eur J Nucl Med Mol Imaging. 2008 Oct;35(10):1775–85. PMID: 18481063.18481063
75 Seo Y, Kim MS, Yoo S, . Stereotactic body radiation therapy boost in locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 2009 Dec 1;75(5):1456–61. PMID: 19783379.19783379
76 Li AE, Li BT, Ng BH, . Diagnostic accuracy of imaging modalities in the evaluation of vascular invasion in pancreatic adenocarcinoma: a meta-analysis. World J Oncol. 2013 Apr;4(2):74–82.29147335
77 Tellez-Avila FI, Chavez-Tapia NC, Lopez-Arce G, . Vascular invasion in pancreatic cancer: predictive values for endoscopic ultrasound and computed tomography imaging. Pancreas. 2012 May;41(4):636–8. PMID: 22460727.22460727
78 Soriano A, Castells A, Ayuso C, . Preoperative staging and tumor resectability assessment of pancreatic cancer: prospective study comparing endoscopic ultrasonography, helical computed tomography, magnetic resonance imaging, and angiography. Am J Gastroenterol. 2004 Mar;99(3):492–501. PMID: 15056091.15056091
79 Holzapfel K, Reiser-Erkan C, Fingerle AA, . Comparison of diffusion-weighted MR imaging and multidetector-row CT in the detection of liver metastases in patients operated for pancreatic cancer. Abdom Imaging. 2011 Apr;36(2):179–84. PMID: 20563868.20563868
80 Imai H, Doi R, Kanazawa H, . Preoperative assessment of para-aortic lymph node metastasis in patients with pancreatic cancer. Int J Clin Oncol. 2010 Jun;15(3):294–300.20232101
81 Farma JM, Santillan AA, Melis M, . PET/CT fusion scan enhances CT staging in patients with pancreatic neoplasms. Ann Surg Oncol. 2008 Sep;15(9):2465–71. PMID: 18551347.18551347
82 Shami VM, Mahajan A, Loch MM, . Comparison between endoscopic ultrasound and magnetic resonance imaging for the staging of pancreatic cancer. Pancreas. 2011 May;40(4):567–70. PMID: 21499211.21499211
83 Fabbri C, Polifemo AM, Luigiano C, . Endoscopic ultrasound-guided fine needle aspiration with 22- and 25-gauge needles in solid pancreatic masses: a prospective comparative study with randomisation of needle sequence. Dig Liver Dis. 2011 Aug;43(8):647–52. PMID: 21592873.21592873
84 Carrara S, Arcidiacono PG, Mezzi G, . Pancreatic endoscopic ultrasound-guided fine needle aspiration: complication rate and clinical course in a single centre. Dig Liver Dis. 2010 Jul;42(7):520–3. PMID: 19955025.19955025
85 Eloubeidi MA, Gress FG, Savides TJ, . Acute pancreatitis after EUS-guided FNA of solid pancreatic masses: a pooled analysis from EUS centers in the United States. Gastrointest Endosc. 2004 Sep;60(3):385–9. PMID: 15332028.15332028
86 Voth M, Rosenberg M, Breuer J. Safety of Gadobutrol, a new generation of contrast agents: experience from clinical trials and postmarketing surveillance. Invest Radiol. 2011 Nov;46(11):663–71. PMID: 21623211.21623211
87 Shah-Patel LR, Piraner M, Silberzweig JE. Adverse events in a freestanding radiology office. J Am Coll Radiol. 2009 Apr;6(4):263–7. PMID: 19327659.19327659
88 Sakamoto H, Kitano M, Suetomi Y, . Utility of contrast-enhanced endoscopic ultrasonography for diagnosis of small pancreatic carcinomas. Ultrasound Med Biol. 2008 Apr;34(4):525–32. PMID: 18045768.18045768
89 Kim SH, Jo EJ, Kim MY, . Clinical value of radiocontrast media skin tests as a prescreening and diagnostic tool in hypersensitivity reaction. Ann Allergy Asthma Immunol. 2013 Apr;110(4):258–62. PMID: 23535089.23535089
90 Kobayashi D, Takahashi O, Ueda T, . Risk factors for adverse reactions from contrast agents for computed tomography. BMC Med Inform Decis Mak. 2013;13:18. PMID: 23363607.23363607
91 Davenport MS, Wang CL, Bashir MR, . Rate of contrast material extravasations and allergic-like reactions: effect of extrinsic warming of low-osmolality iodinated CT contrast material to 37 degrees. Radiology. 2012 Feb;262(2):475–84. PMID: 22106356.22106356
92 Kingston RJ, Young N, Sindhusake DP, . Study of patients with intravenous contrast extravasation on CT studies, with radiology staff and ward staff cannulation. J Med Imaging Radiat Oncol. 2012 Apr;56(2):163–7. PMID: 22498188.22498188
93 Mitchell AM, Jones AE, Tumlin JA, . Prospective study of the incidence of contrast-induced nephropathy among patients evaluated for pulmonary embolism by contrast-enhanced computed tomograph. Acad Emerg Med. 2012 Jun;19(6):618–25. PMID: 22687176.22687176
94 Vogl TJ, Wessling J, Buerke B. An observational study to evaluate the efficiency and safety of Ioversol pre-filled syringes compared with Ioversol bottles in contrast-enhanced examination. Acta Radiol. 2012 Oct 1;53(8):914–20. PMID: 22983259.22983259
95 Cadwallader RA, Walsh SR, Burrows B, . Prospective audit of cross-sectional imaging and radiation exposure in general surgical patients. Ann R Coll Surg Engl. 2011 Jan;93(1):6–8. PMID: 20955661.20955661
96 Hatakeyama S, Abe A, Suzuki T, . Clearance and safety of the radiocontrast medium Iopamidol in peritoneal dialysis patients. Int J Nephrol. 2011;2011:657051. Epub 2011 Oct 19. PMID: 22028966.22028966
97 Loh S, Bagheri S, Katzberg RW, . Delayed adverse reaction to contrast-enhanced CT: a prospective single-center study comparison to control group without enhancement. Radiology. 2010 Jun;255(3):764–71. PMID: 20406882.20406882
98 Ozbulbul NI, Yurdakul M, Tola M. Comparison of a low-osmolar contrast medium, Iopamidol, and an iso-osmolar contrast medium, Iodixanol, in MDCT coronary angiography. Coron Artery Dis. 2010 Nov;21(7):414–9. PMID: 20671550.20671550
99 Jung KE, Chung J, Park BC, . A clinical study of cutaneous adverse reactions to nonionic contrast media in Korea. Ann Dermatol. 2012 Feb;24(1):22–5. PMID: 22363151.22363151
100 Fact sheet: computed tomography (CT) scans and cancer. Bethesda, MD: National Cancer Institute (NCI); 2013 Jul 16. www.cancer.gov/cancertopics/factsheet/detection/CT. Accessed 2013 Jul 30.
101 Hucl T, Wee E, Anuradha S, . Feasibility and efficiency of a new 22G core needle: a prospective comparison study. Endoscopy. 2013;45(10):792–8.24068588
102 Iwashita T, Nakai Y, Samarasena JB, . High single-pass diagnostic yield of a new 25-gauge core biopsy needle for EUS-guided FNA biopsy in solid pancreatic lesions. Gastrointest Endosc. 2013 Jun;77(6):909–15.23433596
103 Ngamruengphong S, Xu C, Woodward TA, . Risk of gastric or peritoneal recurrence, and long-term outcomes, following pancreatic cancer resection with preoperative endosonographically guided fine needle aspiration. Endoscopy. 2013;45(8):619–26. PMID: 23881804.23881804
104 Hikichi T, Irisawa A, Bhutani MS, . Endoscopic ultrasound-guided fine-needle aspiration of solid pancreatic masses with rapid on-site cytological evaluation by endosonographers without attendance of cytopathologists. J Gastroenterol. 2009;44(4):322–8. PMID: 19274426.19274426
105 Choi ER, Jang TH, Chung YH, . A prospective comparison of liquid-based cytology and traditional smear cytology in pancreatic endoscopic ultrasound-guided fine needle aspiration. Acta Cytol. 2011 Oct;55(5):401–7.21986165
106 Bang JY, Magee SH, Ramesh J, Trevino JM, Varadarajulu S. Randomized trial comparing fanning with standard technique for endoscopic ultrasound-guided fine-needle aspiration of solid pancreatic mass lesions. Endoscopy. 2013 Mar 15;45(6):445–50. PMID: 23504490.23504490
107 Ranney N, Phadnis M, Trevino J, . Impact of biliary stents on EUS-guided FNA of pancreatic mass lesions. Gastrointest Endosc. 2012 Jul;76(1):76–83. PMID: 22726468.22726468
108 Attila T, Faigel DO. Endoscopic ultrasound in patients over 80 years old. Dig Dis Sci. 2011 Oct;56(10):3065–71. PMID: 21735087.21735087
109 Kubiliun N, Ribeiro A, Fan YS, . EUS-FNA with rescue fluorescence in situ hybridization for the diagnosis of pancreatic carcinoma in patients with inconclusive on-site cytopathology results. Gastrointest Endosc. 2011 Sep;74(3):541–7. PMID: 21752364.21752364
110 Siddiqui UD, Rossi F, Rosenthal LS, . EUS-guided FNA of solid pancreatic masses: a prospective, randomized trial comparing 22-gauge and 25-gauge needles. Gastrointest Endosc. 2009 Dec;70(6):1093–7. PMID: 19640524.19640524
111 Ramirez-Luna MA, Zepeda-Gomez S, Chavez-Tapia NC, . Diagnostic yield and therapeutic impact of fine-needle aspiration biopsies guided by endoscopic ultrasound in pancreatic lesions. Rev Invest Clin. 2008 Jan–Feb;60(1):11–4. PMID: 18589582.18589582
112 Wittmann J, Kocjan G, Sgouros SN, . Endoscopic ultrasound-guided tissue sampling by combined fine needle aspiration and trucut needle biopsy: a prospective study. Cytopathology. 2006 Feb;17(1):27–33. PMID: 16417562.16417562
113 Ryozawa S, Kitoh H, Gondo T, . Usefulness of endoscopic ultrasound-guided fine-needle aspiration biopsy for the diagnosis of pancreatic cancer. J Gastroenterol. 2005 Sep;40(9):907–11. PMID: 16211348.16211348
114 Reddymasu SC, Gupta N, Singh S, . Pancreato-biliary malignancy diagnosed by endoscopic ultrasonography in absence of a mass lesion on transabdominal imaging: Prevalence and predictors. Dig Dis Sci. 2011 Jun;56(6):1912–16.21188524
115 Fritscher-Ravens A, Sriram PVJ, Krause C, . Detection of pancreatic metastases by EUS-guided fine-needle aspiration. Gastrointest Endosc. 2001;53(1):65–70.11154491
116 Katanuma A, Maguchi H, Yane K, . Factors predictive of adverse events associated with endoscopic ultrasound-guided fine needle aspiration of pancreatic solid lesions. Dig Dis Sci. 2013 Jul;58(7):2093–9. Epub 2013 Feb 20. PMID: 23423501.23423501
117 Choi JH, Lee KH, Kim KM, . A prospective, comparative trial to optimize sampling techniques in EUS-guided FNA of solid pancreatic masses. Gastrointest Endosc. 2013 May;77(5):745–51.23433878
118 Lee KT, Choi ER, Jang TH, . A prospective, randomized trial comparing 25-gauge and 22-gauge needles for endoscopic ultrasound-guided fine needle aspiration of pancreatic masses. Scand J Gastroenterol. 2013 Jun;48(6):752–7.23600919
119 Ikezawa K, Uehara H, Sakai A, Fukutake N, Imanaka K, Ohkawa K, Tanakura R, Ioka T, Tanaka S, Ishikawa O, Katayama K. Risk of peritoneal carcinomatosis by endoscopic ultrasound-guided fine needle aspiration for pancreatic cancer. J Gastroenterol. 2013 Aug;48(8):966–72. Epub 2012 Oct 13. PMID: 23065024.23065024
120 Siddiqui AA, Fein M, Kowalski TE, . Comparison of the influence of plastic and fully covered metal biliary stents on the accuracy of EUS-FNA for the diagnosis of pancreatic cancer. Dig Dis Sci. 2012 Sep;57(9):2438–45. PMID: 22526586.22526586
121 Beane JD, House MG, Cote GA, . Outcomes after preoperative endoscopic ultrasonography and biopsy in patients undergoing distal pancreatectomy. Surgery. 2011 Oct;150(4):844–53. PMID: 22000199.22000199
122 Kopelman Y, Marmor S, Ashkenazi I, . Value of EUS-FNA cytological preparations compared with cell block sections in the diagnosis of pancreatic solid tumours. Cytopathology. 2011 Jun;22(3):174–8. PMID: 20482717.20482717
123 Fisher L, Segarajasingam DS, Stewart C, . Endoscopic ultrasound guided fine needle aspiration of solid pancreatic lesions: Performance and outcomes. J Gastroenterol Hepatol. 2009 Jan;24(1):90–6. PMID: 19196396.19196396
124 Eloubeidi MA, Varadarajulu S, Desai S, . A prospective evaluation of an algorithm incorporating routine preoperative endoscopic ultrasound-guided fine needle aspiration in suspected pancreatic cancer. J Gastrointest Surg. 2007 Jul;11(7):813–9. PMID: 17440790.17440790
125 Mahnke D, Chen YK, Antillon MR, . A prospective study of complications of endoscopic retrograde cholangiopancreatography and endoscopic ultrasound in an ambulatory endoscopy center. Clin Gastroenterol Hepatol. 2006 Jul;4(7):924–30. PMID: 16797251.16797251
126 Bournet B, Migueres I, Delacroix M, . Early morbidity of endoscopic ultrasound: 13 years’ experience at a referral center. Endoscopy. 2006 Apr;38(4):349–54. PMID: 16680633.16680633
127 Mortensen MB, Fristrup C, Holm FS, . Prospective evaluation of patient tolerability, satisfaction with patient information, and complications in endoscopic ultrasonography. Endoscopy. 2005 Feb;37(2):146–53. PMID: 15692930.15692930
128 Gress F, Michael H, Gelrud D, . EUS-guided fine-needle aspiration of the pancreas: evaluation of pancreatitis as a complication. Gastrointest Endosc. 2002 Dec;56(6):864–7. PMID: 12447299.12447299
129 Harewood GC, Wiersema MJ. Endosonography-guided fine needle aspiration biopsy in the evaluation of pancreatic masses. Am J Gastroenterol. 2002 Jun;97(6):1386–91. PMID: 12094855.12094855
130 O’Toole D, Palazzo L, Arotcarena R, . Assessment of complications of EUS-guided fine-needle aspiration. Gastrointest Endosc. 2001 Apr;53(4):470–4. PMID: 11275888.11275888
131 Gress F, Gottlieb K, Sherman S, . Endoscopic ultrasonography-guided fine-needle aspiration biopsy of suspected pancreatic cancer. Ann Intern Med. 2001 Mar 20;134(6):459–64. PMID: 1125552111255521
132 Voss M, Hammel P, Molas G, . Value of endoscopic ultrasound guided fine needle aspiration biopsy in the diagnosis of solid pancreatic masses. Gut. 2000 Feb;46(2):244–9. PMID: 10644320.10644320
133 Iglesias-Garcia J, Dominguez-Munoz JE, Abdulkader I, . Influence of on-site cytopathology evaluation on the diagnostic accuracy of endoscopic ultrasound-guided fine needle aspiration (EUS-FNA) of solid pancreatic masses. Am J Gastroenterol. 2011 Sep;106(9):1705–10.21483464
134 Fisher JM, Gordon SR, Gardner TB. The impact of prior biliary stenting on the accuracy and complication rate of endoscopic ultrasound fine-needle aspiration for diagnosing pancreatic adenocarcinoma. Pancreas. 2011 Jan;40(1):21–4.20881899
135 Yusuf TE, Ho S, Pavey DA, . Retrospective analysis of the utility of endoscopic ultrasound-guided fine-needle aspiration (EUS-FNA) in pancreatic masses, using a 22-gauge or 25-gauge needle system: a multicenter experience. Endoscopy. 2009 May;41(5):445–8.19418399
136 Chang YH, Sang SL, Tae JS, . Endoscopic ultrasound guided fine needle aspiration biopsy in diagnosis of pancreatic and peripancreatic lesions: a single center experience in Korea. Gut Liver. 2009 Jun;3(2):116–21.20431733
137 Eloubeidi MA, Tamhane A. Prospective assessment of diagnostic utility and complications of endoscopic ultrasound-guided fine needle aspiration. Results from a newly developed academic endoscopic ultrasound program. Dig Dis. 2008;26(4):356–63. PMID: 19188728.19188728
138 Eloubeidi MA, Tamhane A, Varadarajulu S, . Frequency of major complications after EUS-guided FNA of solid pancreatic masses: a prospective evaluation. Gastrointest Endosc. 2006 Apr;63(4):622–9. PMID: 16564863.16564863
139 Eloubeidi MA, Tamhane A. EUS-guided FNA of solid pancreatic masses: a learning curve with 300 consecutive procedures. Gastrointest Endosc. 2005 May;61(6):700–8. PMID: 15855975.15855975
140 Eloubeidi MA, Chen VK, Eltoum IA, . Endoscopic ultrasound-guided fine needle aspiration biopsy of patients with suspected pancreatic cancer: diagnostic accuracy and acute and 30-day complications. Am J Gastroenterol. 2003 Dec;98(12):2663–8. PMID: 14687813.14687813
141 Varadarajulu S, Tamhane A, Eloubeidi MA. Yield of EUS-guided FNA of pancreatic masses in the presence or the absence of chronic pancreatitis. Gastrointest Endosc. 2005 Nov;62(5):728–36.16246688
142 Kliment M, Urban O, Cegan M, . Endoscopic ultrasound-guided fine needle aspiration of pancreatic masses: the utility and impact on management of patients. Scand J Gastroenterol. 2010 Nov;45(11):1372–9. PMID: 20626304.20626304
143 Shah SM, Ribeiro A, Levi J, . EUS-guided fine needle aspiration with and without trucut biopsy of pancreatic masses. JOP. 2008;9(4):422–30. PMID: 1864813318648133
144 Zamboni GA, D’Onofrio M, Idili A, . Ultrasound-guided percutaneous fine-needle aspiration of 545 focal pancreatic lesion. AJR Am J Roentgenol. 2009 Dec;193(6):1691–5.19933666
145 Al-Haddad M, Wallace MB, Woodward TA, . The safety of fine-needle aspiration guided by endoscopic ultrasound: a prospective study. Endoscopy. 2008 Mar;40(3):204–8.18058615
146 Hayashi T, Ishiwatari H, Yoshida M, Ono M, Sato T, Miyanishi K, Sato Y, Kobune M, Takimoto R, Mitsuhashi T, Asanuma H, Ogino J, Hasegawa T, Sonoda T, Kato J. Rapid on-site evaluation by endosonographer during endoscopic ultrasound-guided fine needle aspiration for pancreatic solid masses. J Gastroenterol Hepatol. 2013 Apr;28(4):656–63. PMID: 23301574.23301574
147 Ootaki C, Stevens T, Vargo J, . Does general anesthesia increase the diagnostic yield of endoscopic ultrasound-guided fine needle aspiration of pancreatic masses. Anesthesiology. 2012 Nov;117(5):1044–50. PMID: 23042221.23042221
148 Itoi T, Tsuchiya T, Itokawa F, . Histological diagnosis by EUS-guided fine-needle aspiration biopsy in pancreatic solid masses without on-site cytopathologist: a single-center experience. Dig Endosc. 2011 May;23: Suppl 1:34–8. PMID: 21535198.21535198
149 Rocca R, De Angelis C, Daperno M, . Endoscopic ultrasound-fine needle aspiration (EUS-FNA) for pancreatic lesions: effectiveness in clinical practice. Dig Liver Dis. 2007 Aug;39(8):768–74. PMID: 17606420.17606420
150 Cote GA, Hovis RM, Ansstas MA, . Incidence of sedation-related complications with Propofol use during advanced endoscopic procedures. Clin Gastroenterol Hepatol. 2010 Feb;8(2):137–42. PMID: 19607937.19607937
151 Schilling D, Rosenbaum A, Schweizer S, . Sedation with Propofol for interventional endoscopy by trained nurses in high-risk octogenarians: a prospective, randomized, controlled study. Endoscopy. 2009 Apr;41(4):295–8. PMID: 19340730.19340730
152 Kalaitzakis E, Varytimiadis K, Meenan J. Predicting what can go wrong at endoscopic ultrasound: a large series experience. Frontline Gastroenterol. 2011 Apr;2(2):110–6.28839592
153 Niv Y, Gershtansky Y, Kenett RS, . Complications in endoscopic retrograde cholangiopancreatography (ERCP) and endoscopic ultrasound (EUS): analysis of 7-year physician-reported adverse events. Drug Healthc Patient Saf. 2011;3:21–5. PMID: 21753900.21753900
154 Eloubeidi MA, Tamhane A, Lopes TL, . Cervical esophageal perforations at the time of endoscopic ultrasound: a prospective evaluation of frequency, outcomes, and patient management. Am J Gastroenterol. 2009 Jan;104(1):53–6. PMID: 19098849.19098849
155 Jenssen C, Alvarez-Sanchez MV, Napoleon B, . Diagnostic endoscopic ultrasonography: assessment of safety and prevention of complication. World J Gastroenterol. 2012 Sep 14;18(34):4659–76. PMID: 23002335.23002335
156 Semelka RC, Hernandes Mde A, Stallings CG, . Objective evaluation of acute adverse events and image quality of Gadolinium-based contrast agents (Gadobutrol and Gadobenate Dimeglumine) by blinded evaluation. Pilot study. Magn Reson Imaging. 2013 Jan;31(1):96–101. PMID: 22898688.22898688
157 Albiin N, Kartalis N, Bergquist A, . Manganese chloride tetrahydrate (CMC-001) enhanced liver MRI: evaluation of efficacy and safety in healthy volunteer. MAGMA. 2012 Oct;25(5):361–8. PMID: 22399275.22399275
158 Maurer M, Heine O, Wolf M, . Tolerability and diagnostic value of Gadoteric Acid in the general population and in patients with risk factors: results in more than 84,000 patients. Eur J Radiol. 2012 May;81(5):885–90. PMID: 21555197.21555197
159 Forsting M, Palkowitsch P. Prevalence of acute adverse reactions to Gadobutrol-a highly concentrated macrocyclic Gadolinium chelate: review of 14,299 patients from observational trials. Eur J Radiol. 2010 Jun;74(3):e186–92. PMID: 19574008.19574008
160 Ichikawa T, Saito K, Yoshioka N, . Detection and characterization of focal liver lesions: a Japanese phase III, multicenter comparison between gadoxetic acid disodium-enhanced magnetic resonance imaging and contrast-enhanced computed tomography predominantly in patients with hepatocellular carcinoma and chronic liver disease. Invest Radiol. 2010 Mar;45(3):133–41. PMID: 20098330.20098330
161 Ishiguchi T, Takahashi S. Safety of Gadoterate Meglumine (Gd-DOTA) as a contrast agent for magnetic resonance imaging: results of a post-marketing surveillance study in Japan. Drugs R D. 2010;10(3):133–45. PMID: 20945944.20945944
162 Leander P, Golman K, Mansson S, . Orally administered Manganese with and without Ascorbic Acid as a liver-specific contrast agent and bowel marker for magnetic resonance imaging: phase I clinical trial assessing efficacy and safety. Invest Radiol. 2010 Sep;45(9):559–64. PMID: 20644487.20644487
163 Hammerstingl R, Adam G, Ayuso JR, . Comparison of 1.0 M Gadobutrol and 0.5 m Gadopentetate Dimeglumine-enhanced magnetic resonance imaging in five hundred seventy-two patients with known or suspected liver lesions. Invest Radiol. 2009 Mar;44(3):168–76. PMID: 19169143.19169143
164 Bredart A, Kop JL, Fall M, . Perception of care and experience of examination in women at risk of breast cancer undergoing intensive surveillance by standard imaging with or without MR. Patient Educ Couns. 2012 Mar;86(3):405–13. PMID: 21795009.21795009
165 Chang Y, Lee GH, Kim TJ, . Toxicity of magnetic resonance imaging agents: small molecule and nanoparticle. Curr Top Med Chem. 2013;13(4):434–45. PMID: 23432006.23432006
166 American College of Radiology. ACR manual on contrast media [version 9]. Reston, VA: American College of Radiology; 2013. 128 p.
167 Thomsen HS. Nephrogenic systemic fibrosis. Imaging Decis. 2008 Mar 21;11(4):13–18.
168 FDA drug safety communication: new warnings for using Gadolinium-based contrast agents in patients with kidney dysfunction. Silver Spring, MD: U.S. Food and Drug Administration; 2010 Dec 23. www.fda.gov/Drugs/DrugSafety/ucm223966.htm. Accessed 2013 Jul 29.
169 Public health advisory - Gadolinium-containing contrast agents for magnetic resonance imaging (MRI). Silver Spring, MD: U.S. Food and Drug Administration; 2006 Jun 8. www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/DrugSafetyInformationforHeathcareProfessionals/PublicHealthAdvisories/ucm053112.htm. Accessed 2013 Jul 29.
170 FDA requests boxed warning for contrast agents used to improve MRI images. Silver Spring, MD: U.S. Food and Drug Administration; 2007 May 23. www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/2007/ucm108919.htm. Accessed 2013 Jul 29.
171 Harinck F, Nagtegaal T, Kluijt I, . Feasibility of a pancreatic cancer surveillance program from a psychological point of view. Genet Med. 2011 Dec;13(12):1015–24. PMID: 21857231.21857231
172 Vasen HF, Wasser M, van Mil A, . Magnetic resonance imaging surveillance detects early-stage pancreatic cancer in carriers of a p16-Leiden mutation. Gastroenterology. 2011 Mar;140(3):850–6. PMID: 21129377.21129377
173 Canto MI, Hruban RH, Fishman EK, . Frequent detection of pancreatic lesions in asymptomatic high-risk individuals. Gastroenterology. 2012 Apr;142(4):796–804; quiz e14–5. PMID: 22245846.22245846
174 Verna EC, Hwang C, Stevens PD, . Pancreatic cancer screening in a prospective cohort of high-risk patients: a comprehensive strategy of imaging and genetics. Clin Cancer Res. 2010 Oct 15;16(20):5028–37. PMID: 20876795.20876795
175 Canto MI, Goggins M, Hruban RH, . Screening for early pancreatic neoplasia in high-risk individuals: a prospective controlled study. Clin Gastroenterol Hepatol. 2006 Jun;4(6):766–81.16682259
176 Langer P, Kann PH, Fendrich V, . Five years of prospective screening of high-risk individuals from families with familial pancreatic cancer. Gut. 2009 Oct;58(10):1410–8. PMID: 19470496.19470496
177 Al-Sukhni W, Borgida A, Rothenmund H, . Screening for pancreatic cancer in a high-risk cohort: an eight-year experience. J Gastrointest Surg. 2012 Apr;16(4):771–83. PMID: 22127781.22127781
178 Wang KX, Ben QW, Jin ZD, . Assessment of morbidity and mortality associated with EUS-guided FNA: a systematic review. Gastrointest Endosc. 2011 Feb;73(2):283–90.21295642
179 Health policies and data: OECD health data. Paris: Organisation for Economic Co-operation and Development (OECD); 2013 Jun 27. www.oecd.org/health/health-systems/oecdhealthdata.htm. Accessed 2013 Oct 23.
180 Buck AK, Herrmann K, Stargardt T, . Economic evaluation of PET and PET/CT in oncology: evidence and methodologic approaches. J Nucl Med Technol. 2010 Mar;38(1):6–17. PMID: 20197541.20197541
181 Brand RE, Lerch MM, Rubinstein WS, . Advances in counselling and surveillance of patients at risk for pancreatic cancer. Gut. 2007 Oct;56(10):1460–9. PMID: 17872573.17872573
182 Ahlawat SK. Lymphoepithelial cyst of pancreas. Role of endoscopic ultrasound guided fine needle aspiration. JOP. 2008;9(2):230–4. PMID: 18326936.18326936
183 Canto MI, Harinck F, Hruban RH, . International cancer of the pancreas screening (CAPS) consortium summit on the management of patients with increased risk for familial pancreatic cancer. Gut. 2013 Mar;62(3):339–47.23135763
184 Bilimoria KY, Bentrem DJ, Tomlinson JS, . Quality of pancreatic cancer care at Veterans Administration compared with non-Veterans Administration hospitals. Am J Surg. 2007 Nov;194(5):588–93. PMID: 17936418.17936418
185 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Rockville, MD: Agency for Healthcare Research and Quality; 2011 Jun. 79 p. (Methods future research needs report; no. 2). www.effectivehealthcare.ahrq.gov.