# Acknowledgments

We greatly appreciate the assistance of numerous ECRI Institute–Penn Medicine EPC employees including Eloise DeHaan (copyediting), Lydia Dharia (document formatting, reference list generation and reference formatting), Helen Dunn (document retrieval, database organization), Gina Giradi (conference call planning, conference call note-taking, project management), Allison Gross (literature search), Janice Kaczmarek (project management), Tracy Monastero-Stem (document retrieval), and Craig Umscheid (recruiting clinical coauthors, key informants, and technical experts and reviewing the protocol and portions of the final draft).