# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Task Order Officer (TOO) and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Jeffrey A. Drebin, M.D., Ph.D., FACS
  Chair, Department of Surgery
  University of Pennsylvania Perelman School of Medicine
  Philadelphia, PA
- Elliot K. Fishman, M.D., FACR
  Professor of Radiology, Surgery and Oncology
  Director, Diagnostic Imaging and Body CT
  Johns Hopkins Hospital
  Baltimore, MD
- Matthew H.G. Katz, M.D., FACS
  Assistant Professor, Department of Surgical Oncology
  The University of Texas MD Anderson Cancer Center
  Houston, TX
- Michael L. Kochman, M.D., FACP
  Wilmott Family Professor of Medicine
  Vice-Chair of Medicine for Clinical Services Center for Endoscopic Innovation, Research, and Training Gastroenterology Division University of Pennsylvania Health System
  Philadelphia, PA
- Eileen M. O’Reilly, M.D.
  Medical Oncologist
  Memorial Sloan Kettering Cancer Center
  New York, NY
- Dushyant V. Sahani, M.D.
  Radiologist
  Massachusetts General Hospital
  Boston, MA
- Margaret Tempero, M.D.
  Director, University of California, San Francisco Pancreas Center
  Helen Diller Family Comprehensive Cancer Center
  San Francisco, CA