# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Elliot K. Fishman, M.D., FACR
  Professor of Radiology, Surgery and Oncology
  Director, Diagnostic Imaging and Body CT
  Johns Hopkins Hospital
  Baltimore, MD
- Juliet Jegasothy, M.D.
  Medical Advisor, Department of Medical Management
  University of Pittsburgh Medical Center Health Plan
  Pittsburgh, PA
- Michael L. Kochman, M.D., FACP
  Wilmott Family Professor of Medicine
  Vice-Chair of Medicine for Clinical Services Center for Endoscopic Innovation, Research, and Training Gastroenterology Division University of Pennsylvania Health System
  Philadelphia, PA
- Jeffrey E. Lee, M.D.
  Department Chair, Department of Surgical Oncology
  The University of Texas MD Anderson Cancer Center
  Houston, TX
- Evan Siegelman, M.D.
  Associate Professor of Radiology
  Chief, MRI Section
  Hospital of the University of Pennsylvania
  Philadelphia, PA
- Anitra Talley
  Director of Patient Services and Medical Relations
  Pancreatic Cancer Action Network
  Manhattan Beach, CA
- Margaret Tempero, M.D.
  Director, University of California, San Francisco Pancreas Center
  Helen Diller Family Comprehensive Cancer Center
  San Francisco, CA