# Appendix F Appendix References

1 Affolter KE, Schmidt RL, Matynia AP, . Needle size has only a limited effect on outcomes in EUS-guided fine needle aspiration: a systematic review and meta-analysis. Dig Dis Sci. 2013 Apr;58(4):1026–34. PMID: 2308611723086117
2 Chen G, Liu S, Zhao Y, . Diagnostic accuracy of endoscopic ultrasound-guided fine-needle aspiration for pancreatic cancer: a meta-analysis. Pancreatology. 2013 May–Jun;13(3):298–304. PMID: 2371960423719604
3 Hebert-Magee S, Bae S, Varadarajulu S, . The presence of a cytopathologist increases the diagnostic accuracy of endoscopic ultrasound-guided fine needle aspiration cytology for pancreatic adenocarcinoma: a meta-analysis. Cytopathology. 2013 Jun;24(3):159–71. PMID: 2371118223711182
4 Madhoun MF, Wani SB, Rastogi A, . The diagnostic accuracy of 22-gauge and 25-gauge needles in endoscopic ultrasound-guided fine needle aspiration of solid pancreatic lesions: a meta-analysis. Endoscopy. 2013;45(2):86–92. PMID: 2330714823307148
5 Wang Z, Chen JQ, Liu JL, . FDG-PET in diagnosis, staging and prognosis of pancreatic carcinoma: a meta-analysis. World J Gastroenterol. 2013 Aug 7;19(29):4808–17.23922481
6 Puli SR, Bechtold ML, Buxbaum JL, . How good is endoscopic ultrasound-guided fine-needle aspiration in diagnosing the correct etiology for a solid pancreatic mass? A meta-analysis and systematic review. Pancreas. 2013 Jan;42(1):20–6. PMID: 2325491323254913
7 Chen J, Yang R, Lu Y, . Diagnostic accuracy of endoscopic ultrasound-guided fine-needle aspiration for solid pancreatic lesion: a systematic review. J Cancer Res Clin Oncol. 2012 Sep;138(9):1433–41. PMID: 2275260122752601
8 Hewitt MJ, McPhail MJW, Possamai L, . EUS-guided FNA for diagnosis of solid pancreatic neoplasms: A meta-analysis. Gastrointest Endosc. 2012 Feb;75(2):319–31.22248600
9 Wu LM, Hu JN, Hua J, . Diagnostic value of diffusion-weighted magnetic resonance imaging compared with Fluorodeoxyglucose positron emission tomography/computed tomography for pancreatic malignancy: a meta-analysis using a hierarchical regression model. J Gastroenterol Hepatol. 2012 Jun;27(6):1027–35. PMID: 2241409222414092
10 Wu LM, Xu JR, Hua J, . Value of diffusion-weighted imaging for the discrimination of pancreatic lesions: a meta-analysis. Eur J Gastroenterol Hepatol. 2012 Feb;24(2):134–42. PMID: 2224121522241215
11 Tang S, Huang G, Liu J, . Usefulness of 18F-FDG PET, combined FDG-PET/CT and EUS in diagnosing primary pancreatic carcinoma: a meta-analysis. Eur J Radiol. 2011 Apr;78(1):142–50. PMID: 1985401619854016
12 Hartwig W, Schneider L, Diener MK, . Preoperative tissue diagnosis for tumours of the pancreas. Br J Surg. 2009 Jan;96(1):5–20. PMID: 1901627219016272
13 Bipat S, Phoa SS, van Delden OM, . Ultrasonography, computed tomography and magnetic resonance imaging for diagnosis and determining resectability of pancreatic adenocarcinoma: a meta-analysis. J Comput Assist Tomogr. 2005 Jul–Aug;29(4):438–45. PMID: 1601229716012297
14 Li AE, Li BT, Ng BH, . Diagnostic accuracy of imaging modalities in the evaluation of vascular invasion in pancreatic adenocarcinoma: a meta-analysis. World J Oncol. 2013 Apr;4(2):74–82.29147335
15 Zhao WY, Luo M, Sun YW, . Computed tomography in diagnosing vascular invasion in pancreatic and periampullary cancers: a systematic review and meta-analysis. Hepatobiliary Pancreat Dis Int. 2009 Oct;8(5):457–64. PMID: 1982248719822487
16 Fang CH, Zhu W, Wang H, . A new approach for evaluating the resectability of pancreatic and periampullary neoplasms. Pancreatology. 2012 Jul–Aug;12(4):364–71. PMID: 2289863922898639
17 Herrmann K, Erkan M, Dobritz M, . Comparison of 3’-deoxy-3’-[18F]fluorothymidine positron emission tomography (FLT PET) and FDG PET/CT for the detection and characterization of pancreatic tumours. Eur J Nucl Med Mol Imaging. 2012 May;39(5):846–51. PMID: 2227832022278320
18 Tellez-Avila FI, Chavez-Tapia NC, Lopez-Arce G, . Vascular invasion in pancreatic cancer: predictive values for endoscopic ultrasound and computed tomography imaging. Pancreas. 2012 May;41(4):636–8. PMID: 2246072722460727
19 Holzapfel K, Reiser-Erkan C, Fingerle AA, . Comparison of diffusion-weighted MR imaging and multidetector-row CT in the detection of liver metastases in patients operated for pancreatic cancer. Abdom Imaging. 2011 Apr;36(2):179–84. PMID: 2056386820563868
20 Koelblinger C, Ba-Ssalamah A, Goetzinger P, . Gadobenate Dimeglumine-enhanced 3.0-T MR imaging versus multiphasic 64-detector row CT: prospective evaluation in patients suspected of having pancreatic cancer. Radiology. 2011 Jun;259(3):757–66. PMID: 2143608421436084
21 Motosugi U, Ichikawa T, Morisaka H, . Detection of pancreatic carcinoma and liver metastases with Gadoxetic Acid-enhanced MR imaging: comparison with contrast-enhanced multi-detector row CT. Radiology. 2011 Aug;260(2):446–53. PMID: 2169366221693662
22 Rao SX, Zeng MS, Cheng WZ, . Small solid tumors (< or = 2 cm) of the pancreas: relative accuracy and differentiation of CT and MR imaging. Hepatogastroenterology. 2011 May–Jun;58(107–108):996–1001. PMID: 2183043121830431
23 Shami VM, Mahajan A, Loch MM, . Comparison between endoscopic ultrasound and magnetic resonance imaging for the staging of pancreatic cancer. Pancreas. 2011 May;40(4):567–70. PMID: 2149921121499211
24 Takakura K, Sumiyama K, Munakata K, . Clinical usefulness of diffusion-weighted MR imaging for detection of pancreatic cancer: comparison with enhanced multidetector-row CT. Abdom Imaging. 2011 Aug;36(4):457–62. PMID: 2164393921643939
25 Imai H, Doi R, Kanazawa H, . Preoperative assessment of para-aortic lymph node metastasis in patients with pancreatic cancer. Int J Clin Oncol. 2010 Jun;15(3):294–300.20232101
26 Lee JK, Kim AY, Kim PN, . Prediction of vascular involvement and resectability by multidetector-row CT versus MR imaging with MR angiography in patients who underwent surgery for resection of pancreatic ductal adenocarcinoma. Eur J Radiol. 2010 Feb;73(2):310–6. PMID: 1907098119070981
27 Kauhanen SP, Komar G, Seppanen MP, . A prospective diagnostic accuracy study of 18F-fluorodeoxyglucose positron emission tomography/computed tomography, multidetector row computed tomography, and magnetic resonance imaging in primary diagnosis and staging of pancreatic cancer. Ann Surg. 2009 Dec;250(6):957–63. PMID: 1968773619687736
28 Farma JM, Santillan AA, Melis M, . PET/CT fusion scan enhances CT staging in patients with pancreatic neoplasms. Ann Surg Oncol. 2008 Sep;15(9):2465–71. PMID: 1855134718551347
29 Saif MW, Cornfeld D, Modarresifar H, . 18F-FDG positron emission tomography CT (FDG PET-CT) in the management of pancreatic cancer: initial experience in 12 patients. J Gastrointest Liver Dis. 2008 Jun;17(2):173–8. PMID: 1856813818568138
30 Schick V, Franzius C, Beyna T, . Diagnostic impact of 18F-FDG PET-CT evaluating solid pancreatic lesions versus endosonography, endoscopic retrograde cholangio-pancreatography with intraductal ultrasonography and abdominal ultrasound. Eur J Nucl Med Mol Imaging. 2008 Oct;35(10):1775–85. PMID: 1848106318481063
31 Casneuf V, Delrue L, Kelles A, . Is combined 18F-fluorodeoxyglucose-positron emission tomography/computed tomography superior to positron emission tomography or computed tomography alone for diagnosis, staging and restaging of pancreatic lesions. Acta Gastroenterol Belg. 2007 Oct–Dec;70(4):331–8. PMID: 183300818330088
32 Tamm EP, Loyer EM, Faria SC, . Retrospective analysis of dual-phase MDCT and follow-up EUS/EUS-FNA in the diagnosis of pancreatic cancer. Abdom Imaging. 2007 Sep–Oct;32(5):660–7. PMID: 1771258917712589
33 Mehmet Erturk S, Ichikawa T, Sou H, . Pancreatic adenocarcinoma: MDCT versus MRI in the detection and assessment of locoregional extension. J Comput Assist Tomogr. 2006 Jul–Aug;30(4):583–90. PMID: 1684528816845288
34 Heinrich S, Goerres GW, Schafer M, . Positron emission tomography/computed tomography influences on the management of resectable pancreatic cancer and its cost-effectiveness. Ann Surg. 2005 Aug;242(2):235–43.16041214
35 Agarwal B, Abu-Hamda E, Molke KL, . Endoscopic ultrasound-guided fine needle aspiration and multidetector spiral CT in the diagnosis of pancreatic cancer. Am J Gastroenterol. 2004 May;99(5):844–50.15128348
36 DeWitt J, Devereaux B, Chriswell M, . Comparison of endoscopic ultrasonography and multidetector computed tomography for detecting and staging pancreatic cancer. Ann Intern Med. 2004 Nov 16;141(10):753–63. PMID: 1554567515545675
37 Lemke AJ, Niehues SM, Hosten N, . Retrospective digital image fusion of multidetector CT and 18F-FDG PET: Clinical value in pancreatic lesions - A prospective study with 104 patients. J Nucl Med. 2004 Aug 1;45(8):1279–86.15299049
38 Soriano A, Castells A, Ayuso C, . Preoperative staging and tumor resectability assessment of pancreatic cancer: prospective study comparing endoscopic ultrasonography, helical computed tomography, magnetic resonance imaging, and angiography. Am J Gastroenterol. 2004 Mar;99(3):492–501. PMID: 1505609115056091
39 Rieber A, Tomczak R, Nussle K, . MRI with Mangafodipir Trisodium in the detection of pancreatic tumours: comparison with helical CT. Br J Radiol. 2000 Nov;73(875):1165–9. PMID: 1114479311144793
40 Newcombe RG. Two-sided confidence intervals for the single proportion: comparison of seven methods. Stat Med. 1998 Apr 30;17(8):857–72. PMID: 95956169595616
41 Bang JY, Magee SH, Ramesh J, Trevino JM, Varadarajulu S. Randomized trial comparing fanning with standard technique for endoscopic ultrasound-guided fine-needle aspiration of solid pancreatic mass lesions. Endoscopy. 2013 Mar 15;45(6):445–50. PMID: 2350449023504490
42 Hayashi T, Ishiwatari H, Yoshida M, Ono M, Sato T, Miyanishi K, Sato Y, Kobune M, Takimoto R, Mitsuhashi T, Asanuma H, Ogino J, Hasegawa T, Sonoda T, Kato J. Rapid on-site evaluation by endosonographer during endoscopic ultrasound-guided fine needle aspiration for pancreatic solid masses. J Gastroenterol Hepatol. 2013 Apr;28(4):656–63. PMID: 2330157423301574
43 Hucl T, Wee E, Anuradha S, . Feasibility and efficiency of a new 22G core needle: a prospective comparison study. Endoscopy. 2013;45(10):792–8.24068588
44 Iwashita T, Nakai Y, Samarasena JB, . High single-pass diagnostic yield of a new 25-gauge core biopsy needle for EUS-guided FNA biopsy in solid pancreatic lesions. Gastrointest Endosc. 2013 Jun;77(6):909–15.23433596
45 Katanuma A, Maguchi H, Yane K, . Factors predictive of adverse events associated with endoscopic ultrasound-guided fine needle aspiration of pancreatic solid lesions. Dig Dis Sci. 2013 Jul;58(7):2093–9. Epub 2013 Feb 20. PMID: 2342350123423501
46 Choi JH, Lee KH, Kim KM, . A prospective, comparative trial to optimize sampling techniques in EUS-guided FNA of solid pancreatic masses. Gastrointest Endosc. 2013 May;77(5):745–51.23433878
47 Lee KT, Choi ER, Jang TH, . A prospective, randomized trial comparing 25-gauge and 22-gauge needles for endoscopic ultrasound-guided fine needle aspiration of pancreatic masses. Scand J Gastroenterol. 2013 Jun;48(6):752–7.23600919
48 Ngamruengphong S, Xu C, Woodward TA, . Risk of gastric or peritoneal recurrence, and long-term outcomes, following pancreatic cancer resection with preoperative endosonographically guided fine needle aspiration. Endoscopy. 2013;45(8):619–26. PMID: 2388180423881804
49 Ikezawa K, Uehara H, Sakai A, Fukutake N, Imanaka K, Ohkawa K, Tanakura R, Ioka T, Tanaka S, Ishikawa O, Katayama K. Risk of peritoneal carcinomatosis by endoscopic ultrasound-guided fine needle aspiration for pancreatic cancer. J Gastroenterol. 2013 Aug;48(8):966–72. Epub 2012 Oct 13. PMID: 2306502423065024
50 Ootaki C, Stevens T, Vargo J, . Does general anesthesia increase the diagnostic yield of endoscopic ultrasound-guided fine needle aspiration of pancreatic masses. Anesthesiology. 2012 Nov;117(5):1044–50. PMID: 2304222123042221
51 Ranney N, Phadnis M, Trevino J, . Impact of biliary stents on EUS-guided FNA of pancreatic mass lesions. Gastrointest Endosc. 2012 Jul;76(1):76–83. PMID: 2272646822726468
52 Siddiqui AA, Fein M, Kowalski TE, . Comparison of the influence of plastic and fully covered metal biliary stents on the accuracy of EUS-FNA for the diagnosis of pancreatic cancer. Dig Dis Sci. 2012 Sep;57(9):2438–45. PMID: 2252658622526586
53 Attila T, Faigel DO. Endoscopic ultrasound in patients over 80 years old. Dig Dis Sci. 2011 Oct;56(10):3065–71. PMID: 2173508721735087
54 Beane JD, House MG, Cote GA, . Outcomes after preoperative endoscopic ultrasonography and biopsy in patients undergoing distal pancreatectomy. Surgery. 2011 Oct;150(4):844–53. PMID: 2200019922000199
55 Choi ER, Jang TH, Chung YH, . A prospective comparison of liquid-based cytology and traditional smear cytology in pancreatic endoscopic ultrasound-guided fine needle aspiration. Acta Cytol. 2011 Oct;55(5):401–7.21986165
56 Fabbri C, Polifemo AM, Luigiano C, . Endoscopic ultrasound-guided fine needle aspiration with 22- and 25-gauge needles in solid pancreatic masses: a prospective comparative study with randomisation of needle sequence. Dig Liver Dis. 2011 Aug;43(8):647–52. PMID: 2159287321592873
57 Fisher JM, Gordon SR, Gardner TB. The impact of prior biliary stenting on the accuracy and complication rate of endoscopic ultrasound fine-needle aspiration for diagnosing pancreatic adenocarcinoma. Pancreas. 2011 Jan;40(1):21–4.20881899
58 Iglesias-Garcia J, Dominguez-Munoz JE, Abdulkader I, . Influence of on-site cytopathology evaluation on the diagnostic accuracy of endoscopic ultrasound-guided fine needle aspiration (EUS-FNA) of solid pancreatic masses. Am J Gastroenterol. 2011 Sep;106(9):1705–10.21483464
59 Itoi T, Tsuchiya T, Itokawa F, . Histological diagnosis by EUS-guided fine-needle aspiration biopsy in pancreatic solid masses without on-site cytopathologist: a single-center experience. Dig Endosc. 2011 May;23: Suppl 1:34–8. PMID: 2153519821535198
60 Kopelman Y, Marmor S, Ashkenazi I, . Value of EUS-FNA cytological preparations compared with cell block sections in the diagnosis of pancreatic solid tumours. Cytopathology. 2011 Jun;22(3):174–8. PMID: 2048271720482717
61 Kubiliun N, Ribeiro A, Fan YS, . EUS-FNA with rescue fluorescence in situ hybridization for the diagnosis of pancreatic carcinoma in patients with inconclusive on-site cytopathology results. Gastrointest Endosc. 2011 Sep;74(3):541–7. PMID: 2175236421752364
62 Reddymasu SC, Gupta N, Singh S, . Pancreato-biliary malignancy diagnosed by endoscopic ultrasonography in absence of a mass lesion on transabdominal imaging: Prevalence and predictors. Dig Dis Sci. 2011 Jun;56(6):1912–16.21188524
63 Carrara S, Arcidiacono PG, Mezzi G, . Pancreatic endoscopic ultrasound-guided fine needle aspiration: complication rate and clinical course in a single centre. Dig Liver Dis. 2010 Jul;42(7):520–3. PMID: 1995502519955025
64 Kliment M, Urban O, Cegan M, . Endoscopic ultrasound-guided fine needle aspiration of pancreatic masses: the utility and impact on management of patients. Scand J Gastroenterol. 2010 Nov;45(11):1372–9. PMID: 2062630420626304
65 Song TJ, Kim JH, Lee SS, . The prospective randomized, controlled trial of endoscopic ultrasound-guided fine-needle aspiration using 22G and 19G aspiration needles for solid pancreatic or peripancreatic masses. Am J Gastroenterol. 2010 Aug;105(8):1739–45. PMID: 2021653220216532
66 Chang YH, Sang SL, Tae JS, . Endoscopic ultrasound guided fine needle aspiration biopsy in diagnosis of pancreatic and peripancreatic lesions: a single center experience in Korea. Gut Liver. 2009 Jun;3(2):116–21.20431733
67 Fisher L, Segarajasingam DS, Stewart C, . Endoscopic ultrasound guided fine needle aspiration of solid pancreatic lesions: Performance and outcomes. J Gastroenterol Hepatol. 2009 Jan;24(1):90–6. PMID: 1919639619196396
68 Hikichi T, Irisawa A, Bhutani MS, . Endoscopic ultrasound-guided fine-needle aspiration of solid pancreatic masses with rapid on-site cytological evaluation by endosonographers without attendance of cytopathologists. J Gastroenterol. 2009;44(4):322–8. PMID: 1927442619274426
69 Wakatsuki T, Irisawa A, Bhutani MS, . Comparative study of diagnostic value of cytologic sampling by endoscopic ultrasonography-guided fine-needle aspiration and that by endoscopic retrograde pancreatography for the management of pancreatic mass without biliary stricture. J Gastroenterol Hepatol. 2005 Nov;20(11):1707–11. PMID: 1624619016246190
70 Siddiqui UD, Rossi F, Rosenthal LS, . EUS-guided FNA of solid pancreatic masses: a prospective, randomized trial comparing 22-gauge and 25-gauge needles. Gastrointest Endosc. 2009 Dec;70(6):1093–7. PMID: 1964052419640524
71 Yusuf TE, Ho S, Pavey DA, . Retrospective analysis of the utility of endoscopic ultrasound-guided fine-needle aspiration (EUS-FNA) in pancreatic masses, using a 22-gauge or 25-gauge needle system: a multicenter experience. Endoscopy. 2009 May;41(5):445–8.19418399
72 Zamboni GA, D’Onofrio M, Idili A, . Ultrasound-guided percutaneous fine-needle aspiration of 545 focal pancreatic lesion. AJR Am J Roentgenol. 2009 Dec;193(6):1691–5.19933666
73 Al-Haddad M, Wallace MB, Woodward TA, . The safety of fine-needle aspiration guided by endoscopic ultrasound: a prospective study. Endoscopy. 2008 Mar;40(3):204–8.18058615
74 Ramirez-Luna MA, Zepeda-Gomez S, Chavez-Tapia NC, . Diagnostic yield and therapeutic impact of fine-needle aspiration biopsies guided by endoscopic ultrasound in pancreatic lesions. Rev Invest Clin. 2008 Jan–Feb;60(1):11–4. PMID: 1858958218589582
75 Shah SM, Ribeiro A, Levi J, . EUS-guided fine needle aspiration with and without trucut biopsy of pancreatic masses. JOP. 2008;9(4):422–30. PMID: 1864813318648133
76 Eloubeidi MA, Varadarajulu S, Desai S, . A prospective evaluation of an algorithm incorporating routine preoperative endoscopic ultrasound-guided fine needle aspiration in suspected pancreatic cancer. J Gastrointest Surg. 2007 Jul;11(7):813–9. PMID: 1744079017440790
77 Eloubeidi MA, Tamhane A. Prospective assessment of diagnostic utility and complications of endoscopic ultrasound-guided fine needle aspiration. Results from a newly developed academic endoscopic ultrasound program. Dig Dis. 2008;26(4):356–63. PMID: 1918872819188728
78 Eloubeidi MA, Tamhane A, Varadarajulu S, . Frequency of major complications after EUS-guided FNA of solid pancreatic masses: a prospective evaluation. Gastrointest Endosc. 2006 Apr;63(4):622–9. PMID: 1656486316564863
79 Eloubeidi MA, Tamhane A. EUS-guided FNA of solid pancreatic masses: a learning curve with 300 consecutive procedures. Gastrointest Endosc. 2005 May;61(6):700–8. PMID: 1585597515855975
80 Eloubeidi MA, Chen VK, Eltoum IA, . Endoscopic ultrasound-guided fine needle aspiration biopsy of patients with suspected pancreatic cancer: diagnostic accuracy and acute and 30-day complications. Am J Gastroenterol. 2003 Dec;98(12):2663–8. PMID: 1468781314687813
81 Varadarajulu S, Tamhane A, Eloubeidi MA. Yield of EUS-guided FNA of pancreatic masses in the presence or the absence of chronic pancreatitis. Gastrointest Endosc. 2005 Nov;62(5):728–36.16246688
82 Rocca R, De Angelis C, Daperno M, . Endoscopic ultrasound-fine needle aspiration (EUS-FNA) for pancreatic lesions: effectiveness in clinical practice. Dig Liver Dis. 2007 Aug;39(8):768–74. PMID: 1760642017606420
83 Bournet B, Migueres I, Delacroix M, . Early morbidity of endoscopic ultrasound: 13 years’ experience at a referral center. Endoscopy. 2006 Apr;38(4):349–54. PMID: 1668063316680633
84 Mahnke D, Chen YK, Antillon MR, . A prospective study of complications of endoscopic retrograde cholangiopancreatography and endoscopic ultrasound in an ambulatory endoscopy center. Clin Gastroenterol Hepatol. 2006 Jul;4(7):924–30. PMID: 1679725116797251
85 Wittmann J, Kocjan G, Sgouros SN, . Endoscopic ultrasound-guided tissue sampling by combined fine needle aspiration and trucut needle biopsy: a prospective study. Cytopathology. 2006 Feb;17(1):27–33. PMID: 1641756216417562
86 Mortensen MB, Fristrup C, Holm FS, . Prospective evaluation of patient tolerability, satisfaction with patient information, and complications in endoscopic ultrasonography. Endoscopy. 2005 Feb;37(2):146–53. PMID: 1569293015692930
87 Ryozawa S, Kitoh H, Gondo T, . Usefulness of endoscopic ultrasound-guided fine-needle aspiration biopsy for the diagnosis of pancreatic cancer. J Gastroenterol. 2005 Sep;40(9):907–11. PMID: 1621134816211348
88 Eloubeidi MA, Gress FG, Savides TJ, . Acute pancreatitis after EUS-guided FNA of solid pancreatic masses: a pooled analysis from EUS centers in the United States. Gastrointest Endosc. 2004 Sep;60(3):385–9. PMID: 1533202815332028
89 Gress F, Michael H, Gelrud D, . EUS-guided fine-needle aspiration of the pancreas: evaluation of pancreatitis as a complication. Gastrointest Endosc. 2002 Dec;56(6):864–7. PMID: 1244729912447299
90 Harewood GC, Wiersema MJ. Endosonography-guided fine needle aspiration biopsy in the evaluation of pancreatic masses. Am J Gastroenterol. 2002 Jun;97(6):1386–91. PMID: 1209485512094855
91 Fritscher-Ravens A, Sriram PVJ, Krause C, . Detection of pancreatic metastases by EUS-guided fine-needle aspiration. Gastrointest Endosc. 2001;53(1):65–70.11154491
92 Gress F, Gottlieb K, Sherman S, . Endoscopic ultrasonography-guided fine-needle aspiration biopsy of suspected pancreatic cancer. Ann Intern Med. 2001 Mar 20;134(6):459–64. PMID: 1125552111255521
93 O’Toole D, Palazzo L, Arotcarena R, . Assessment of complications of EUS-guided fine-needle aspiration. Gastrointest Endosc. 2001 Apr;53(4):470–4. PMID: 1127588811275888
94 Voss M, Hammel P, Molas G, . Value of endoscopic ultrasound guided fine needle aspiration biopsy in the diagnosis of solid pancreatic masses. Gut. 2000 Feb;46(2):244–9. PMID: 1064432010644320
95 Sakamoto H, Kitano M, Suetomi Y, . Utility of contrast-enhanced endoscopic ultrasonography for diagnosis of small pancreatic carcinomas. Ultrasound Med Biol. 2008 Apr;34(4):525–32. PMID: 1804576818045768
96 Semelka RC, Hernandes Mde A, Stallings CG, . Objective evaluation of acute adverse events and image quality of Gadolinium-based contrast agents (Gadobutrol and Gadobenate Dimeglumine) by blinded evaluation. Pilot study. Magn Reson Imaging. 2013 Jan;31(1):96–101. PMID: 2289868822898688
97 Albiin N, Kartalis N, Bergquist A, . Manganese chloride tetrahydrate (CMC-001) enhanced liver MRI: evaluation of efficacy and safety in healthy volunteer. MAGMA. 2012 Oct;25(5):361–8. PMID: 2239927522399275
98 Bredart A, Kop JL, Fall M, . Perception of care and experience of examination in women at risk of breast cancer undergoing intensive surveillance by standard imaging with or without MR. Patient Educ Couns. 2012 Mar;86(3):405–13. PMID: 2179500921795009
99 Maurer M, Heine O, Wolf M, . Tolerability and diagnostic value of Gadoteric Acid in the general population and in patients with risk factors: results in more than 84,000 patients. Eur J Radiol. 2012 May;81(5):885–90. PMID: 2155519721555197
100 Voth M, Rosenberg M, Breuer J. Safety of Gadobutrol, a new generation of contrast agents: experience from clinical trials and postmarketing surveillance. Invest Radiol. 2011 Nov;46(11):663–71. PMID: 2162321121623211
101 Forsting M, Palkowitsch P. Prevalence of acute adverse reactions to Gadobutrol-a highly concentrated macrocyclic Gadolinium chelate: review of 14,299 patients from observational trials. Eur J Radiol. 2010 Jun;74(3):e186–92. PMID: 1957400819574008
102 Ichikawa T, Saito K, Yoshioka N, . Detection and characterization of focal liver lesions: a Japanese phase III, multicenter comparison between gadoxetic acid disodium-enhanced magnetic resonance imaging and contrast-enhanced computed tomography predominantly in patients with hepatocellular carcinoma and chronic liver disease. Invest Radiol. 2010 Mar;45(3):133–41. PMID: 2009833020098330
103 Ishiguchi T, Takahashi S. Safety of Gadoterate Meglumine (Gd-DOTA) as a contrast agent for magnetic resonance imaging: results of a post-marketing surveillance study in Japan. Drugs R D. 2010;10(3):133–45. PMID: 2094594420945944
104 Leander P, Golman K, Mansson S, . Orally administered Manganese with and without Ascorbic Acid as a liver-specific contrast agent and bowel marker for magnetic resonance imaging: phase I clinical trial assessing efficacy and safety. Invest Radiol. 2010 Sep;45(9):559–64. PMID: 2064448720644487
105 Hammerstingl R, Adam G, Ayuso JR, . Comparison of 1.0 M Gadobutrol and 0.5 m Gadopentetate Dimeglumine-enhanced magnetic resonance imaging in five hundred seventy-two patients with known or suspected liver lesions. Invest Radiol. 2009 Mar;44(3):168–76. PMID: 1916914319169143
106 Shah-Patel LR, Piraner M, Silberzweig JE. Adverse events in a freestanding radiology office. J Am Coll Radiol. 2009 Apr;6(4):263–7. PMID: 1932765919327659
107 Kim SH, Jo EJ, Kim MY, . Clinical value of radiocontrast media skin tests as a prescreening and diagnostic tool in hypersensitivity reaction. Ann Allergy Asthma Immunol. 2013 Apr;110(4):258–62. PMID: 2353508923535089
108 Kobayashi D, Takahashi O, Ueda T, . Risk factors for adverse reactions from contrast agents for computed tomography. BMC Med Inform Decis Mak. 2013;13:18. PMID: 2336360723363607
109 Davenport MS, Wang CL, Bashir MR, . Rate of contrast material extravasations and allergic-like reactions: effect of extrinsic warming of low-osmolality iodinated CT contrast material to 37 degrees. Radiology. 2012 Feb;262(2):475–84. PMID: 2210635622106356
110 Jung KE, Chung J, Park BC, . A clinical study of cutaneous adverse reactions to nonionic contrast media in Korea. Ann Dermatol. 2012 Feb;24(1):22–5. PMID: 2236315122363151
111 Kingston RJ, Young N, Sindhusake DP, . Study of patients with intravenous contrast extravasation on CT studies, with radiology staff and ward staff cannulation. J Med Imaging Radiat Oncol. 2012 Apr;56(2):163–7. PMID: 2249818822498188
112 Mitchell AM, Jones AE, Tumlin JA, . Prospective study of the incidence of contrast-induced nephropathy among patients evaluated for pulmonary embolism by contrast-enhanced computed tomograph. Acad Emerg Med. 2012 Jun;19(6):618–25. PMID: 2268717622687176
113 Vogl TJ, Wessling J, Buerke B. An observational study to evaluate the efficiency and safety of Ioversol pre-filled syringes compared with Ioversol bottles in contrast-enhanced examination. Acta Radiol. 2012 Oct 1;53(8):914–20. PMID: 2298325922983259
114 Cadwallader RA, Walsh SR, Burrows B, . Prospective audit of cross-sectional imaging and radiation exposure in general surgical patients. Ann R Coll Surg Engl. 2011 Jan;93(1):6–8. PMID: 2095566120955661
115 Hatakeyama S, Abe A, Suzuki T, . Clearance and safety of the radiocontrast medium Iopamidol in peritoneal dialysis patients. Int J Nephrol. 2011;2011:657051. Epub 2011 Oct 19. PMID: 2202896622028966
116 Loh S, Bagheri S, Katzberg RW, . Delayed adverse reaction to contrast-enhanced CT: a prospective single-center study comparison to control group without enhancement. Radiology. 2010 Jun;255(3):764–71. PMID: 2040688220406882
117 Ozbulbul NI, Yurdakul M, Tola M. Comparison of a low-osmolar contrast medium, Iopamidol, and an iso-osmolar contrast medium, Iodixanol, in MDCT coronary angiography. Coron Artery Dis. 2010 Nov;21(7):414–9. PMID: 2067155020671550
118 Cote GA, Hovis RM, Ansstas MA, . Incidence of sedation-related complications with Propofol use during advanced endoscopic procedures. Clin Gastroenterol Hepatol. 2010 Feb;8(2):137–42. PMID: 1960793719607937
119 Eloubeidi MA, Tamhane A, Lopes TL, . Cervical esophageal perforations at the time of endoscopic ultrasound: a prospective evaluation of frequency, outcomes, and patient management. Am J Gastroenterol. 2009 Jan;104(1):53–6. PMID: 1909884919098849
120 Kalaitzakis E, Varytimiadis K, Meenan J. Predicting what can go wrong at endoscopic ultrasound: a large series experience. Frontline Gastroenterol. 2011 Apr;2(2):110–6.28839592
121 Niv Y, Gershtansky Y, Kenett RS, . Complications in endoscopic retrograde cholangiopancreatography (ERCP) and endoscopic ultrasound (EUS): analysis of 7-year physician-reported adverse events. Drug Healthc Patient Saf. 2011;3:21–5. PMID: 2175390021753900
122 Schilling D, Rosenbaum A, Schweizer S, . Sedation with Propofol for interventional endoscopy by trained nurses in high-risk octogenarians: a prospective, randomized, controlled study. Endoscopy. 2009 Apr;41(4):295–8. PMID: 1934073019340730
123 Chang Y, Lee GH, Kim TJ, . Toxicity of magnetic resonance imaging agents: small molecule and nanoparticle. Curr Top Med Chem. 2013;13(4):434–45. PMID: 2343200623432006
124 Canto MI, Hruban RH, Fishman EK, . Frequent detection of pancreatic lesions in asymptomatic high-risk individuals. Gastroenterology. 2012 Apr;142(4):796–804; quiz e14–5. PMID: 2224584622245846
125 Al-Sukhni W, Borgida A, Rothenmund H, . Screening for pancreatic cancer in a high-risk cohort: an eight-year experience. J Gastrointest Surg. 2012 Apr;16(4):771–83. PMID: 2212778122127781
126 Verna EC, Hwang C, Stevens PD, . Pancreatic cancer screening in a prospective cohort of high-risk patients: a comprehensive strategy of imaging and genetics. Clin Cancer Res. 2010 Oct 15;16(20):5028–37. PMID: 2087679520876795
127 Langer P, Kann PH, Fendrich V, . Five years of prospective screening of high-risk individuals from families with familial pancreatic cancer. Gut. 2009 Oct;58(10):1410–8. PMID: 1947049619470496
128 Vasen HF, Wasser M, van Mil A, . Magnetic resonance imaging surveillance detects early-stage pancreatic cancer in carriers of a p16-Leiden mutation. Gastroenterology. 2011 Mar;140(3):850–6. PMID: 2112937721129377
129 Canto MI, Goggins M, Hruban RH, . Screening for early pancreatic neoplasia in high-risk individuals: a prospective controlled study. Clin Gastroenterol Hepatol. 2006 Jun;4(6):766–81.16682259
130 Brune K, Abe T, Canto M, . Multifocal neoplastic precursor lesions associated with lobular atrophy of the pancreas in patients having a strong family history of pancreatic cancer. Am J Surg Pathol. 2006 Sep;30(9):1067–76.16931950
131 White CM, Ip S, McPheeters M, . Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. In: Agency for Healthcare Research and Quality. Methods guide for comparative effectiveness reviews [posted September 2009]. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2009 Sep. http://effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60. PMID: 2143340221433402
132 Shea BJ, Grimshaw JM, Wells GA, . Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. PMID: 1730298917302989