# Appendix C Evidence Tables

## Systematic Reviews

Table C-1 Key Question 1a systematic reviews: study characteristics

Table C-2 Key question 1a systematic reviews: published results

Table C-3 Key Question 2a systematic reviews: study characteristics

Table C-4 Key Question 2a systematic reviews: published results

## Comparative Accuracy Studies

Table C-5 General study information of comparative accuracy studies

Table C-6 Patient characteristics of comparative accuracy studies

Table C-7 General test details of comparative accuracy studies

Table C-8 MDCT details of comparative accuracy studies

Table C-9 EUS-FNA details of comparative accuracy studies

Table C-10 MRI details of comparative accuracy studies

Table C-11 PET/CT details of comparative accuracy studies

Table C-12 Comparative accuracy data for tests of interest in included studies

## Harms Studies

Table C-13 General information in pancreas-specific studies included for harms data

Table C-14 Patient characteristics in pancreas-specific studies included for harms data

Table C-15 Testing characteristics in pancreas-specific studies included for harms data

Table C-16 Harms reported in included pancreas-specific studies

Table C-17 Harms from MRI in included non-pancreatic-cancer studies

Table C-18 Harms from MDCT in included non-pancreatic-cancer studies

Table C-19 Harms from EUS in included non-pancreatic-cancer studies

Table C-20 Harms from PET/CT in included non-pancreatic-cancer studies

Table C-21 Harms from EUS-FNA in included non-pancreatic-cancer studies

Table C-22 Physical and chemical characteristics of all currently marketed Gadolinium agents for MRI

## Screening Studies

Table C-23 General study information of screening studies

Table C-24 Patient characteristics of screening studies

Table C-25 General test details of screening studies

Table C-26 CT details of screening studies

Table C-27 EUS-FNA details of screening studies

Table C-28 MRI details of screening studies

Table C-29 General data reported by screening studies for any imaging modality

Table C-30 Screening studies: individual patient data for patients whose final diagnosis was based on surgery and/or biopsy