# Appendix B Full-Length Review of Excluded Studies

Adamek HE, Albert J, Breer H, . Pancreatic cancer detection with magnetic resonance cholangiopancreatography and endoscopic retrograde cholangiopancreatography: a prospective controlled study. Lancet. 2000 Jul 15;356(9225):190–3. No statement in the methods about plan to capture harms10963196
Afify AM, al-Khafaji BM, Kim B, . Endoscopic ultrasound-guided fine needle aspiration of the pancreas. Diagnostic utility and accuracy. Acta Cytol. 2003 May–Jun;47(3):341–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12789912
Agarwal B, Krishna NB, Labundy JL, . EUS and/or EUS-guided FNA in patients with CT and/or magnetic resonance imaging findings of enlarged pancreatic head or dilated pancreatic duct with or without a dilated common bile duct. Gastrointest Endosc. 2008 Aug;68(2):237–42; quiz 334. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18423464
Ahmed SI, Bochkarev V, Oleynikov D, . Patients with pancreatic adenocarcinoma benefit from staging laparoscopy. J Laparoendosc Adv Surg Tech A. 2006 Oct;16(5):458–463. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17004868
Ahn SS, Kim M-J, Choi J-Y, . Indicative findings of pancreatic cancer in prediagnostic CT. Eur Radiol. 2009;19(10):2448–2455. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19415290
Ainsworth AP, Hansen T, Fristrup CW, . Indications for and clinical impact of repeat endoscopic ultrasound. Scand J Gastroenterol. 2010 Apr;45(4):477–82. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19968612
Aithal GP, Anagnostopoulos GK, Tam W, . EUS-guided tissue sampling: comparison of “dual sampling” (Trucut biopsy plus FNA) with “sequential sampling” (Trucut biopsy and then FNA as required). Endoscopy. 2007 Aug;39(8):725–30. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17620230
Alle V, Gurusamy KS, Kali A, . Role of Positron Emission Tomography (PET) in pancreatic resection for suspected pancreatic and periampullary cancer. Int J Surg. 2011;9(5):366. Just a meeting abstract
Almadi MA, Aljebreen A, Azzam N, Eltayeb MO, Javed M, Alharbi O. Clinical predictors of resectability of pancreatic adenocarcinoma. Gastroenterology. 2013 May;144(5 Suppl 1):S662–3. Just a meeting abstract
Al-Nahhas A, Win Z, Szyszko T, . What can gallium-68 PET add to receptor and molecular imaging? Eur J Nucl Med Mol Imaging. 2007 Dec;34(12):1897–1901. Narrative review17713764
Alsibai KD, Denis B, Bottlaender J, . Impact of cytopathologist expert on diagnosis and treatment of pancreatic lesions in current clinical practice. A series of 106 endoscopic ultrasound-guided fine needle aspirations. Cytopathology. 2006 Feb;17(1):18–26. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16417561
Alsohaibani F, Girgis S, Sandha GS. Does onsite cytotechnology evaluation improve the accuracy of endoscopic ultrasound-guided fine-needle aspiration biopsy? Can J Gastroenterol. 2009 Jan;23(1):26–30. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19172205
Amin Z, Theis B, Russell RC, . Diagnosing pancreatic cancer: the role of percutaneous biopsy and CT. Clin Radiol. 2006 Dec;61(12):996–1002. Unclear whether biopsies were ultrasound-guided17097419
Anand N, Tran AH, Karabalin N, Wu BU. The utility of endoscopic ultrasound (EUS) in preoperative staging of potentially resectable pancreatic cancer. Gastroenterology. 2013 May;144(5 Suppl 1):S208–9. Just a meeting abstract
Anderson MA. Diagnostic and therapeutic applications of EUS in pancreatic disease. Gastroenterol Hepatol. 2007 Oct;3(10):768–771. Narrative review
Anderson SW, Soto JA. Pancreatic duct evaluation: Accuracy of portal venous phase 64 MDCT. Abdom Imaging. 2009 Jan;34(1):55–63. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18425544
Andrawes SA, Hindy P, Taur Y, . Accuracy of endoscopic elastography for detection of malignant pancreatic mass lesions. Systematic review and meta-analysis. Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB207. No data specific to an imaging test of interest
Ang TL, Teo EK, Ang D, . A pilot study of contrast harmonic endosonography using DEFINITY in the evaluation of suspected pancreatic and peri-ampullary malignancies. J Interv Gastroenterol. 2011 Oct;1(4):160–165. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22586529
Arabul M, Karakus F, Alper E, . Comparison of multidetector CT and endoscopic ultrasonography in malignant pancreatic mass lesions. Hepatogastroenterology. 2012 Jul–Aug;59(117):1599–603. No data specific to an imaging test of interest22155849
Arcidiacono PG, Carrara S. Endoscopic ultrasonography: Impact in diagnosis, staging and management of pancreatic tumors. An overview. JOP. 2004 Jul;5(4):247–252. Narrative review15254358
Ardengh JC, De Paulo GA, Ferrari Jr AP. Pancreatic carcinomas smaller than 3.0 cm: Endosonography (EUS) in diagnosis, staging and prediction of resectability. HPB. 2003;5(4):226–230. No comparative specificity data18332991
Ardengh JC, Lopes CV, Campos AD, . Endoscopic ultrasound and fine needle aspiration in chronic pancreatitis: differential diagnosis between pseudotumoral masses and pancreatic cancer. JOP. 2007;8(4):413–21. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17625292
Ardengh JC, Lopes CV, de Lima LF, . Diagnosis of pancreatic tumors by endoscopic ultrasound-guided fine-needle aspiration. World J Gastroenterol. 2007 Jun 14;13(22):3112–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17589929
Ardengh JC, Lopes CV, De Lima LFP, . Cell block technique and cytological smears for the differential diagnosis of pancreatic neoplasms after endosonography-guided fine-needle aspiration. Acta Gastroenterol Latinoam. 2008 Dec;38(4):246–251. Non-English19157379
Ardengh JC, Malheiros CA, Pereira V, . Endoscopic ultrasound-guided fine-needle aspiration using helical computerized tomography for TN staging and vascular injury in operable pancreatic carcinoma. JOP. 2009;10(3):310–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19454825
Arslan A, Buanes T, Geitung JT. Pancreatic carcinoma: MR, MR angiography and dynamic helical CT in the evaluation of vascular invasion. Eur J Radiol. 2001;38(2):151–159. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11335098
Arvold ND, Niemierko A, Mamon HJ, . Pancreatic cancer tumor size on CT scan versus pathologic specimen: implications for radiation treatment planning. Int J Radiat Oncol Biol Phys. 2011 Aug 1;80(5):1383–90. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20708856
Arya M, Mathur S, Sonpal N, . Maintaining yield while minimizing eus guided fna passes in a community hospital setting. Am J Gastroenterol. 2010;105:S411. Just a meeting abstract
Asagi A, Ohta K, Nasu J, . Utility of contrast-enhanced FDG-PET/CT in the clinical management of pancreatic cancer: impact on diagnosis, staging, evaluation of treatment response, and detection of recurrence. Pancreas. 2013 Jan;42(1):11–9. No comparative specificity data22699206
Ashida R, Ioka T, Ishida N, . For early detection of pancreatic cancer. J Gastroenterol Hepatol. 2012 Dec;27:370. Just a meeting abstract
Aslanian H, Salem R, Lee J, . EUS diagnosis of vascular invasion in pancreatic cancer: surgical and histologic correlates. Am J Gastroenterol. 2005 Jun;100(6):1381–5. No data specific to an imaging test of interest15929774
Azabdaftari G, Goldberg SN, Wang HH. Efficacy of on-site specimen adequacy evaluation of image-guided fine and core needle biopsies. Acta Cytol. 2010 Mar–Apr;54(2):132–137. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20391967
Aziz AM, Said T, Poovathumkadavil A, . Using Multidetector CT in Predicting Resectability of Pancreatic Head Tumors: Surgical and Pathologic Correlation. J Egypt Natl Canc Inst. 2010 Dec;22(4):233–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21863075
Baghbanian M, Salmanroghani H, Baghbanian A, Bakhtpour M, Shabazkhani B. Efficacy of multi-detector computerized tomography scan, endoscopic ultrasound, and laparoscopy for predicting tumor resectability in pancreatic adenocarcinoma. Indian J Gastroenterol. 2013 Nov;32(6):376–80. Assumed no false positives, thus did not truly measure both sensitivity and specificity23982702
Baghbanian M, Shabazkhani B, Ghofrani H, . Efficacy of endoscopic ultrasound guided fine needle aspiration in patients with solid pancreatic neoplasms. Saudi J Gastroenterol. 2012 Nov–Dec;18(6):358–63. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23150020
Balthazar EJ. CT contrast enhancement of the pancreas: Patterns of enhancement, pitfalls and clinical implications. Pancreatology. 2012 Feb;11(6):585–7. Narrative review
Bang JY, Hebert-Magee S, Trevino J, . Randomized trial comparing the 22-gauge aspiration and 22-gauge biopsy needles for EUS-guided sampling of solid pancreatic mass lesions. Gastrointest Endosc. 2012 Aug;76(2):321–7. N <5022658389
Bang JY, Trevino J, Ramesh J, . Randomized trial comparing the fanning and standard techniques for EUS-guided FNA of solid pancreatic mass lesions. Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB445–AB446. Just a meeting abstract
Bao PQ, Johnson JC, Lindsey EH, . Endoscopic ultrasound and computed tomography predictors of pancreatic cancer resectability. J Gastrointest Surg 2008 Jan; 12(1): 10–6, discussion 16. Correlated vessel involvement via imaging to actual resectability, thus not direct17955311
Barber TW, Kalff V, Cherk MH, . 18 F-FDG PET/CT influences management in patients with known or suspected pancreatic cancer. Intern Med J. 2011 Nov;41(11):776–83. No data specific to an imaging test of interest20492008
Barreiro CJ, Lillemoe KD, Koniaris LG, . Diagnostic laparoscopy for periampullary and pancreatic cancer: what is the true benefit? J Gastrointest Surg. 2002 Jan–Feb;6(1):75–81. No data specific to an imaging test of interest11986021
Bartsch DK. Familial pancreatic cancer. Br J Surg. 2003 Apr 1;90(4):386–387. Narrative review12673738
Basir Z, Pello N, Dayer AM, . Accuracy of cytologic interpretation of pancreatic neoplasms by fine needle aspiration and pancreatic duct brushings. Acta Cytol. 2003 Sep–Oct;47(5):733–8. Only a single imaging test of interest, and N <5014526670
Basnayake C, Moore G, Croagh D, . Analysis of factors that influence accuracy of endoscopic ultrasound-guided fine needle aspiration for solid pancreatic masses. J Gastroenterol Hepatol. 2012 Oct;27:51. Just a meeting abstract22004366
Bhutani MS. Endoscopic ultrasonography. Endoscopy. 2007 Nov;39(11):1005–1009. Narrative review18008207
Bipat S, Saffire SKS, Van Delden OM, . Ultrasonography, computed tomography and magnetic resonance imaging for diagnosis and determining resectability of pancreatic adenocarcinoma: A meta-analysis. J Comput Assist Tomogr. 2005 Jul–Aug;29(4):438–445. Duplicate16012297
Birchard KR, Semelka RC, Hyslop WB, . Suspected pancreatic cancer: Evaluation by dynamic gadolinium-enhanced 3D gradient-echo MRI. AJR Am J Roentgenol. 2005;185(3):700–703. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16120921
Bluen BE, Lachter J, Khamaysi I, . Accuracy and quality assessment of EUS-FNA: A single-center large cohort of biopsies. Diagn Ther Endosc. 2012;139563. Epub 2012 Oct 31. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23197929
Bolog N, Constantinescu G, Oancea I, . Magnetic resonance imaging of bile and pancreatic ducts: a retrospective study. Rom J Gastroenterol. 2004 Jun;13(2):91–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15229771
Boraschi P, Donati F, Gigoni R, . Mangafodipir trisodium-enhanced MR imaging of pancreatic disease. Eur Radiol. 2006 May;16(5):988–997. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16421713
Boraschi P, Donati F, Gigoni R, . Secretin-stimulated multi-detector CT versus mangafodipir trisodium-enhanced MR imaging plus MRCP in characterization of non-metastatic solid pancreatic lesions. Dig Liver Dis. 2009 Nov;41(11):829–37. No data specific to an imaging test of interest19303825
Borbath I, Van Beers BE, Lonneux M, . Preoperative assessment of pancreatic tumors using magnetic resonance imaging, endoscopic ultrasonography, positron emission tomography and laparoscopy. Pancreatology. 2005;5(6):553–61. EUS accuracy directly influenced reference standard16113592
Brais RJ, Davies SE, O’Donovan M, . Direct histological processing of EUS biopsies enables rapid molecular biomarker analysis for interventional pancreatic cancer trials. Pancreatology. 2012 Jan–Feb;12(1):8–15. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22487467
Brandwein SL, Farrell JJ, Centeno BA, . Detection and tumor staging of malignancy in cystic, intraductal, and solid tumors of the pancreas by EUS. Gastrointest Endosc. 2001 Jun;53(7):722–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11375578
Breitkopf CR, Sinicrope PS, Rabe KG, . Factors influencing receptivity to future screening options for pancreatic cancer in those with and without pancreatic cancer family history. Hered Cancer Clin Pract. 2012 Jun 27;10(1). Hypothetical imaging test
Brimiene V, Brimas G, Strupas K. Differential diagnosis between chronic pancreatitis and pancreatic cancer: a prospective study of 156 patients. Medicina (Kaunas). 2011;47(3):154–62. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21822037
Brix G, Nissen-Meyer S, Lechel U, . Radiation exposures of cancer patients from medical X-rays: How relevant are they for individual patients and population exposure? Eur J Radiol. 2009 Nov;72(2):342–347. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18722727
Brugel M, Rummeny EJ, Dobritz M. Vascular invasion in pancreatic cancer: Value of multislice helical CT. Abdom Imaging. 2004 May–Apr;29(2):239–245. Just a meeting abstract15290953
Brugge WR. EUS. Gastrointest Endosc. September 2013;78(3):414–420. Narrative review23948189
Bruno MJ. Endoscopic ultrasonography. Endoscopy. 2006 Nov;38(11):1098–1105. Narrative review17111330
Buchs NC, Frossard JL, Rosset A, . Vascular invasion in pancreatic cancer: evaluation of endoscopic ultrasonography, computed tomography, ultrasonography, and angiography. Schweiz Med Wochenschr. 2007 May 19;137(19–20):286–91. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Buchs NC, Frossard JL, Rosset A, . Vascular invasion in pancreatic cancer. Swiss Med Wkly. 2007 May 19;137(19–20):286–291. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17594541
Bueno FS, Carrion JF, De La Pena J, Claver MA, Galvez J, Parrilla P, Perez RG. Diagnostic utility of PET-CT for diagnosis of pancreatic adenocarcinoma and early intraepithelial neoplasia (PanIN). A Case-control study of 119 patients. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S35. Just a meeting abstract
Burski CM, Varadarajulu S, Trevino J. Diagnosing cancer in chronic pancreatitis: The struggle persists. Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB193. Just a meeting abstract
Caglar E, Senturk H, Atasoy D, . The Role of EUS and EUS-FNA in the Management of Pancreatic Masses: Five-Year Experience. Hepatogastroenterology. 2013 Jan 24;60(126). Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Calculli L, Casadei R, Amore B, . Correlazione tra la tomografia computerizzata spirale e l’eco color-Doppler nella definizione dell’interessamento del tronco mesenterico-portale nel carcinoma pancreatico. Radiol Med. 2002 Oct 1;104(4):307–315. Non-English12569311
Camp ER, Vogel SB. Blind Whipple resections for periampullary and pancreatic lesions. Am Surg. 2004 Jan;70(1):6–10; discussion 11–2. No data specific to an imaging test of interest14964538
Campisi A, Brancatelli G, Vullierme M-P, . Are pancreatic calcifications specific for the diagnosis of chronic pancreatitis? A multidetector-row CT analysis. Clin Radiol. 2009 Sep;64(9):903–911. Not pancreatic adenocarcinoma19664481
Camus M, Trouilloud I, Villacis AL, . Effectiveness of combined endoscopic ultrasound-guided fine-needle aspiration biopsy and stenting in patients with suspected pancreatic cancer. Eur J Gastroenterol Hepatol. 2012 Nov;24(11):1281–7. Used treatment prior to (or during) the imaging test(s)22890210
Canto MI, Goggins M, Yeo CJ, . Screening for pancreatic neoplasia in high-risk individuals: an EUS-based approach. Clin Gastroenterol Hepatol. 2004 Jul;2(7):606–21. Only a single imaging test of interest, and N <5015224285
Canto MI, Hruban RH, Fishman EK, . Frequent detection of pancreatic lesions in asymptomatic high-risk individuals. Gastroenterology. 2012 Apr;142(4):796–804; quiz e14–5. Duplicate22245846
Carneiro MP, Lopes FCR, Domingues RC, . Whole-body MRI and FDG PET fused images for evaluation of patients with cancer. AJR Am J Roentgenol. 2009 Apr;192(4):1012–1020. Not pancreatic adenocarcinoma19304708
Cassinotto C, Cortade J, Belleannee G, . An evaluation of the accuracy of CT when determining resectability of pancreatic head adenocarcinoma after neoadjuvant treatment. Eur J Radiol. 2013 Apr;82(4):589–93. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23287712
Catanzaro R, Arona S, Sapienza C, Giangreco E, Magnano A, Palermo F, Iabichino G, Mangiafico S, Alberghina N, Bonanno G. Endoscopic ultrasound-guided fine needle aspiration role in preoperative diagnosis of pancreatic tumors. Dig Liver Dis. 2013 Mar;45:S163. Just a meeting abstract
Cermak TS, Wang B, DeBrito P, . Does on-site adequacy evaluation reduce the nondiagnostic rate in endoscopic ultrasound-guided fine-needle aspiration of pancreatic lesions? Cancer Cytopathol. 2012 Oct 25;120(5):319–25. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22517672
Chandarana H, Babb J, Macari M. Signal characteristic and enhancement patterns of pancreatic adenocarcinoma: evaluation with dynamic gadolinium enhanced MRI. Clin Radiol. 2007 Sep;62(9):876–83. No outcomes of interest17662736
Chang KJ. EUS-guided FNA: The training is moving. Gastrointest Endosc. 2004 Jan;59(1):69–73. News/opinion/editorial14722551
Chang L, Stefanidis D, Richardson WS, . The role of staging laparoscopy for intraabdominal cancers: An evidence-based review. Surg Endosc. 2009 Feb;23(2):231–41. Narrative review18813972
Chang WI, Kim BJ, Lee JK, . The clinical and radiological characteristics of focal mass-forming autoimmune pancreatitis: comparison with chronic pancreatitis and pancreatic cancer. Pancreas. 2009 May;38(4):401–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18981953
Chari ST, Takahashi N, Levy MJ, . A diagnostic strategy to distinguish autoimmune pancreatitis from pancreatic cancer. Clin Gastroenterol Hepatol. 2009 Oct;7(10):1097–103. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19410017
Chatterjee S, Wadehra V, Cunningham J, . Impact of on-site adequacy assessment for eus fna of solid pancreatic lesions. Gut. 2011 Apr;60:A51–A52. Just a meeting abstract
Chen CH, Yang CC, Yeh YH, Yang T, Chung TC. Endosonography for suspected obstructive jaundice with no definite pathology on ultrasonography. J Formos Med Assoc. 2013 Sep 30; Duplicate
Chen C-H, Yang C-C, Yeh Y-H. For biliary dilatation, a negative endosonography needs additional image studies in weight loss suggesting malignancy. Dig Dis Sci. August 2013;58(8):2345–2352. Single test of interest and no harms/screening/patient preference data23546699
Cherian PT, Mohan P, Douiri A, . Role of endoscopic ultrasound-guided fine-needle aspiration in the diagnosis of solid pancreatic and peripancreatic lesions: is onsite cytopathology necessary? HPB. 2010 Aug;12(6):389–95. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20662789
Chhieng DC, Benson E, Eltoum I, . MUC1 and MUC2 expression in pancreatic ductal carcinoma obtained by fine-needle aspiration. Cancer. 2003 Dec 25;99(6):365–71. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14681945
Chu YL, Wang XF, Gao XZ, Qiao XL, Liu F, Yu SY, Zhang J. Endoscopic ultrasonography in tandem with endoscopic retrograde cholangiopancreatography in the management of suspected distal obstructive jaundice. Eur J Gastroenterol Hepatol. 2013 Apr;25(4):455–9. Only a single imaging test of interest, and N<5023249605
Chung KH, Lee SH, Park JK, Hwang J-H. Functional role of 18F-FDG PET/CT imaging in pancreatic ductal adenocarcinoma patients with diabetes. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S48. Just a meeting abstract
Chung KH, Lee YS, Park JK, Lee SH, Hwang J-H. Functional role of 18f-FDG PET/CT scan in diabetic patients with pancreatic ductal adenocarcinomas. Gastroenterology. 2013 May;144(5 Suppl 1):S658. Just a meeting abstract
Chung O. Pancreas. Curr Opin Gastroenterol. 2008 Sep;24(5):569–572. News/opinion/editorial19122496
Chun-Ye Q, Xun S, Ming G. Correlation between spiral CT preoperative staging of pancreatic cancer and PTEN and COX-2 expression. Hepatogastroenterology. 2012 Sep;59(118):2000–2. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22389271
Cipolletta L, Bianco MA, Rotondano G, . Pancreatic head mass: What can be done? Diagnosis: ERCP and EUS. JOP. 2000 Sep;1(3):108–110. News/opinion/editorial11854566
Cipollone I, Kelly M, Corbally C, . Is there still a utility for selected laparoscopic staging in pancreas cancer with contemporary multi detector CT scanning? Pancreatology. 2012 May–Jun;12(3):e12. Just a meeting abstract
Cleveland P, Gill KR, Coe SG, . An evaluation of risk factors for inadequate cytology in EUS-guided FNA of pancreatic tumors and lymph nodes. Gastrointest Endosc. 2010 Jun;71(7):1194–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20598246
Codreanu I, Dasanu CA, Weinstein GS, . Fluorodeoxyglucose-induced allergic reaction: a case report. J Oncol Pharm Pract. 2013 Mar;19(1):86–8. Other (such as case report)22267446
Cohen J, Sawhney M, Pleskow DK, Chuttani R, Patel N, Berzin TM. Double-duct sign in the era of EUS: Is the absence of a mass on EUS adequately reassuring? Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB415. Just a meeting abstract
Crippa S, Salgarello M, Laiti S, Partelli S, Zardini C, Castelli P, Zamboni G, Falconi M. The value of (18)FDG-PET/CT in patients with resectable pancreatic cancer: A prospective study. Dig Liver Dis. 2013 Mar;45:S160. Just a meeting abstract
Croome KP, Jayaraman S, Schlachta CM. Preoperative staging of cancer of the pancreatic head: is there room for improvement? Can J Surg. 2010 Jun;53(3):171–4. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20507789
Das A, Nguyen CC, Li F, . Digital image analysis of EUS images accurately differentiates pancreatic cancer from chronic pancreatitis and normal tissue. Gastrointest Endosc. 2008 May;67(6):861–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18179797
de Bree E, Tsiftsis DD, Santos RM, . Objective assessment of the contribution of each diagnostic test and of the ordering sequence in jaundice caused by pancreatobiliary carcinoma. Scand J Gastroenterol. 2000 Apr;35(4):438–45. No data specific to an imaging test of interest10831270
De Icaza E, Lopez-Cervantes M, Arredondo A, . Likelihood ratios of clinical, laboratory and image data of pancreatic cancer: Bayesian approach. J Eval Clin Pract. 2009 Feb;15(1):62–68. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19239583
de la Fuente SG, Ceppa EP, Reddy SK, . Incidence of benign disease in patients that underwent resection for presumed pancreatic cancer diagnosed by endoscopic ultrasonography (EUS) and fine-needle aspiration (FNA). J Gastrointest Surg. 2010 Jul;14(7):1139–42. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20424928
de Luna R, Eloubeidi MA, Sheffield MV, . Comparison of ThinPrep and conventional preparations in pancreatic fine-needle aspiration biopsy. Diagn Cytopathol. 2004 Feb;30(2):71–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14755754
Delrue L, Blanckaert P, Mertens D, . Assessment of tumor vascularization in pancreatic adenocarcinoma using 128-slice perfusion computed tomography imaging. J Comput Assist Tomogr. 2011 Jul–Aug;35(4):434–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21765297
Deshmukh S, Roberts K, Smith AM. Obstructive jaundice and pancreatic disease. BMJ. 2013 Jan 5;346(7889):e6701. Just a meeting abstract
Deshpande V, Mino-Kenudson M, Brugge WR, . Endoscopic ultrasound guided fine needle aspiration biopsy of autoimmune pancreatitis: diagnostic criteria and pitfalls. Am J Surg Pathol. 2005 Nov;29(11):1464–71. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16224213
DeWitt J, Devereaux B, Chriswell M, . Comparison of endoscopic ultrasonography and multidetector computed tomography for detecting and staging pancreatic cancer.[Summary for patients in Ann Intern Med. 2004 Nov 16;141(10):I46; PMID: 15545671. Ann Intern Med. 2004 Nov 16;141(10):753–63. Duplicate15545675
DeWitt J, Devereaux B, Chriswell M, . Is endoscopic ultrasound really better than multidetector CT for pancreatic cancer? Evid Based Gastroenterol. 2005 May;6(2):50. Just a meeting abstract
Dewitt J, Devereaux BM, Lehman GA, . Comparison of endoscopic ultrasound and computed tomography for the preoperative evaluation of pancreatic cancer: a systematic review. Clin Gastroenterol Hepatol. 2006 Jun;4(6):717–25; quiz 664. No data specific to an imaging test of interest16675307
Diederichs CG, Staib L, Vogel J, . Values and limitations of 18F-fluorodeoxyglucose-positron-emission tomography with preoperative evaluation of patients with pancreatic masses. Pancreas. 2000 Mar;20(2):109–16. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives10707924
Dietrich CF, Kratzer W, Strobe D, . Assessment of metastatic liver disease in patients with primary extrahepatic tumors by contrast-enhanced sonography versus CT and MRI. World J Gastroenterol. 2006 Mar 21;12(11):1699–705. Not pancreatic adenocarcinoma16586537
Dim DC, Jiang F, Qiu Q, . The usefulness of S100P, mesothelin, fascin, prostate stem cell antigen, and 14-3-3 sigma in diagnosing pancreatic adenocarcinoma in cytological specimens obtained by endoscopic ultrasound guided fine-needle aspiration. Diagn Cytopathol. 2011 Apr 28. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Dimitroulopoulos D, Xynopoulos D, Tsamakidis K, . Scintigraphic detection of carcinoid tumors with a cost effectiveness analysis. World J Gastroenterol. 2004 Dec 15;10(24):3628–33. No data specific to an imaging test of interest15534919
Divgi C, Pandit-Taskar N. PET: too much of a good thing? Does the plethora of choices impact on patient management? Eur J Nucl Med Mol Imaging. 2005 Apr;32(4):398. Just a meeting abstract15761778
D’Onofrio M, Crosara S, Signorini M, . Comparison between CT and CEUS in the Diagnosis of Pancreatic Adenocarcinoma. Ultraschall Med. 2012 Sep 21. Non-English
Doran HE, Bosonnet L, Connor S, . Laparoscopy and laparoscopic ultrasound in the evaluation of pancreatic and periampullary tumours. Dig Surg. 2004;21(4):305–13. No data specific to an imaging test of interest15365229
Doucas H, Sutton CD, Zimmerman A, . Assessment of pancreatic malignancy with laparoscopy and intraoperative ultrasound. Surg Endosc. 2007 Jul;21(7):1147–52. No outcomes of interest17177081
Drougas D, Giannopoulou C, Panagiotidis E, . Dual-phase, 18FDG-PET/CT imaging in patients with various cancer types. Eur J Nucl Med Mol Imaging. 2011 Oct;38:S278. Just a meeting abstract
Egorov V, Petrov R, Solodinina E, Karmazanovsky G, Starostina N, Kuruschkina N. CT-based diagnostics might be insufficient in the determination of pancreatic cancer unresectability. Pancreatology. 2013 May–Jun;13(3 Suppl 1):S51–2. Just a meeting abstract
Egorov V, Vishnevsky V, Karmazanovsky G, . The arterial encasement by pancreatic cancer on CT and MRI does not necessarily translate into arterial invasion at surgery. Which should be called on: Surgery, intrarterial us or (NEO) adjuvant therapy? How can one assess resectability on the spot? HPB. 2012 Jul;14:72. Just a meeting abstract
Egorov VI, Vishnevsky VA, Karmazanovsky GG, . Does arterial ebcasement on CT always mean arterial invasion at surgery in pancreatic cancer? If not, how can we assess resectability and what is the strategy? Pancreatology. 2012 Nov–Dec;12(6):559. Just a meeting abstract
Eguia V, Winner M, Sethi A, . Preoperative EUS-FNA does not adversely affect outcomes in resectable pancreatic cancer. Gastrointest Endosc. 2012 Apr;75(4 SUPPL. 1):AB194. Just a meeting abstract
Einersen P, Epelboym I, Winner M, Leung D, Chabot JA, Allendorf JD. Positron emission tomography (PET) has limited utility in preoperative staging of pancreatic adenocarcinoma. Gastroenterology. 2013 May;144(5 Suppl 1):S1080. Just a meeting abstract
Elias P, Hill E, Hertel J, . Reliability of visible tissue fragments and number of passes in fine needle biopsies: A single center experience with the cook pro core needle. Am J Gastroenterol. 2012;107:S711. Just a meeting abstract
Eloubeidi MA, Fusaroli P, Kypraios D, . Pancreaticobiliary EUS: a systematic review of current indications, test performance, and clinical outcome according to the levels of evidence. Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB184–5. Just a meeting abstract
Eloubeidi MA, Jhala D, Chhieng DC, . Yield of endoscopic ultrasound-guided fine-needle aspiration biopsy in patients with suspected pancreatic carcinoma. Cancer. 2003 Oct 25;99(5):285–92. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14579295
Eloubeidi MA, Tamhane A, Jhala N, . Agreement between rapid onsite and final cytologic interpretations of EUS-guided FNA specimens: Implications for the endosonographer and patient management. Am J Gastroenterol. 2006 Dec;101(12):2841–2847. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17026562
Eloubeidi MA, Varadarajulu S, Desai S, . Value of repeat endoscopic ultrasound-guided fine needle aspiration for suspected pancreatic cancer. J Gastroenterol Hepatol. 2008 Apr;23(4):567–70. N <5018397485
Ergul N, Gundogan C, Tozlu M, Toprak H, Kadioglu H, Aydin M, Cermik TF. Role of F-Fluorodeoxyglucose Positron Emission Tomography/Computed Tomography in diagnosis and management of pancreatic cancer; comparison with Multidetector Row Computed Tomography, Magnetic Resonance Imaging and Endoscopic Ultrasonography. Rev Esp Med Nucl Imagen Mol. 2013 Oct 16; Not English
Erickson RA, Garza AA. Impact of endoscopic ultrasound on the management and outcome of pancreatic carcinoma. Am J Gastroenterol. 2000 Sep;95(9):2248–54. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11007225
Erickson RA, Sayage-Rabie L, Beissner RS. Factors predicting the number of EUS-guided fine-needle passes for diagnosis of pancreatic malignancies. Gastrointest Endosc. 2000 Feb;51(2):184–90. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives10650262
Erturk SM, Mortele KJ, Tuncali K, . Fine-needle aspiration biopsy of solid pancreatic masses: comparison of CT and endoscopic sonography guidance. AJR Am J Roentgenol. 2006 Dec;187(6):1531–5. Only a single imaging test of interest, and N<5017114547
Eser G, Karabacakoglu A, Karakose S, . Mangafodipir trisodium-enhanced magnetic resonance imaging for evaluation of pancreatic mass and mass-like lesions. World J Gastroenterol. 2006 Mar 14;12(10):1603–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16570354
Faigel DO. Quality, competency and endosonography. Endoscopy. 2006 Jun;38(SUPPL. 1):S65–S69. Narrative review16802229
Falconi M, Plockinger U, Kwekkeboom DJ, . Well-differentiated pancreatic nonfunctioning tumors/carcinoma. Neuroendocrinology. 2007 Feb;84(3):196–211. Narrative review
Fan Z, Li Y, Yan K, Wu W, Yin S, Yang W, Xing B, Li X, Zhang X. Application of contrast-enhanced ultrasound in the diagnosis of solid pancreatic lesions - A comparison of conventional ultrasound and contrast-enhanced CT. Eur J Radiol. September 2013;82(9):1385–1390. Single test of interest and no harms/screening/patient preference data23727375
Fan Z, Li Y, Yan K, Wu W, Yin S, Yang W, Xing B, Li X, Zhang X. Application of contrast-enhanced ultrasound in the diagnosis of solid pancreatic lesions-a comparison of conventional ultrasound and contrast-enhanced CT. Eur J Radiol. 2013 Sep;82(9):1385–90. Duplicate23727375
Fanning S, Kwok A, Jones B, . EUS aspiration needle size: Smaller is better? Gastrointest Endosc. 2010 Oct;72(4):904–905. Just a meeting abstract
Farrell RJ, Agarwal B, Brandwein SL, . Intraductal US is a useful adjunct to ERCP for distinguishing malignant from benign biliary strictures. Gastrointest Endosc. 2002 Nov 1;56(5):681–687. No data specific to an imaging test of interest12397276
Fatima H, DeWitt J, LeBlanc J, . Nurse-administered propofol sedation for upper endoscopic ultrasonography. Am J Gastroenterol. 2008 Jul;103(7):1649–56. Not specific to pancreatic cancer, data on harms but is pre-200918557709
Fischer MA, Nanz D, Hany T, . Diagnostic accuracy of whole-body MRI/DWI image fusion for detection of malignant tumours: a comparison with PET/CT. Eur Radiol. 2011 Feb;21(2):246–255. 2+ tests, but <10 patients per imaging test20717828
Fischer U, Vosshenrich R, Horstmann O, . Preoperative local MRI-staging of patients with a suspected pancreatic mass. Eur Radiol. 2002 Feb;12(2):296–303. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11870425
Foster RA, Gilles D, Philcox SM. Endoscopic ultrasound (EUS) for suspected pancreaticobiliary malignancy at a tertiary referral centre. J Gastroenterol Hepatol. 2012 Oct;27:55. Just a meeting abstract
Francesco P, Marechal R, Demetter P, Verset L, Eisendrath P, Calomme A, Toussaint E, Bachet J-B, Arvanitakis M, Deviere JM, Laethem Jean-Luc V. Eus fine needle aspiration and biopsy sample quality analysis for HENT1 immunohistochemical staining in pancreatic cancer management. Gastrointest Endosc. 20130518 Conference End: 20130521; Just a meeting abstract
Fritscher-Ravens A, Brand L, Knofel WT, . Comparison of endoscopic ultrasound-guided fine needle aspiration for focal pancreatic lesions in patients with normal parenchyma and chronic pancreatitis. Am J Gastroenterol. 2002 Nov;97(11):2768–75. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12425546
Fritscher-Ravens A, Izbicki JR, Sriram PV, . Endosonography-guided, fine-needle aspiration cytology extending the indication for organ-preserving pancreatic surgery. Am J Gastroenterol. 2000 Sep;95(9):2255–60. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11007226
Fuccio L, Hassan C, Laterza L, Pagano N, Bocus P, Fabbri C, Cennamo V, Repici A, Costamagna G, Bazzoli F, Larghi A. The role of K-RAS gene mutation analysis in EUS-FNA cytological specimens for the differential diagnosis of pancreatic masses: A meta-analysis. Dig Liver Dis. 20130320 Conference End: 20130323. Just a meeting abstract
Fukukura Y, Takumi K, Kamimura K, . Pancreatic Adenocarcinoma: Variability of Diffusion-weighted MR Imaging Findings. Radiology. 2012 Apr 24. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Fukukura Y, Takumi K, Kamiyama T, . Pancreatic adenocarcinoma: a comparison of automatic bolus tracking and empirical scan delay. Abdom Imaging. 2010 Oct;35(5):548–55. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19588187
Furukawa H, Uesaka K, Boku N. Treatment decision making in pancreatic adenocarcinoma: multidisciplinary team discussion with multidetector-row computed tomography. Arch Surg. 2008 Mar;143(3):275–80; discussion 281. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18347275
Fusari M, Maurea S, Imbriaco M, . Comparison between multislice CT and MR imaging in the diagnostic evaluation of patients with pancreatic masses. Radiol Med. 2010 Apr;115(3):453–66. Non-English20077047
Fusaroli P, Kypraios D, Caletti G, . Pancreatico-biliary endoscopic ultrasound: A systematic review of the levels of evidence, performance and outcomes. World J Gastroenterol. 2012 Aug 28;18(32):4243–56. No reviewer estimates of sensitivity and specificity22969187
Fusaroli P, Kypraios D, Eloubeidi MA, . Levels of evidence in endoscopic ultrasonography: a systematic review. Dig Dis Sci. 2012 Mar;57(3):602–9. Narrative review22057240
Fusaroli P, Vallar R, Togliani T, . Scientific publications in endoscopic ultrasonography: a 20-year global survey of the literature. Endoscopy. 2002 Jun;34(6):451–6. No outcomes of interest12048626
Gabata T, Matsui O, Terayama N, . Imaging diagnosis of hepatic metastases of pancreatic carcinomas: Significance of transient wedge-shaped contrast enhancement mimicking arterioportal shunt. Abdom Imaging. 2008 Jul;33(4):437–443. No comparative specificity data17610105
Gabbard SL, Sampath K, Gordon SR, Gardner TB. Diagnostic yield and safety of the 22 vs. 25 gauge expect needles for solid malignancies: Results of a prospective randomized trial. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB358–9. Just a meeting abstract
Gagovic V, Spier BJ, DeLee RJ, . Endoscopic ultrasound fine-needle aspiration characteristics of primary adenocarcinoma versus other malignant neoplasms of the pancreas. Can J Gastroenterol. 2012 Oct;26(10):691–696. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23061060
Gallix BP, Bret PM, Atri M, . Comparison of qualitative and quantitative measurements on unenhanced T1-weighted fat saturation MR images in predicting pancreatic pathology. J Magn Reson Imaging. 2005 May;21(5):583–589. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15834922
Gangi S, Fletcher JG, Nathan MA, . Time interval between abnormalities seen on CT and the clinical diagnosis of pancreatic cancer: retrospective review of CT scans obtained before diagnosis. AJR Am J Roentgenol. 2004 Apr;182(4):897–903. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15039161
Gardner TB. Endoscopic ultrasonography. Gastrointest Endosc. 2012 Sep;76(3):510–5. Narrative review22898409
Gerritsen A, Molenaar IQ, Bollen TL, Nio CY, Dijkgraaf MG, Van Santvoort HC, Offerhaus GJ, Sieders E, De Jong KP, Van Dam RM, Van Der Harst E, Van Goor H, Van Ramshorst B, Bonsing BA, De Hingh IH, Gerhards MF, Van Eijck CH, Gouma DJ, Borel Rinkes IHM, Busch OR, Besselink MGH. Preoperative characteristics of patients with presumed pancreatic cancer but ultimately benign disease: A multicenter series of 344 pancreatoduodenectomies. Pancreatology. 2013 May–Jun;13(3 Suppl 1):S11. Just a meeting abstract
Ghaneh P, Costello E, Neoptolemos JP. Biology and management of pancreatic cancer. Postgrad Med J. 2008 Sep;84(995):478–497. Narrative review18940950
Gheonea DI, Streba CT, Ioncica AM, . Diagnosis of focal pancreatic masses by quantitative low mechanical index contrast-enhanced Endoscopic Ultrasound (EUS). Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB205. Just a meeting abstract
Gilbert D, Penman ID. Endoscopic ultrasound. Endoscopy. 2008 Oct;40(10):849–854. Narrative review18828082
Giorgadze TA, Peterman H, Baloch ZW, . Diagnostic utility of mucin profile in fine-needle aspiration specimens of the pancreas: An immunohistochemical study with surgical pathology correlation. Cancer. 2006 Jun 25;108(3):186–197. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16628655
Giorgetti A, Genovesi D, Bottoni A, . Different SUVmax cut-off values improve the diagnostic accuracy of 18-FDG PET/TC in patients with pancreatic lesions. Eur J Nucl Med Mol Imaging. 2010 Oct;37:S431. Just a meeting abstract
Giorgetti A, Salemi S, Boraschi P, . MRI versus 18F-FDG PET/CT in the differential diagnosis of benign and malignant lesions of the pancreas. Eur J Nucl Med Mol Imaging. 2010 Oct;37:S431. Just a meeting abstract
Glant JA, Waters JA, House MG, . Does the interval from imaging to operation affect the rate of unanticipated metastasis encountered during operation for pancreatic adenocarcinoma? Surgery. 2011 Oct;150(4):607–16. No outcomes of interest22000171
Gleeson FC, Kipp BR, Caudill JL, . False positive endoscopic ultrasound fine needle aspiration cytology: incidence and risk factors. Gut. 2010 May;59(5):586–93. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20427392
Gleeson FC, Levy MJ. Endoscopic ultrasound. Endoscopy. 2011;43(1):54–57. Narrative review21234842
Gogou L, Filippi V, Vlachou F, . Is 18F-FDG-PET/CT a useful technique for staging and restaging patients with pancreatic adenocarcinoma? Comparison with Conventional Imaging. Eur J Nucl Med Mol Imaging. 2010 Oct;37:S432. Just a meeting abstract
Goh BKP. Pancreatic cysts 3 cm or smaller [5]. Radiology. 2007 May;243(2):607. Just a meeting abstract17456886
Gong TT, Hu DM, Zhu Q. Contrast-enhanced EUS for differential diagnosis of pancreatic mass lesions: a meta-analysis. Gastrointest Endosc. 2012 Aug;76(2):301–9. No data specific to an imaging test of interest22703697
Grieser C, Steffen IG, Grajewski L, . Preoperative multidetector row computed tomography for evaluation and assessment of resection criteria in patients with pancreatic masses. Acta Radiol. 2010 Dec;51(10):1067–77. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20929294
Grossjohann HS, Rappeport ED, Jensen C, . Usefulness of contrast-enhanced transabdominal ultrasound for tumor classification and tumor staging in the pancreatic head. Scand J Gastroenterol. 2010 Aug;45(7–8):917–24. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20441527
Haba S, Yamao K, Bhatia V, . Diagnostic ability and factors affecting accuracy of endoscopic ultrasound-guided fine needle aspiration for pancreatic solid lesions: Japanese large single center experience. J Gastroenterol. 2012 Oct 24. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Haba S, Yamao K, Mizuno N, . Diagnostic ability of endoscopic ultrasoundguided fine needle aspiration for pancreatic solid lesions: A large single center experience. J Gastroenterol Hepatol. 2011 Oct;26:240. Just a meeting abstract21155883
Hall WA, Mikell JL, Mittal P, . Tumor size on abdominal MRI versus pathologic specimen in resected pancreatic adenocarcinoma: implications for radiation treatment planning. Int J Radiat Oncol Biol Phys. 2013 Jan 3. Just a meeting abstract
Halm U, Rohde N, Klapdor R, . Improved sensitivity of fuzzy logic based tumor marker profiles for diagnosis of pancreatic carcinoma Versus benign pancreatic disease. Anticancer Res. 2000;20(6 D):4957–4960. No data specific to an imaging test of interest11326646
Hamm B. Multi-detector CT of the abdomen. Eur Radiol. 2003;13 Just a meeting abstract
Han A, Xue J, Hu M, . Clinical value of 18F-FDG PET/CT in detecting primary tumor for patients with carcinoma of unknown primary. Cancer Epidemiol. 2012 Oct;36(5):470–475. Only a single imaging test of interest, and N <5022504050
Harewood GC, Wiersema LM, Halling AC, . Influence of EUS training and pathology interpretation on accuracy of EUS-guided fine needle aspiration of pancreatic masses. Gastrointest Endosc. 2002 May;55(6):669–673. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11979248
Harewood GC, Wiersema MJ. Pancreatic cancer - New hope for early detection. Am J Gastroenterol. 2002;97(2):486. Just a meeting abstract
Hayakawa T, Jin CX, Hirooka Y. Endoscopic ultrasonography of the pancreas: New advances. JOP. 2000 Sep;1(3):46–48. Narrative review11854557
Hayano K, Miura F, Amano H, . Correlation of apparent diffusion coefficient measured by diffusion-weighted MRI and clinicopathologic features in pancreatic cancer patients. J Hepatobiliary Pancreat Sci. 2013 Feb;20(2):243–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22311389
Hebert-Magee S, Treece A, Mukhtar F, . Diagnostic accuracy of endoscopic ultrasound-guided fine-needle aspiration in patients with pancreatic adenocarcinoma using histology as the gold standard. Lab Invest. 2012 Feb;92:444A. Just a meeting abstract
Hedenstrom P, Demir A, Lindkvist B, Sadik R. The combination of EUS-FNA and EUS-FNB improves the diagnostic accuracy compared with EUS-FNA alone in difficult lesions-a randomised comparative study. Gastrointest Endosc. 20130518 Conference End: 20130521. Just a meeting abstract
Henkes DN, Patel SN, Rosenkranz LA, . The utility of UroVysion fluorescence in situ hybridization in pancreatic fine-needle aspiration samples directed and obtained by endoscopic ultrasonography. Arch Pathol Lab Med. 2013 Jan;137(1):64–71. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23276176
Hewitt M, McPhail M, Possamai L, . A meta-analysis of endoscopic ultrasound with fine needle aspiration(EUS-FNA)for diagnosis of solid pancreatic neoplasms. Gut. 2011 Apr;60: Suppl 1:A190–1. Just a meeting abstract
Higashi T, Saga T, Nakamoto Y, . Relationship between retention index in dual-phase (18)F-FDG PET, and hexokinase-II and glucose transporter-1 expression in pancreatic cancer. J Nucl Med. 2002 Feb;43(2):173–80. No data specific to an imaging test of interest11850481
Hirokawa Y, Isoda H, Okada T, . Improved detection of hepatic metastases from pancreatic cancer using periodically rotated overlapping parallel lines with enhanced reconstruction (PROPELLER) technique after SPIO administration. Invest Radiol. 2010 Mar;45(3):158–64. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20142748
Ho JM, Darcy SJ, Eysselein VE, . Evolution of fine needle aspiration cytology in the accurate diagnosis of pancreatic neoplasms. Am Surg. 2007 Oct;73(10):941–4. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17983052
Ho S, Bonasera RJ, Pollack BJ, . A single-center experience of endoscopic ultrasonography for enlarged pancreas on computed tomography. Clin Gastroenterol Hepatol. 2006 Jan;4(1):98–103. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16431311
Hocke M, Schulze E, Gottschalk P, . Contrast-enhanced endoscopic ultrasound in discrimination between focal pancreatitis and pancreatic cancer. World J Gastroenterol. 2006 Jan 14;12(2):246–250. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16482625
Holm J, Loizou L, Albiin N, . Low tube voltage CT for improved detection of pancreatic cancer: detection threshold for small, simulated lesions. BMC Med Imag. 2012;12:20. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Horwhat JD, Gerke H, Acosta RD, Pavey DA, Jowell PS. Focal or diffuse “fullness” of the pancreas on CT. Usually benign, but EUS plus/minus FNA is warranted to identify malignancy. JOP 2009; 10(1): 37–42. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19129613
Hottenrott C. Endoscopic and laparoscopic ultrasonography used to predict tumor staging and improve therapeutic decisions for upper gastrointestinal tract cancer. Surg Endosc. 2012 Jan;26(1):280–281. News/opinion/editorial21789638
House MG, Yeo CJ, Cameron JL, . Predicting resectability of periampullary cancer with three-dimensional computed tomography. J Gastrointest Surg. 2004 Mar–Apr;8(3):280–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15019924
Hu DM, Gong TT, Zhu Q. Endoscopic Ultrasound Elastography for Differential Diagnosis of Pancreatic Masses: A Meta-Analysis. Dig Dis Sci. 2013 Jan 10. No data specific to an imaging test of interest
Hu J, Zhang X, Li B, Zhang M, Wang C, Chen G. The clinical value of 18F-FDG PET/CT in the evaluation of bone metastases undetermined origin. Clin Imaging. September 2013;37(5):922–924. Single test of interest and no harms/screening/patient preference data23849830
Hu SL, Yang ZY, Zhou ZR, . Role of SUVmax obtained by 18F-FDG PET/CT in patients with a solitary pancreatic lesion: predicting malignant potential and proliferation. Nucl Med Commun. 2013 Mar 14. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Hua YP, Liang LJ, Peng BG, . Pancreatic head carcinoma: clinical analysis of 189 cases. Hepatobiliary Pancreat Dis Int. 2009 Feb;8(1):79–84. No comparative specificity data19208521
Huang Q-J, Xu Q, Wang X-N, . Spiral multi-phase CT in evaluating resectability of pancreatic carcinoma. Hepatobiliary Pancreat Dis Int. 2002 Nov;1(4):614–619. No data specific to an imaging test of interest14607698
Huang WC, Sheng J, Chen SY, . Differentiation between pancreatic carcinoma and mass-forming chronic pancreatitis: usefulness of high b value diffusion-weighted imaging. J Dig Dis. 2011 Oct;12(5):401–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21955434
Hucl T, Wee E, Anuradha S, Gupta R, Ramchandani M, Rakesh K, Shrestha R, Reddy DN, Lakhtakia S. Feasibility and efficiency of a new 22G core needle: a prospective comparison study. Endoscopy. 2013 Oct;45(10):792–8. Duplicate24068588
Hunt D, Kuhn P, Bethel K, Kuldau J, Luttgen M, Coyle W. Measurement of circulating tumor cell levels before and after endoscopic ultrasound-guided fine needle aspiration in patients with newly diagnosed pancreatic adenocarcinoma: Interim analysis. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB400–1. Just a meeting abstract
Hunt GC, Faigel DO. Assessment of EUS for diagnosing, staging, and determining resectability of pancreatic cancer: a review. Gastrointest Endosc. 2002 Feb;55(2):232–7. Narrative review11818928
Hwang JC, Lim MK, Kim SC, Kim JH, Yoo BM. A comparative study of 22-gauge aspiration and 25-gauge biopsy needles for endoscopic ultrasound guided sampling of solid pancreatic mass lesions. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S48–9. Just a meeting abstract
Ibrahim AA, Cramer HM, Wu HH. Endoscopic ultrasound-guided fine-needle aspiration of the pancreas: A retrospective study of 1,000 cases. Lab Invest. 2013 Feb;93:93A. Just a meeting abstract
Ichikawa T, Erturk SM, Sou H, . MDCT of pancreatic adenocarcinoma: optimal imaging phases and multiplanar reformatted imaging. AJR Am J Roentgenol. 2006 Dec;187(6):1513–20. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17114545
Ichikawa T, Sou H, Araki T, . Duct-penetrating sign at MRCP: usefulness for differentiating inflammatory pancreatic mass from pancreatic carcinomas. Radiology. 2001 Oct;221(1):107–16. No data specific to an imaging test of interest11568327
Ide M, Suzuki Y, Weckesser M, . Is whole-body FDG-PET valuable for health screening? Eur J Nucl Med Mol Imaging. 2005 Mar;32(3):339–343. Narrative review15726352
Iglesias-Garcia J, Abdulkader I, Larino-Noia J, . Differential diagnosis of solid pancreatic masses: Do procore histology needles improve the diagnostic yield of standard cytology needles? Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB203. Just a meeting abstract
Iglesias-Garcia J, Dominguez-Munoz E, Lozano-Leon A, . Impact of endoscopic ultrasound-guided fine needle biopsy for diagnosis of pancreatic masses. World J Gastroenterol. 2007 Jan 14;13(2):289–93. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17226911
Iglesias-Garcia J, Lindkvist B, Cruz-Soares JB, . Differential diagnosis of solid pancreatic masses. Contrast-enhanced harmonic endoscopic ultrasound, quantitative-elastography endoscopic ultrasound or both? Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB147. Just a meeting abstract
Ikuta Y, Takamori H, Ikeda O, . Detection of liver metastases secondary to pancreatic cancer: utility of combined helical computed tomography during arterial portography with biphasic computed tomography-assisted hepatic arteriography. J Gastroenterol. 2010 Dec;45(12):1241–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20635101
Imai K, Matsubayashi H, Fukutomi A, . Endoscopic ultrasonography-guided fine needle aspiration biopsy using 22-gauge needle in diagnosis of autoimmune pancreatitis. Dig Liver Dis. 2011 Nov;43(11):869–74. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21733766
Imbriaco M, Megibow AJ, Camera L, Pace L, Mainenti PP, Romano M, Selva G, Salvatore M. Dual-phase versus single-phase helical CT to detect and assess resectability of pancreatic carcinoma. AJR Am J Roentgenol. 2002 Jun;178(6), 1473–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12034622
Imbriaco M, Megibow AJ, Ragozzino A, . Value of the single-phase technique in MDCT assessment of pancreatic tumors. AJR Am J Roentgenol. 2005;184(4):1111–1117. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15788581
Imbriaco M, Smeraldo D, Liuzzi R, . Multislice CT with single-phase technique in patients with suspected pancreatic cancer. Radiol Med. 2006 Mar;111(2):159–66. Non-English16671374
Imbriaco M, Smeraldo D, Liuzzi R, . TC multistrato con tecnica monofasica nei pazienti con sospetto tumore pancreatico. Radiol Med. 2006 Mar;111(2):159–166. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16671374
Iordache S, Saftoiu A, Cazacu S, . Endoscopic ultrasound approach of pancreatic cancer in chronic pancreatitis patients in a tertiary referral centre. J Gastrointest Liver Dis. 2008 Sep;17(3):279–284. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Iqbal S, Quddus-ur-Rehman, Latif U, . Etiology and diagnosis of obstructive jaundice, our experience. Med Forum Mon. August 2012;23(8):39–43. Unable to obtain
Irie H, Honda H, Aibe H, . Efficacy of three-dimensional fast imaging with steady precession dynamic MR imaging in evaluating pancreatic ductal adenocarcinoma. Clin Imaging. 2001;25(1):50–56. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11435041
Ishigami K, Tajima T, Nishie A, . Differential diagnosis of groove pancreatic carcinomas vs. groove pancreatitis: Usefulness of the portal venous phase. Eur J Radiol. 2010 Jun;74(3):e95–e100. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19450943
Ishigami K, Yoshimitsu K, Irie H, . Diagnostic value of the delayed phase image for iso-attenuating pancreatic carcinomas in the pancreatic parenchymal phase on multidetector computed tomography. Eur J Radiol. 2009 Jan;69(1):139–146. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17961951
Ishikawa S, Aoki J, Ohwada S, . Mass screening of multiple abdominal solid organs using mobile helical computed tomography scanner - A preliminary report. Asian J Surg. 2007 Apr;30(2):118–121. Screening healthy people17475581
Ishikawa S, Aoki J, Ohwada S, . Mass screening of multiple abdominal solid organs using mobile helical computed tomography scanner-a preliminary report. Asian J Surg. 2007 Apr;30(2):118–21. Screening healthy people17475581
Ishimaru K, Ishimaru H, Matsuoka Y, . Multidetector-row CT in patients with suspected obstructive jaundice: Comparison with non-contrast MRI with MR cholangiopancreatography. Acta Med Nagasaki. 2006;50(4):147–154. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Itoi T, Itokawa F, Sofuni A, . Puncture of solid pancreatic tumors guided by endoscopic ultrasonography: a pilot study series comparing Trucut and 19-gauge and 22-gauge aspiration needles. Endoscopy. 2005 Apr;37(4):362–6. Only a single imaging test of interest, and N <5015824948
Itoi T, Takei K, Sofuni A, . Immunohistochemical analysis of p53 and MIB-1 in tissue specimens obtained from endoscopic ultrasonography-guided fine needle aspiration biopsy for the diagnosis of solid pancreatic masses. Oncol Rep (Athens). 2005 Feb;13(2):229–34. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Iwanicki-Caron I, Basile P, Toure E, . Usefulness of circulating tumor cell detection in pancreatic adenocarcinoma diagnosis. Am J Gastroenterol. 2013 Jan;108(1):152–5. Just a meeting abstract23287955
Izuishi K, Yamamoto Y, Sano T, . Impact of 18-fluorodeoxyglucose positron emission tomography on the management of pancreatic cancer. J Gastrointest Surg. 2010 Jul;14(7):1151–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20443074
Jacobsen R-L, Larsen AC, Fisker RV, . Integrated PET/CT in diagnostic workup of pancreatic and biliary tract cancer. HPB. 2011 Apr;13:115. Just a meeting abstract
Janssen J, Konig K, Knop-Hammad V, . Frequency of bacteremia after linear EUS of the upper GI tract with and without FNA. Gastrointest Endosc. 2004 Mar;59(3):339–344. Not pancreatic adenocarcinoma14997128
Javery O, Shyn P, Mortele K. FDG PET or PET/CT in patients with pancreatic cancer: when does it add to diagnostic CT or MRI. Clin Imaging. 2013 Mar;37(2):295–301. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23465982
Javery O, Shyn P, Mortele K. FDG PET or PET/CT in patients with pancreatic cancer: when does it add to diagnostic CT or MRI? Clin Imaging. 2013 Mar–Apr;37(2):295–301. Single test of interest and no harms/screening/patient preference data23465982
Jeffrey RB. Pancreatic cancer: radiologic imaging. Gastroenterol Clin North Am. 2012 Mar;41(1):159–77. Narrative review22341256
Jemaa Y, Houissa F, Trabelsi S, . Endoscopic ultrasonography versus helical CT in diagnosis and staging of pancreatic cancer. Tunis Med. 2008 Apr;86(4):346–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19476136
Jeong SU, Lee SS, Lee BU, . The comparative study of endoscopic EUS-guided fine-needle aspiration using 22-gauge and 25-gauge aspiration needle for solid pancreatic or peripancreatic masses. J Gastroenterol Hepatol. 2012;27:123. Just a meeting abstract
Jhala NC, Eltoum IA, Eloubeidi MA, . Providing on-site diagnosis of malignancy on endoscopic-ultrasound-guided fine-needle aspirates: should it be done? Ann Diagn Pathol. 2007 Jun;11(3):176–81. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17498591
Jhala NC, Jhala D, Eltoum I, . Endoscopic ultrasound-guided fine-needle aspiration biopsy: a powerful tool to obtain samples from small lesions. Cancer. 2004 Aug 25;102(4):239–46. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15368316
Jin Z, Li X, Cai L. Assessing the resectability of pancreatic ductal adenocarcinoma: comparision of dual-phase helical CT arterial portography with conventional angiography. Chin Med Sci J. 2001 Mar;16(1):40–5. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12899347
Jing X, Wamsteker E-J, Li H, . Combining fine needle aspiration with brushing cytology has improved yields in diagnosing pancreatic ductal adenocarcinoma. Diagn Cytopathol. 2009 Aug;37(8):574–578. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19306410
Jorgensen MT, Mortensen MB, Gerdes A-M, . Familial pancreatic cancer. Scand J Gastroenterol. 2008;43(4):387–397. Narrative review18365902
Jung JG, Kang KJ, Oh CR, Lee JK, Lee KT, Jang KT, Choi JH, Park SM, Lee KH. Histological and immunohistochemical evaluation using endoscopic ultrasound-guided fine-needle aspiration in solid masses. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S45. Just a meeting abstract
Kaffes AJ, Mishra A, Simpson SB, . Upper gastrointestinal endoscopic ultrasound and its impact on patient management: 1990–2000. Intern Med J. 2002 Aug;32(8):372–8. Not pancreatic adenocarcinoma12162393
Kala Z, Valek V, Hlavsa J, . The role of CT and endoscopic ultrasound in pre-operative staging of pancreatic cancer. Eur J Radiol. 2007 May;62(2):166–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17344007
Kalade AV, Desmond PV, Chen RY. Experience of endoscopic ultrasound in an Australian tertiary hospital. ANZ J Surg. 2006 Dec;76(12):1075–80. Not pancreatic adenocarcinoma17199693
Kali A, Gurusamy KS, Alle V, . Role of diagnostic laparoscopy in assessing resectability of pancreatic and periampullary cancer. Int J Surg. 2011;9(5):368. Just a meeting abstract
Kamisawa T, Imai M, Yui Chen P, . Strategy for differentiating autoimmune pancreatitis from pancreatic cancer. Pancreas. 2008 Oct;37(3):e62–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18815540
Kamisawa T, Takuma K, Anjiki H, . Differentiation of autoimmune pancreatitis from pancreatic cancer by diffusion-weighted MRI. Am J Gastroenterol. 2010 Aug;105(8):1870–1875. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20216538
Kaneko OF, Lee DM, Wong J, . Performance of multidetector computed tomographic angiography in determining surgical resectability of pancreatic head adenocarcinoma. J Comput Assist Tomogr. 2010 Sep–Oct;34(5):732–738. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20861777
Kang KM, Lee JM, Yoon JH, Kiefer B, Han JK, Choi BI. Intravoxel Incoherent Motion Diffusion-weighted MR Imaging for Characterization of Focal Pancreatic Lesions. Radiology. 2013 Oct 14; Single test of interest and no harms/screening/patient preference data
Karl RC. Efficacy of detection methods for metastatic gastrointestinal cancers. Cancer Control. 1998;5(3 Suppl.):21–24. Narrative review10762476
Karmazanovsky G, Fedorov V, Kubyshkin V, . Pancreatic head cancer: accuracy of CT in determination of resectability. Abdom Imaging. 2005 Jul–Aug;30(4):488–500. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15759205
Karoumpalis I, Sigalas P, Salla C, . Endoscopic ultrasound staging and guided fine needle aspiration biopsy in patients with resectable pancreatic malignancies: a single-center prospective experience. Onkologie. 2011;34(10):533–7. Non-English21985852
Karstensen JG, Cartana T, Hassan H, Gheonea DI, Popescu CF, Linnemann D, Saftoiu A, Vilmann P. Needle-based confocal laser endomicroscopy examination of pancreatic masses. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB411. Just a meeting abstract
Kartalis N, Lindholm TL, Aspelin P, . Diffusion-weighted magnetic resonance imaging of pancreas tumours. Eur Radiol. 2009 Aug;19(8):1981–90. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19308414
Kartalis N, Loizou L, Edsborg N, . Optimising diffusion-weighted MR imaging for demonstrating pancreatic cancer: a comparison of respiratory-triggered, free-breathing and breath-hold techniques. Eur Radiol. 2012 Oct;22(10):2186–92. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22549106
Kasperk RK, Riesener KP, Wilms K, . Limited value of positron emission tomography in treatment of pancreatic cancer: surgeon’s view. World J Surg. 2001 Sep;25(9):1134–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11571948
Kent TS, Raptopoulos V, Callery MP, . Escalating computed tomography angiogram (CTA) grade predicts unresectability and margin status for pancreaticobiliary neoplasms. HPB. 2010 Mar;12(2):115–22. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20495655
Khalili K, Doyle DJ, Chawla TP, . Renal lesions in autoimmune pancreatitis aid the differentiation from pancreatic adenocarcinoma. Pancreas. 2009 Oct;38(7):833. Just a meeting abstract19893457
Khan AH, Austin GL, Fukami N, Sethi A, Brauer BC, Shah RJ. Cholangiopancreatoscopy and endoscopic ultrasound for indeterminate pancreaticobiliary pathology. Dig Dis Sci. 2013 Apr;58(4):1110–5. Single test of interest and no harms/screening/patient preference data23161267
Kida M, Araki M, Miyazawa S, . Comparison of diagnostic accuracy of endoscopic ultrasound-guided fine-needle aspiration with 22- and 25-gauge needles in the same patients. J Interv Gastroenterol. 2011 Jul;1(3):102–107. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22163079
Kida M. Endoscopic tumor diagnosis and treatment. Endoscopy. 2002 Nov 1;34(11):860–870. Narrative review12430069
Kim JH, Eun HW, Kim KW, Lee JY, Lee JM, Han JK, Choi BI. Diagnostic performance of MDCT for predicting important prognostic factors in pancreatic cancer. Pancreas. 2013 Nov;42(8):1316–22. Single test of interest and no harms/screening/patient preference data24152957
Kim JH, Park SH, Yu ES, . Visually isoattenuating pancreatic adenocarcinoma at dynamic-enhanced CT: frequency, clinical and pathologic characteristics, and diagnosis at imaging examinations. Radiology. 2010 Oct;257(1):87–96. No comparative specificity data20697118
Kim MJ, Lee KH, Lee KT, . The value of positron emission tomography/computed tomography for evaluating metastatic disease in patients with pancreatic cancer. Pancreas. 2012 Aug;41(6):897–903. No comparative specificity data22699202
Kim T, Murakami T, Takamura M, . Original report. Pancreatic mass due to chronic pancreatitis: Correlation of CT and MR imaging features with pathologic findings. AJR Am J Roentgenol. 2001;177(2):367–371. 2+ tests, but <10 patients per imaging test11461864
Kim TH, Choi KH, Song HS, Kim JW, Jeon BJ. Histology combined with cytology by endoscopic ultrasound-guided fine needle aspiration for the diagnosis of solid pancreatic mass and intra-abdominal lymphadenopathy. Gut Liver. September 2013;7(5):605–610. Single test of interest and no harms/screening/patient preference data24073320
Kim YC, Park MS, Cha SW, . Comparison of CT and MRI for presurgical characterization of paraaortic lymph nodes in patients with pancreatico-biliary carcinoma. World J Gastroenterol. 2008 Apr 14;14(14):2208–12. Not pancreatic adenocarcinoma18407595
Kimmey MB, Bronner MP, Byrd DR, . Screening and surveillance for hereditary pancreatic cancer. Gastrointest Endosc. 2002 Oct;56:(4 Suppl):S82–6. Narrative review12297755
Kimura Y, Kurokami T, Kodama Y, Chiba T, Kikuyama M. Acute pancreatitis as a high risk group for pancreatic cancer. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S22. Just a meeting abstract
Kipp BR, Pereira TC, Souza PC, . Comparison of EUS-guided FNA and Trucut biopsy for diagnosing and staging abdominal and mediastinal neoplasms. Diagn Cytopathol. 2009 Aug;37(8):549–556. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19217057
Kirkpatrick ID, Desser TS, Nino-Murcia M, . Small cystic lesions of the pancreas: clinical significance and findings at follow-up. Abdom Imaging. 2007 Jan–Feb;32(1):119–25. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16944031
Kitano M, Kudo M, Maekawa K, . Dynamic imaging of pancreatic diseases by contrast enhanced coded phase inversion harmonic ultrasonoqraphy. Gut. 2004 Jun;53(6):854–859. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15138213
Kitano M, Kudo M, Yamao K, . Characterization of small solid tumors in the pancreas: the value of contrast-enhanced harmonic endoscopic ultrasonography. Am J Gastroenterol. 2012 Feb;107(2):303–10. No comparative accuracy data on 2+ tests of interest22008892
Klapman JB, Logrono R, Dye CE, . Clinical impact of on-site cytopathology interpretation on endoscopic ultrasound-guided fine needle aspiration. Am J Gastroenterol. 2003 Jun 1;98(6):1289–1294. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12818271
Klauss M, Mohr A, von Tengg-Kobligk H, . A new invasion score for determining the resectability of pancreatic carcinomas with contrast-enhanced multidetector computed tomography. Pancreatology. 2008;8(2):204–10. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18434758
Klek S, Kulig J, Popiela T, . The value of modern ultrasonographic techniques and computed tomography in detecting and staging of pancreatic carcinoma. Acta Chir Belg. 2004 Nov–Dec;104(6):659–67. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15663271
Klek S, Kulig J, Popiela T, . Wartosc kliniczna wspolczesnej ultrasonografii i tomografii komputerowej w rozpoznawaniu i ocenie stopnia zaawansowania raka trzustki. Pol Przegl Chir. 2004;76(8):809–822. Non-English
Knudson K, Raeburn CD, McIntyre Jr RC, . Management of duodenal and pancreaticobiliary perforations associated with periampullary endoscopic procedures. Am J Surg. 2008 Dec;196(6):975–982. No data specific to an imaging test of interest19095118
Kobayashi A, Yamaguchi T, Ishihara T, . Assessment of portal vein invasion in pancreatic cancer by fusion 3-dimensional ultrasonography. J Ultrasound Med. 2005 Mar;24(3):363–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15723849
Koc Z, Erbay G. Optimal b value in diffusion-weighted imaging for differentiation of abdominal lesions. J Magn Reson Imaging. 2013 Sep 23. Single test of interest and no harms/screening/patient preference data
Korenblit J, Singh H, Butt M, Mehendiratta V, Lewis J, Infantolino A, Coben RM, Bibbo M, Siddiqui A, Loren DE, Kowalski TE. Prospective randomized trial of the 22g echotip procore needle versus the 22g cook echotip ultra 3 needle in patients with solid mass lesions undergoing EUS-guided fine needle aspiration (FNA). Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB178. Just a meeting abstract
Kosugi C, Furuse J, Ishii H, . Needle Tract Implantation of Hepatocellular Carcinoma and Pancreatic Carcinoma after Ultrasound-guided Percutaneous Puncture: Clinical and Pathologic Characteristics and the Treatment of Needle Tract Implantation. World J Surg. 2004 Jan;28(1):29–32. No data specific to an imaging test of interest14648043
Koyama K, Okamura T, Kawabe J, . Diagnostic usefulness of FDG PET for pancreatic mass lesions. Ann Nucl Med. 2001 Jun;15(3):217–24. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11545191
Kozarek RA. Analog diagnosis in a digital world: the quest to improve endoscopic tissue acquisition and diagnostic sensitivity in malignant biliary stricture. Clin Gastroenterol Hepatol. 2004 Mar;2(3):207–8. News/opinion/editorial15017603
Krinsky ML, Binmoeller KF. EUS-guided investigational therapy for pancreatic cancer. Gastrointest Endosc. 2000 Dec;52:(6 Suppl):S35–8. No outcomes of interest11115946
Krishna N, Tummala P, Reddy AV, . Dilation of both pancreatic duct and the common bile duct on computed tomography and magnetic resonance imaging scans in patients with or without obstructive jaundice. Pancreas. 2012 Jul;41(5):767–72. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22450366
Krishna NB, LaBundy JL, Saripalli S, . Diagnostic value of EUS-FNA in patients suspected of having pancreatic cancer with a focal lesion on CT scan/MRI but without obstructive jaundice. Pancreas. 2009 Aug;38(6):625–30. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19506529
Krishna NB, Mehra M, Reddy AV, . EUS/EUS-FNA for suspected pancreatic cancer: influence of chronic pancreatitis and clinical presentation with or without obstructive jaundice on performance characteristics. Gastrointest Endosc. 2009 Jul;70(1):70–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19249774
Krishna NB, Tummala P, Mehan CD, . Small and potentially resectable focal pancreatic lesions noted on CT/MRI scans in nonjaundiced patients: likelihood of neoplasia and utility of EUS. J Gastrointest Surg. 2012 Apr;16(4):793–800. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22258870
Krishna SG, Bhattacharya A, Ladha HS, Singh A, Ross WA, Bhutani MS, Fleming JB, Lee JH. Pretest probability and diagnostic accuracy of endoscopic ultrasound-guided fine needle aspiration (EUS-FNA) for pancreatic adenocarcinoma at a tertiary care oncology center: A 12 year experience. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB403. Just a meeting abstract
Krishnan K, Dalal S, Nayar R, Keswani RN, Keefer L, Komanduri S. Rapid on-site evaluation of endoscopic ultrasound core biopsy specimens has excellent specificity and positive predictive value for gastrointestinal lesions. Dig Dis Sci. July 2013;58(7):2007–2012. Only a single imaging test of interest, and N<5023504350
Kulig P, Pach R, Pietruszka S, . Abdominal ultrasonography in detecting and surgical treatment of pancreatic carcinoma. Pol Przegl Chir. 2012 Jun;84(6):285–92. No data specific to an imaging test of interest22842740
Kumar R, Garg P, Midha S, Sharma R, Thulkar S, Shamim SA, Sharma P, Malhotra A. Role of PET/CT in differentiating benign and malignant pancreatic mass lesions in patients with or without chronic pancreatitis. Eur J Nucl Med Mol Imaging. 2011 Oct;38:S181. Just a meeting abstract
Kumar R, Sharma P, Garg P, Sharma R, Singla S, Thulkar S, Malhotra A. Prospective evaluation of dual time 18F-FDG PET/CT for differentiating benign and malignant pancreatic masses: Comparison with contrast enhanced CT and endoscopic ultrasound. Eur J Nucl Med Mol Imaging. 2012 Oct;39:S582. Just a meeting abstract
Kuroki-Suzuki S, Kuroki Y, Nasu K, Nagashima C, Machida M, Muramatsu Y, Moriyama N. Pancreatic cancer screening employing noncontrast magnetic resonance imaging combined with ultrasonography. Jpn J Radiol. 2011 May;29(4):265–71. No data specific to an imaging test of interest21607840
Lachter J, Cooperman JJ, Shiller M, Suissa A, Yassin K, Cohen H, Reshef R. The impact of endoscopic ultrasonography on the management of suspected pancreatic cancer-a comprehensive longitudinal continuous evaluation. Pancreas. 2007 Aug;35(2):130–4. No comparative specificity data17632318
Lakhtakia S, Hucl T, Sekaran A, Wee E, Gupta R, Kalpala R, Shrestha R, Ramchandani MJ, Reddy DN. EUS guided new 22G core needle requires fewer number of passes to diagnose a pancreatic mass. J Gastroenterol Hepatol. 2012 Dec;27:378. Just a meeting abstract21777278
Lan BY, Kwee SA, Wong LL. Positron emission tomography in hepatobiliary and pancreatic malignancies: a review. Am J Surg. 2012 Aug;204(2):232–41. Narrative review22464445
Langer P, Kann PH, Fendrich V, Habbe N, Schneider M, Sina M, Slater EP, Heverhagen JT, Gress TM, Rothmund M, Bartsch DK. Five years of prospective screening of high-risk individuals from families with familial pancreatic cancer. Gut. 2009 Oct;58(10):1410–1418. Duplicate19470496
Larghi A, Iglesias-Garcia J, Poley JW, Monges G, Petrone MC, Rindi G, Abdulkader I, Arcidiacono PG, Costamagna G, Biermann K, Bories E, Doglioni C, Dominguez-Munoz JE, Hassan C, Bruno M, Giovannini M. Feasibility and yield of a novel 22-gauge histology EUS needle in patients with pancreatic masses: a multicenter prospective cohort study. Surg Endosc. 2013 Oct;27(10):3733–8. Single test of interest and no harms/screening/patient preference data23644834
Larino-Noia J, Iglesias-Garcia J, Macias M, . A multicenter, prospective, comparative, randomized open-trial of endoscopic ultrasound cytologic brushing vs fine-needle aspiration (FNA) for the pathological diagnosis of cystic pancreatic lesions. Pancreatology. 2012 Nov–Dec;12(6):528. Just a meeting abstract
Latchford A, Greenhalf W, Vitone LJ, . Peutz-Jeghers syndrome and screening for pancreatic cancer. Br J Surg. 2006 Dec;93(12):1446–55. Narrative review17115408
Latronico A, Crosta C, De Fiori E, . Endoscopic ultrasound and Computed Tomography in the diagnosis, locoregional staging and assessment of vascular infiltration of pancreatic carcinoma. Radiol Med. 2005 May–June;109(5–6):508–515. Only a single imaging test of interest, and N <5015973224
Lavonius MI, Laine S, Salo S, . Role of laparoscopy and laparoscopic ultrasound in staging of pancreatic tumours. Ann Chir Gynaecol. 2001;90(4):252–5. No data specific to an imaging test of interest11820412
LeBlanc JK, Ciaccia D, Al-Assi MT, . Optimal number of EUS-guided fine needle passes needed to obtain a correct diagnosis. Gastrointest Endosc. 2004 Apr;59(4):475–81. Only a single imaging test of interest, and N <5015044881
LeBlanc JK, Emerson RE, Dewitt J, . A prospective study comparing rapid assessment of smears and ThinPrep for endoscopic ultrasound-guided fine-needle aspirates. Endoscopy. 2010 May;42(5):389–94. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20101566
Lee JK, Choi ER, Jang TH, . A prospective comparison of liquid-based cytology and traditional smear cytology in pancreatic endoscopic ultrasound-guided fine needle aspiration. Acta Cytol. 2011;55(5):401–7. Duplicate21986165
Lee JK, Choi JH, Lee KH, . A prospective, comparative trial to optimize sampling techniques in EUS-guided FNA of solid pancreatic masses. Gastrointest Endosc. 2013 Feb 21. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Levy MJ, Gleeson FC, Campion MB, . Prospective cytological assessment of gastrointestinal luminal fluid acquired during EUS: a potential source of false-positive FNA and needle tract seeding. Am J Gastroenterol. 2010 Jun;105(6):1311–8. Only a single imaging test of interest, and N <5020197762
Levy MJ, Norton ID, Wiersema MJ, . Prospective risk assessment of bacteremia and other infectious complications in patients undergoing EUS-guided FNA. Gastrointest Endosc. 2003 May;57(6):672–678. Not pancreatic adenocarcinoma12709695
Levy MJ, Oberg TN, Campion MB, . Comparison of methods to detect neoplasia in patients undergoing endoscopic ultrasound-guided fine-needle aspiration. Gastroenterology. 2012;142(5):1112–1121.e2. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22326996
Levy MJ, Wiersema MJ. EUS-guided Trucut biopsy. Gastrointest Endosc. 2005 Sep;62(3):417–26. No data specific to an imaging test of interest16111962
Li H, Zeng MS, Zhou KR, . Pancreatic adenocarcinoma: Signs of vascular invasion determined by multi-detector row CT. Br J Radiol. 2006 Nov;79(947):880–887. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16822803
Li H, Zeng MS, Zhou KR, . Pancreatic adenocarcinoma: The different CT criteria for peripancreatic major arterial and venous invasion. J Comput Assist Tomogr. 2005 Mar–Apr;29(2):170–175. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15772532
Li S, Huang P, Xu H, . Comparison of double contrast-enhanced ultrasound and MDCT for assessing vascular involvement of pancreatic adenocarcinoma: preliminary results correlated with surgical findings. Ultraschall Med. 2012 Dec;33(7):E299–305. Non-English22549812
Li S, Peck-Radosavljevic M, Kienast O, . Imaging gastrointestinal tumours using vascular endothelial growth factor-165 (VEGF165) receptor scintigraphy. Ann Oncol. 2003 Aug;14(8):1274–7. No data specific to an imaging test of interest12881392
Li X, Wang C, Liu P. MR imaging of the pancreas. J Xian Med Univ. 2000;12(1):40–45. Non-English
Liang W, Xu S. It is diamond cut diamond when CT meets MR imaging in the evaluation of pancreatic cancer. Radiology. 2011 Nov;261(2):660–661. News/opinion/editorial22012910
Lim W-C, LeBlanc JK. Retroperitoneal bleeding after EUS-guided FNA of a pancreatic mass. Gastrointest Endosc. 2006 Mar;63(3):499–500. Just a meeting abstract16500406
Lin F, Staerkel G. Cytologic criteria for well differentiated adenocarcinoma of the pancreas in fine-needle aspiration biopsy specimens. Cancer. 2003 Feb 25;99(1):44–50. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12589645
Lin JL, Barthel JS, Keshishian J, . Negative predictive value of positron emission tomography/computed tomography in patients with a clinical suspicion of pancreatic cancer. Pancreas. 2011 Jul;40(5):653–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21602734
Liu Y, Xu XQ, Lin XZ, . Prospective study comparing two iodine concentrations for multidetector computed tomography of the pancreas. Radiol Med. 2010 Sep;115(6):898–905. Non-English20221707
Lopez Hanninen E, Amthauer H, Hosten N, . Prospective evaluation of pancreatic tumors: accuracy of MR imaging with MR cholangiopancreatography and MR angiography. Radiology. 2002 Jul;224(1):34–41. Duplicate12091659
Lopez Hanninen E, Amthauer H, Hosten N, . Prospective evaluation of pancreatic tumors: accuracy of MR imaging with MR cholangiopancreatography and MR angiography. Radiology. 2002 Jul;224(1):34–41. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12091659
Lu N, Feng XY, Hao SJ, . 64-slice CT perfusion imaging of pancreatic adenocarcinoma and mass-forming chronic pancreatitis. Acad Radiol. 2011 Jan;18(1):81–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20951612
Lu Q, Wang P-J, Shao Z-H, Ni J, Wang G-L. CT enhancement scanning and diffusion-weighted magnetic resonance imaging for differential diagnosis between chronic mass-forming pancreatitis and pancreatic carcinoma. Acad J Second Mil Med Univ. 2013;34(9):974–979. Not English
Ludwig E, Olson SH, Bayuga S, . Feasibility and yield of screening in relatives from familial pancreatic cancer families. Am J Gastroenterol. 2011 May;106(5):946–54. Only a single imaging test of interest, and N <5021468009
Lv P, Mahyoub R, Lin X, . Differentiating pancreatic ductal adenocarcinoma from pancreatic serous cystadenoma, mucinous cystadenoma, and a pseudocyst with detailed analysis of cystic features on CT scans: a preliminary study. Korean J Radiol. 2011 Mar–Apr;12(2):187–95. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21430935
Lytras D, Connor S, Bosonnet L, . Positron emission tomography does not add to computed tomography for the diagnosis and staging of pancreatic cancer. Dig Surg. 2005;22(1–2):55–61. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15838173
Ma X, Zhao X, Ouyang H, Sun F, Zhang H, Zhou C. Quantified ADC histogram analysis: a new method for differentiating mass-forming focal pancreatitis from pancreatic cancer. Acta Radiol. 2013 Oct 28. Single test of interest and no harms/screening/patient preference data
Maguchi H. The roles of endoscopic ultrasonography in the diagnosis of pancreatic tumors. J Hepatobiliary Pancreat Surg. 2004;11(1):1–3. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15747027
Maire F, Sauvanet A, Trivin F, . Staging of pancreatic head adenocarcinoma with spiral CT and endoscopic ultrasonography: an indirect evaluation of the usefulness of laparoscopy. Pancreatology. 2004;4(5):436–40. No data specific to an imaging test of interest15249711
Malfertheiner P, Rickes S. Is endoscopic ultrasonography superior to multidetector CT for assessing pancreatic cancer? Nat Clin Pract Gastroenterol Hepatol. 2005 Apr;2(4):176–7. Duplicate16265180
Malfertheiner P, Rickes S. Is endoscopic ultrasonography superior to multidetector CT for assessing pancreatic cancer? Nat Clin Pract Gastroenterol Hepatol. 2005 Apr;2(4):176–7. Just a meeting abstract16265180
Mallery JS, Centeno BA, Hahn PF, . Pancreatic tissue sampling guided by EUS, CT/US, and surgery: a comparison of sensitivity and specificity. Gastrointest Endosc. 2002 Aug;56(2):218–24. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12145600
Maluf-Filho F, Kumar A, Gerhardt R, . Kras mutation analysis of fine needle aspirate under EUS guidance facilitates risk stratification of patients with pancreatic mass. J Clin Gastroenterol. 2007 Nov–Dec;41(10):906–10. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18090159
Maluf-Filho F, Sakai P, Cunha JEM, . Radial endoscopic ultrasound and spiral computed tomography in the diagnosis and staging of periampullary tumors. Pancreatology. 2004;4(2):122–128. No data specific to an imaging test of interest15114028
Mamoon N, Mushtaq S, Rathore MU. Endoscopic ultrasound guided aspiration cytology - A useful diagnostic tool. J Pak Med Assoc. 2011 Apr;61(4):367–371. Only a single imaging test of interest, and N <5021465975
Manohar K, Bhattacharya A, Mittal BR. Low positive yield from routine inclusion of the brain in whole-body 18F-FDG PET/CT imaging for noncerebral malignancies: Results from a large population study. Nucl Med Commun. June 2013;34(6):540–543. Single test of interest and no harms/screening/patient preference data23503001
Mansfield SD, Scott J, Oppong K, . Comparison of multislice computed tomography and endoscopic ultrasonography with operative and histological findings in suspected pancreatic and periampullary malignancy. Br J Surg. 2008 Dec;95(12):1512–20. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18942059
Manzia TM, Toti L, Lenci I, . Benign disease and unexpected histological findings after pancreaticoduodenectomy: the role of endoscopic ultrasound fine needle aspiration. Ann R Coll Surg Engl. 2010 May;92(4):295–301. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20385044
Mao JT, Fishbein MC. Metastatic pancreatic cancer masquerading as pulmonary sarcoidosis [1]. Am J Med. 2000;109(7):598–599. Just a meeting abstract11185477
Matsubara H, Itoh A, Kawashima H, . Dynamic quantitative evaluation of contrast-enhanced endoscopic ultrasonography in the diagnosis of pancreatic diseases. Pancreas. 2011 Oct;40(7):1073–9. No data specific to an imaging test of interest21633317
Matsubara S, Tada M, Akahane M, . Incidental pancreatic cysts found by magnetic resonance imaging and their relationship with pancreatic cancer. Pancreas. 2012 Nov;41(8):1241–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22699201
Matsumoto I, Shinzeki M, Toyama H, . The clinical role of positron emission tomography with F-18-fluorodeoxyglucose (FDG-PET) in diagnosis and staging in patients with pancreatic ductal adenocaricinoma. HPB. 2012 Jul;14:653–54. Just a meeting abstract
Matsumoto I, Shirakawa S, Shinzeki M, Asari S, Goto T, Ajiki T, Fukumoto T, Kitajima K, Ku Y. 18-fluorodeoxyglucose positron emission tomography does not aid in diagnosis of pancreatic ductal adenocarcinoma. Clin Gastroenterol Hepatol. June 2013;11(6):712–718. Did not report both sensitivity and specificity23353642
Matsumoto I, Shirakawa S, Shinzeki M, . 18 Fluorodeoxyglucose positron emission tomography does not aide in diagnosis of pancreatic ductal adenocarcinoma. Clin Gastroenterol Hepatol. 2013 Jan 22. No comparative specificity data
Matsumoto S, Mori H, Kiyonaga M, . “Peripancreatic strands appearance” in pancreatic body and tail carcinoma: evaluation by multi-detector CT with pathological correlation. Abdom Imaging. 2012 Aug;37(4):602–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21912989
Max JB, Raymond VM, Kwon RS, Stoffel EM. Pancreatic cancer screening in a cohort of high risk individuals presenting for genetic evaluation. Gastroenterology. 2013 May;144(5 Suppl 1):S605. Just a meeting abstract
Mayerle J, Simon P, Dickson EJ, . Prospective cohort study comparing transient EUS guided elastography to EUSFNA for the diagnosis of solid pancreatic mass lesions. Pancreatology. 2010. Just a meeting abstract
Mayo SC, Austin DF, Sheppard BC, . Evolving preoperative evaluation of patients with pancreatic cancer: does laparoscopy have a role in the current era? J Am Coll Surg. 2009 Jan;208(1):87–95. No comparative specificity data19228509
Mazzeo S, Cappelli C, Battaglia V, . Multidetector CT in the evaluation of retroperitoneal fat tissue infiltration in ductal adenocarcinoma of the pancreatic head: Correlation with histopathological findings. Abdom Imaging. 2010 Aug;35(4):465–470. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19618239
Mazzeo S, Cappelli C, Caramella D, . Evaluation of vascular infiltration in resected patients for pancreatic cancer: comparison among multidetector CT, intraoperative findings and histopathology. Abdom Imaging. 2007 Nov;32(6):737–42. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17387543
McBride G. Screening methods may offer early diagnosis of pancreatic cancer. J Natl Cancer Inst. 2004 Nov 3;96(21):1571. News/opinion/editorial15523083
Meijer OL, Weersma RK, van der Jagt EJ, . Endoscopic ultrasonography in suspected pancreatic malignancy and indecisive CT. Neth J Med. 2010 Sep;68(9):360–4. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20876916
Melville A, Morris E, Forman D, . Management of upper gastrointestinal cancers. Qual Health Care. 2001;10(1):57–64. Narrative review11239144
Merdrignac A, Sulpice L, Rayar M, . Pancreatobiliary carcinoma complicating chronic pancreatitis: Are indications of pancreatoduodenectomy correctly assessed? HPB. 2012 Jul;14:664. Just a meeting abstract
Mertz H, Gautam S. The learning curve for EUS-guided FNA of pancreatic cancer. Gastrointest Endosc. 2004 Jan;59(1):33–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14722544
Mertz HR, Sechopoulos P, Delbeke D, . Gastrointest Endosc. 2000 Sep;52(3):367–71. No data specific to an imaging test of interest10968852
Mileto A, Mazziotti S, Gaeta M, Bottari A, . Pancreatic dual-source dual-energy CT: is it time to discard unenhanced imaging? Clin Radiol. 2012 Apr;67(4):334–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22094183
Minamimoto R, Senda M, Terauchi T, . Analysis of various malignant neoplasms detected by FDG-PET cancer screening program: Based on a Japanese Nationwide Survey. Ann Nucl Med. 2011 Jan;25(1):45–54. Screening healthy people20953985
Minamimoto R, Senda M, Uno K, . Performance profile of FDG-PET and PET/CT for cancer screening on the basis of a Japanese Nationwide Survey. Ann Nucl Med. 2007 Nov;21(9):481–98. Screening healthy people18030580
Minniti S, Bruno C, Biasiutti C, . Sonography versus helical CT in identification and staging of pancreatic ductal adenocarcinoma. J Clin Ultrasound. 2003 May;31(4):175–82. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12692824
Mishra G, Zhao Y, Sweeney J, . Determination of qualitative telomerase activity as an adjunct to the diagnosis of pancreatic adenocarcinoma by EUS-guided fine-needle aspiration. Gastrointest Endosc. 2006 Apr;63(4):648–54. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16564867
Mitra V, Nayar M, Bonnington S, Scott J, Anderson K, Charnley R, Jaques B, Sen G, White S, Manas D, French J, Oppong K. Yield of endoscopic ultrasound (EUS)in patients with dilated common bile duct (CBD)and or pancreatic duct (PD) with normal liver function tests (LFTS)and cross-sectional imaging. Pancreatology. 2013 Jan–Feb;13(1):e11–2. Just a meeting abstract
Mitsuhashi T, Ghafari S, Chang CY, . Endoscopic ultrasound-guided fine needle aspiration of the pancreas: cytomorphological evaluation with emphasis on adequacy assessment, diagnostic criteria and contamination from the gastrointestinal tract. Cytopathology. 2006 Feb;17(1):34–41. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16417563
Mochizuki K, Gabata T, Kozaka K, . MDCT findings of extrapancreatic nerve plexus invasion by pancreas head carcinoma: correlation with en bloc pathological specimens and diagnostic accuracy. Eur Radiol. 2010 Jul;20(7):1757–67. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20146066
Moller AK, Loft A, Berthelsen AK, . 18F-FDG PET/CT as a diagnostic tool in patients with extracervical carcinoma of unknown primary site: A literature review. Oncologist. 2011;16(4):445–51. Not pancreatic adenocarcinoma21427201
Moller K, Papanikolaou IS, Toermer T, . EUS-guided FNA of solid pancreatic masses: high yield of 2 passes with combined histologic-cytologic analysis. Gastrointest Endosc. 2009 Jul;70(1):60–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19394012
Morak MJ, Hermans JJ, Smeenk HG, . Staging for locally advanced pancreatic cancer. Eur J Surg Oncol. 2009 Sep;35(9):963–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19246172
Morgan DE, Carroll LV, McNamara MM, Alexander L, Thomas JV. Detection of small pancreatic adenocarcinomas with rapid switching dual energy spectral MDCT (DECT). Abdom Imaging. 2013 Aug;38(4):624. Just a meeting abstract
Mortensen MB, Pless T, Durup J, . Clinical impact of endoscopic ultrasound-guided fine needle aspiration biopsy in patients with upper gastrointestinal tract malignancies. A prospective study. Endoscopy. 2001 Jun;33(6):478–83. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11437039
Muhi A, Ichikawa T, Motosugi U, . Mass-forming autoimmune pancreatitis and pancreatic carcinoma: differential diagnosis on the basis of computed tomography and magnetic resonance cholangiopancreatography, and diffusion-weighted imaging findings. J Magn Reson Imaging. 2012 Apr;35(4):827–36. No outcomes of interest22069025
Muscatiello N, Nacchiero M, Della Valle N, . Ultrasonographic contrast medium improves the diagnostic accuracy of ultrasound-guided fine-needle aspiration. Endoscopy. 2008 Jun;40(6):540–1. Just a meeting abstract18543143
Na S, Park DH, Lee J, Park Y, Hong S-M, Lee BUK, Jeoung SUK, Lee SS, Seo DW, Lee SK, Kim M-H. Suction vs. nonsuction method with optimal number of to-and-fro motion in EUS-guided FNA for pancreatic or peripancreatic masses: A prospective, single blind, randomized, controlled trial. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB404. Just a meeting abstract
Nagamachi S, Nishii R, Wakamatsu H, Mizutani Y, Kiyohara S, Fujita S, Futami S, Sakae T, Furukoji E, Tamura S, Arita H, Chijiiwa K, Kawai K. The usefulness of 18F-FDG PET/MRI fusion image in diagnosing pancreatic tumor: Comparison with 18F-FDG PET/CT. Ann Nucl Med. July 2013;27(6):554–563. Single test of interest and no harms/screening/patient preference data23580090
Nagamachi S, Nishii R, Wakamatsu H, Mizutani Y, Kiyohara S, Fujita S, Futami S, Sakae T, Furukoji E, Tamura S, Arita H, Chijiiwa K, Kawai K. The usefulness of (18)F-FDG PET/MRI fusion image in diagnosing pancreatic tumor: comparison with (18)F-FDG PET/CT. Ann Nucl Med. 2013 Jul;27(6):554–63. Single test of interest and no harms/screening/patient preference data23580090
Nagtegaal T, Harinck F, Kluijt I, . The psychological impact of participating in a pancreatic cancer surveillance program. Fam Cancer. 2011 Apr;10:S86. Just a meeting abstract
Nagula S, Pourmand K, Aslanian HR, Bucobo JC, Dimaio CJ, Gonda TA, Gonzalez S, Goodman AJ, Gross SA, Ho S, Kim MK, Liverant ML, Pais SA, Poneros JM, Robbins DH, Schnoll-Sussman F, Sethi A, Buscaglia J. EUS-fine needle aspiration (FNA) vs. EUS-fine needle biopsy (FNB) for solid mass lesions: Interim analysis of a large multicenter, randomized clinical trial. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB357–8. Just a meeting abstract
Naitoh I, Nakazawa T, Hayashi K, . Clinical differences between mass-forming autoimmune pancreatitis and pancreatic cancer. Scand J Gastroenterol. 2012 May;47(5):607–13. No outcomes of interest22416894
Nakai Y, Isayama H, Yamamoto N, Kawahata S, Saito T, Watanabe T, Hamada T, Uchino R, Mizuno S, Miyabayashi K, Yamamoto K, Kogure H, Sasaki T, Hirano K, Tada M, Koike K. A comparative study of suction technique vs. slow pull technique in EUS-FNA for pancreatic malignant lesions. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB404. Just a meeting abstract
Nakamoto Y, Higashi T, Sakahara H, . Delayed (18)F-fluoro-2-deoxy-D-glucose positron emission tomography scan for differentiation between malignant and benign lesions in the pancreas. Cancer. 2000 Dec 15;89(12):2547–54. No data specific to an imaging test of interest11135214
Nanashima A, Sakamoto I, Hayashi T, . Preoperative diagnosis of lymph node metastasis in biliary and pancreatic carcinomas: evaluation of the combination of multi-detector CT and serum CA19-9 level. Dig Dis Sci. 2010 Dec;55(12):3617–26. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20238244
Nart D, Argon A, Uyarotlu MA, . Endoscopic ultrasound guided fine needle aspiration cytology for diagnosis of pancreatic masses. Cytopathology. 2011 Oct;22:179. Just a meeting abstract20636404
Nawaz H, Chen YF, Khalid A, . Comparison of endoscopic ultrasound (EUS) and computed tomography (CT) in assessing loco-regional lymph node involvement, vascular invasion, and resectability of pancreatic cancer: a meta-analysis. Am J Gastroenterol. 2010 Oct;105:S59. Just a meeting abstract
Nawaz H, Fan CY, Kloke J, Khalid A, McGrath K, Landsittel D, Papachristou GI. Performance characteristics of endoscopic ultrasound in the staging of pancreatic cancer: a meta-analysis. JOP. 2013 Sep;14(5):484–97. Not one of the 4 imaging tests of interest (CT, EUS-FNA, MRI, or PET-CT)24018593
Nawaz H, Yi-Fan C, Kloke J, Khalid A, McGrath K, Landsittel D, Papachristou GI. Performance characteristics of endoscopic ultrasound in the staging of pancreatic cancer: A meta-analysis. JOP. September 2013;14(5):484–497. Not one of the 4 imaging tests of interest (CT, EUS-FNA, MRI, or PET-CT)24018593
Nayar M, Joy D, Wadehra V, . Effect of dedicated and supervised training on achieving competence in EUS-FNA of solid pancreatic lesions. Scand J Gastroenterol. 2011 Jul;46(7–8):997–1003. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21623675
Nayar MK, Chatterjee S, Wadehra V, Cunningham J, Leeds J, Oppong K. Does on-site adequacy assessment by cytotechnologists improve results of EUS guided FNA of solid pancreaticobiliary lesions? JOP. 2013 Jan;14(1):44–9. Single test of interest and no harms/screening/patient preference data23306334
Neoptolemos JP. Is endoscopic ultrasonography superior to multidetector CT for assessing pancreatic cancer? Nat Clin Pract Oncol. 2005 Feb;2(2):78–9. News/opinion/editorial16264878
Ngamruengphong S, Xu C, Woodward TA, Raimondo M, Stauffer J, Asbun HJ, Wallace MB. Risk of gastric/peritoneal recurrence and long term outcomes after EUS-guided FNA in patient with resected pancreatic cancer. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB414. Just a meeting abstract
Nguyen NQ, Bartholomeusz DF. 18F-FDG-PET/CT in the assessment of pancreatic cancer: is the contrast or a better-designed trial needed? J Gastroenterol Hepatol. 2011 Apr;26(4):613–5. News/opinion/editorial21418296
Nilsson O, Van Cutsem E, Yao JC, . Poorly differentiated carcinomas of the foregut (gastric, duodenal and pancreatic). Neuroendocrinology. 2007 Feb;84(3):212–215. Narrative review
Nordback I, Saaristo R, Piironen A, . Chest computed tomography in the staging of pancreatic and periampullary carcinoma. Scand J Gastroenterol. 2004 Jan;39(1):81–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14992566
Novel screening method for pancreatic cancer shows hope for earlier detection. Imaging Med. 2011 Oct;3(5):495. News/opinion/editorial
O’Connell AM, Keeling F, Given M, . Fine-needle trucut biopsy versus fine-needle aspiration cytology with ultrasound guidance in the abdomen. J Med Imaging Radiat Oncol. 2008 Jun;52(3):231–6. Not pancreatic adenocarcinoma18477117
Ogawa Y, Tanaka M, Inoue K, . A prospective pancreatographic study of the prevalence of pancreatic carcinoma in patients with diabetes mellitus. Cancer. 2002 May 1;94(9):2344–9. No data specific to an imaging test of interest12015758
Oguz D, Oztas E, Kalkan IH, . Accuracy of endoscopic ultrasound-guided fine needle aspiration cytology on the differentiation of malignant and benign pancreatic cystic lesions: A single-center experience. J Dig Dis. 2013 Mar;14(3):132–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23167591
Okano K, Kakinoki K, Akamoto S, . 18F-fluorodeoxyglucose positron emission tomography in the diagnosis of small pancreatic cancer. World J Gastroenterol. 2011 Jan 14;17(2):231–5. No comparative specificity data21245997
Okano K, Kakinoki K, Akamoto S, . 18F-fuorodeoxyglucose positron emission tomography in the diagnosis of small pancreatic cancer. World J Gastroenterol. 2011 Jan 14;17(2):231–235. No comparative specificity data21245997
Oliva MR, Mortele KJ, Erturk SM, . Magnetic resonance imaging of the pancreas. Appl Radiol. 2006 Feb;35(2):7–24. Narrative review
Olivie D, Lepanto L, Billiard JS, . Predicting resectability of pancreatic head cancer with multi-detector CT. Surgical and pathologic correlation. JOP. 2007;8(6):753–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17993727
Olson MT, Ali SZ. Cytotechnologist on-site evaluation of pancreas fine needle aspiration adequacy: comparison with cytopathologists and correlation with the final interpretation. Acta Cytol. 2012;56(4):340–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22846449
Orlando LA, Kulasingam SL, Matchar DB. Meta-analysis: The detection of pancreatic malignancy with positron emission tomography. Aliment Pharmacol Ther. 2004 Nov 15;20(10):1063–1070. No, PET that was not always combined PET/CT; The CT data are not representative since the studies were required to also have done PET15569108
Orsini F, Volterrani D, Giorgetti A, . Role of [18F]FDG PET/CT for distinguishing benign and malignant lesions of the pancreas. Eur J Nucl Med Mol Imaging. 2012 Oct;39:S468–9. Just a meeting abstract
Ortiz AM, Elhanafi S, Mccallum R, . The diagnostic accuracy of endoscopic ultrasound (EUS) elastography in differentiating benign from malignant pancreatic lesions, a meta-analysis. Gastrointest Endosc. 2012 Apr;75(4 Suppl 1):AB181–2. No data specific to an imaging test of interest
O’Sullivan M, O’Morain C. Role of endoscopic ultrasound and magnetic resonance imaging in the preoperative staging of pancreatic adenocarcinoma. Am J Gastroenterol. 2000;95(8):1926–1931. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives10950037
Owens MM. Walk closer or carry big glass? Comparing EUS and multidetector CT. Gastrointest Endosc. 2011 Apr;73(4):697–699. News/opinion/editorial21457814
Paik WH, Park Y, Hong S-M, Lee BU, Choi J-H, Lee SS, Seo D-W, Lee SK, Kim M-H, Park DH. Prospective validation of novel 22-gauge EUS histology needle using capillary sampling with slow-pull technique for intra-abdominal solid mass. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S48. Just a meeting abstract
Palacios-Gerona H, Sanchez-Sanchez R, Navarro-Pelayo Lainez M, . Usefulness of 18F-FDG PET/CT in the evaluation of malignant suspected pancreatic lesions: Diagnostic accuracy and clinical impact. Eur J Nucl Med Mol Imaging. 2012 Oct;39:S583. Just a meeting abstract
Pang JC, Minter RM, Kwon RS, . The role of cytology in the preoperative assessment and management of patients with pancreaticobiliary tract neoplasms. J Gastrointest Surg. 2013 Mar;17(3):501–10. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23297029
Papanikolaou IS, Fockens P, Hawes R, . Update on endoscopic ultrasound: How much for imaging, needling, or therapy? Scand J Gastroenterol. 2008;43(12):1416–1424. Narrative review18821273
Pappas SG, Christians KK, Tolat PP, . Staging chest computed tomography and positron emission tomography in patients with pancreatic adenocarcinoma: utility or futility. HPB. 2013 Mar 15. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Park HS, Lee JM, Choi HK, . Preoperative evaluation of pancreatic cancer: comparison of gadolinium-enhanced dynamic MRI with MR cholangiopancreatography versus MDCT. J Magn Reson Imaging. 2009 Sep;30(3):586–95. No data specific to an imaging test of interest19711405
Park JK, Song BJ, Paik WH, Kim MA, Park JM, Kim Y-T, Ryu JK. Analysis of endoscopic ultrasound (EUS)-guided fine needle aspiration (FNA) samples from patients with suspected pancreatic ductal adenocarcinomas (PDACs) using plectin-1 (Plec1) and kras oncogene mutation analysis. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S52. Just a meeting abstract
Patel BN, Thomas JV, Lockhart ME, . Single-source dual-energy spectral multidetector CT of pancreatic adenocarcinoma: optimization of energy level viewing significantly increases lesion contrast. Clin Radiol. 2013 Feb;68(2):148–54. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22889459
Patoureaux S, Saint-Paul M-C, Vanbiervliet G, Barthet M, Fabre M. Randomised prospective comparison of endoscopic ultrasound (EUS)-guided fine needle aspiration (FNA) and core biopsy of solid pancreatic tumours using ProCore and EchoTip 22G needles: The ‘Picore’ study. Acta Cytol. 2013 May;57:27–8. Just a meeting abstract
Paul N, Abboud G, Jamil LH, Lo SK, Gupta K. EUS guided fine needle aspiration (EUS-FNA) versus fine needle biopsy (EUS FNB): A comparison of technical success, efficacy and cost analysis for pancreas masses. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB401. Just a meeting abstract
Pellise M, Castells A, Gines A, . Clinical usefulness of KRAS mutational analysis in the diagnosis of pancreatic adenocarcinoma by means of endosonography-guided fine-needle aspiration biopsy. Aliment Pharmacol Ther. 2003 May 15;17(10):1299–307. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12755843
Pelosi E, Pennone M, Deandreis D, . Role of whole body positron emission tomography/computed tomography scan with 18F-fluorodeoxyglucose in patients with biopsy proven tumor metastases from unknown primary site. Q J Nucl Med Mol Imaging. 2006 Mar;50(1):15–22. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16557200
Peng HQ, Greenwald BD, Tavora FR, . Evaluation of performance of EUS-FNA in preoperative lymph node staging of cancers of esophagus, lung, and pancreas. Diagn Cytopathol. 2008 May;36(5):290–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18418852
Penman ID. Endoscopic ultrasound. Endoscopy. 2001;33(11):940–948. Narrative review11668402
Perez-Miranda M, Vila JJ, De La Serna-Higuera C. Endoscopic ultrasound. Endoscopy. 2013;45(4):300–304. Narrative review23440587
Petrone MC, Arcidiacono PG, Carrara S, . Does cytotechnician training influence the accuracy of EUS-guided fine-needle aspiration of pancreatic masses? Dig Liver Dis. 2012 Apr;44(4):311–4. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22226546
Phillips-Hughes J. Invasive and interventional uses of endoscopic ultrasound. Br J Radiol. January 2007;80(949):1–2. Narrative review17267471
Phoa SS, Reeders JW, Stoker J, . CT criteria for venous invasion in patients with pancreatic head carcinoma. Br J Radiol. 2000 Nov;73(875):1159–64. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11144792
Phoa SS, Tilleman EH, van Delden OM, . Value of CT criteria in predicting survival in patients with potentially resectable pancreatic head carcinoma. J Surg Oncol. 2005 Jul 1;91(1):33–40. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15999356
Pitts A, Nissen NN, Waxman A, Yu R. Unsuspected fluorodeoxyglucose positron emission tomography (FDG-PET)-positive pancreatic lesions: prevalence and significance. Pancreas. 2013 Oct;42(7):1191–3. Just a meeting abstract24048460
Polkowski M. Endoscopic ultrasonography. Endoscopy. 2006 Jan;38(1):16–21. Narrative review16429349
Pollack BJ, Gress FG. Comparing biopsy methods for patients with pancreatic mass. J Crit Illn. 2003 Feb 1;18(2):53. Narrative review
Porembka MR, Hawkins WG, Linehan DC, . Radiologic and intraoperative detection of need for mesenteric vein resection in patients with adenocarcinoma of the head of the pancreas. HPB. 2011 Sep;13(9):633–42. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21843264
Prachayakul V, Sriprayoon T, Asawakul P, . Repeated endoscopic ultrasound guided fine needle aspiration (EUS-FNA) improved diagnostic yield of inconclusive initial cytology for suspected pancreatic cancer and unknown intra-abdominal lymphadenopathy. J Med Assoc Thai. 2012 Feb;95: Suppl 2:S68–74. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22574532
Prassopoulos P, Tritou I, Papanikolaou N, . Deformity of the superior mesenteric vein: MR sign of pancreatic cancer unresectability. AJR Am J Roentgenol. 2001 Jun;176(6):1600–1. Just a meeting abstract
Procacci C, Biasiutti C, Carbognin G, . Spiral computed tomography assessment of resectability of pancreatic ductal adenocarcinoma: Analysis of results. Dig Liver Dis. 2002 Oct 1;34(1):739–747. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12469802
Prokesch RW, Chow LC, Beaulieu CF, . Isoattenuating pancreatic adenocarcinoma at multi-detector row CT: Secondary signs. Radiology. 2002 Sep;224(3):764–768. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12202711
Pulay I, Tihanyi TF, Flautner L. Pancreatic head mass: What can be done? Classification: The clinical point of view. JOP. 2000 Sep;1(3):85–90. Narrative review11854562
Puli SR, Bechtold ML, Reddy JB, . Accuracy of endoscopic ultrasound to localize gastrinomas in the pancreas: A meta-analysis and systematic review. Gastroenterology. 2009 May;136(5 Suppl 1):A760. Just a meeting abstract
Puli SR, Bechtold ML, Reddy JB, . Diagnostic accuracy of EUS in detecting pancreatic neuroendocrine tumors: a meta-analysis and systematic review. Gastroenterology. 2009 May;136(5 Suppl 1):A932. Primary focus on endocrine pancreatic cancer
Puli SR, Singh S, Hagedorn CH, . Diagnostic accuracy of EUS for vascular invasion in pancreatic and periampullary cancers: a meta-analysis and systematic review. Gastrointest Endosc. 2007 May;65(6):788–97. No data specific to an imaging test of interest17350008
Puri R, Vilmann P, Saftoiu A, . Randomized controlled trial of endoscopic ultrasound-guided fine-needle sampling with or without suction for better cytological diagnosis. Scand J Gastroenterol. 2009 Apr;44(4):499–504. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19117242
Qian X, Hecht JL. Pancreatic fine needle aspiration. A comparison of computed tomographic and endoscopic ultrasonographic guidance. Acta Cytol. 2003 Sep–Oct;47(5):723–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14526668
Qiu H, Wild AT, Wang H, . Comparison of conventional and 3-dimensional computed tomography against histopathologic examination in determining pancreatic adenocarcinoma tumor size: implications for radiation therapy planning. Radiother Oncol. 2012 Aug;104(2):167–72. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22883106
Queneau PE, Sauve G, Koch S, . The impact on clinical practice of endoscopic ultrasonography used for the diagnosis and staging of pancreatic adenocarcinoma. JOP. 2001 May;2(3):98–104. Duplicate11870331
Queneau PE, Sauve G, Koch S, . The impact on clinical practice of endoscopic ultrasonography used for the diagnosis and staging of pancreatic adenocarcinoma. JOP. 2001 May;2(3):98–104. No data specific to an imaging test of interest11870331
Radiotherapy: MRI underestimates the size of pancreatic adenocarcinoma. Nat Rev Clin Oncol. 2013 Jan 22;10(3):122. Just a meeting abstract23381002
Ragozzino A, Scaglione M. Pancreatic head mass: What can be done? Diagnosis: Magnetic resonanace imaging. JOP. 2000 Sep;1(3):100–107. Narrative review11854565
Ramesh J, Bang JY, HeBert-Magee S, Trevino J, Hasan M, Logue AL, Hawes R, Varadarajulu S. Multi-center randomized trial comparing the 19g and 25g needles for EUS-guided FNA of solid pancreatic mass lesions. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB179–80. Just a meeting abstract
Ramesh J, HeBert-Magee S, Varadarajulu S. A meta-analysis critically evaluating the performance of EUSFNA for diagnosis of pancreatic adenocarcinoma. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB243. Just a meeting abstract
Ramsay D, Marshall M, Song S, . Identification and staging of pancreatic tumours using computed tomography, endoscopic ultrasound and mangafodipir trisodium-enhanced magnetic resonance imaging. Australas Radiol. 2004 Jun;48(2):154–61. No data specific to an imaging test of interest15230749
Rao SX, Zeng MS, Cheng WZ, . Small solid tumors (< or = 2 cm) of the pancreas: relative accuracy and differentiation of CT and MR imaging. Hepatogastroenterology. 2011 May–Jun;58(107–108):996–1001. Duplicate21830431
Reicher S, Boyar FZ, Albitar M, . Fluorescence in situ hybridization and K-ras analyses improve diagnostic yield of endoscopic ultrasound-guided fine-needle aspiration of solid pancreatic masses. Pancreas. 2011 Oct;40(7):1057–62. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21705950
Reiner CS, Fischer MA, Hany T, . Molecular Imaging of Malignant Tumor Metabolism. Whole-Body Image Fusion of DWI/CT vs. PET/CT. Acad Radiol. 2011 Aug;18(8):940–946. Not pancreatic adenocarcinoma21718953
Rickes S, Unkrodt K, Ocran K, . Differentiation of neuroendocrine tumors from other pancreatic lesions by echo-enhanced power Doppler sonography and somatostatin receptor scintigraphy. Pancreas. 2003 Jan;26(1):76–81. No data specific to an imaging test of interest12499921
Riemann B, Menzel J, Schiemann U, . Ultrasound-guided biopsies of abdominal organs with an automatic biopsy system: A retrospective analysis of the quality of biopsies and of hemorrhagic complications. Scand J Gastroenterol. 2000;35(1):102–107. Nonstandard method of biopsy collection via EUS (not FNA)10672843
Robbins DH, Hoffman B. Hindsight is not 20/20: a cautionary tale in pancreatic cancer. Endoscopy. 2004 May;36(5):453–4. News/opinion/editorial15100958
Roche CJ, Hughes ML, Garvey CJ, . CT and pathologic assessment of prospective nodal staging in patients with ductal adenocarcinoma of the head of the pancreas. AJR Am J Roentgenol. 2003 Feb;180(2):475–80. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12540455
Rodriguez S, Faigel D. Absence of a dilated duct predicts benign disease in suspected pancreas cancer: a simple clinical rule. Dig Dis Sci. 2010 Apr;55(4):1161–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19590960
Romijn MG, Stoker J, van Eijck CH, . MRI with mangafodipir trisodium in the detection and staging of pancreatic cancer. J Magn Reson Imaging. 2000 Aug;12(2):261–8. N <5010931589
Rosch T, Hofrichter K, Frimberger E, . ERCP or EUS for tissue diagnosis of biliary strictures? A prospective comparative study. Gastrointest Endosc. 2004 Sep;60(3):390–6. Only a single imaging test of interest, and N <5015332029
Rosch T, Schusdziarra V, Born P, . Modern imaging methods versus clinical assessment in the evaluation of hospital in-patients with suspected pancreatic disease. Am J Gastroenterol. 2000 Sep;95(9):2261–70. No data specific to an imaging test of interest11007227
Ross C, Galandauer I, Mund R, . The role of clinical and endosonographic features in predicting the accuracy of endoscopic ultrasound guided fine needle aspiration. Am J Gastroenterol. 2010 Oct;105:S61–S62. Just a meeting abstract
Ross WA, Wasan SM, Evans DB, . Combined EUS with FNA and ERCP for the evaluation of patients with obstructive jaundice from presumed pancreatic malignancy. Gastrointest Endosc. 2008 Sep;68(3):461–6. No data specific to an imaging test of interest18384788
Rout N, Samantaray S, Singh SP, . Rapid Ultrasound Guided Fine Needle Aspiration Cytology [USG FNAC] of pancreatic mass lesions. Pancreatology. 2011. Just a meeting abstract
Rubenstein JH, Scheiman JM, Anderson MA. A clinical and economic evaluation of endoscopic ultrasound for patients at risk for familial pancreatic adenocarcinoma. Pancreatology. 2007;7(5–6):514–25. No outcomes of interest17912015
Rulyak SJ, Brentnall TA. Inherited pancreatic cancer: surveillance and treatment strategies for affected families. Pancreatology. 2001;1(5):477–85. Narrative review12120228
Ruszniewski P, Malka D, Hammel P, . The diagnostic dilemmas in discrimination between pancreatic carcinoma and chronic pancreatitis [3]. Gut. 2004 May;53(5):771. News/opinion/editorial
Saftoiu A, Ciurea T, Branda H. The role of imaging for the evaluation of pancreatic cancer resectability [1] (multiple letters). Rom J Gastroenterol. 2002;11(1):78–80. Just a meeting abstract12096319
Saftoiu A, Vilmann P. Role of endoscopic ultrasound in the diagnosis and staging of pancreatic cancer. J Clin Ultrasound. 2009 Jan;37(1):1–17. Narrative review18932265
Sahai AV, Paquin SC, Gariepy G. A prospective comparison of endoscopic ultrasound-guided fine needle aspiration results obtained in the same lesion, with and without the needle stylet.[Erratum appears in Endoscopy. 2011 Feb;43(2):168. Endoscopy. 2010 Nov;42(11):900–3. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20725886
Sahani DV, Kalva SP, Fischman AJ, . Detection of liver metastases from adenocarcinoma of the colon and pancreas: comparison of mangafodipir trisodium-enhanced liver MRI and whole-body FDG PET. AJR Am J Roentgenol. 2005 Jul;185(1):239–46. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15972430
Sai M, Mori H, Kiyonaga M, . Peripancreatic lymphatic invasion by pancreatic carcinoma: Evaluation with multi-detector row CT. Abdom Imaging. 2010 Apr;35(2):154–162. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18972151
Sakamoto H, Kitano M, Dote K, . In situ carcinoma of pancreas diagnosed by EUS-FNA. Endoscopy. 2008 Sep;40: Suppl 2:E15–6. Just a meeting abstract18278717
Salek C, Benesova L, Zavoral M, . Evaluation of clinical relevance of examining K-ras, p16 and p53 mutations along with allelic losses at 9p and 18q in EUS-guided fine needle aspiration samples of patients with chronic pancreatitis and pancreatic cancer. World J Gastroenterol. 2007 Jul 21;13(27):3714–20. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17659731
Sandrasegaran K, Akisik FM, Patel AA, . Diffusion-weighted imaging in characterization of cystic pancreatic lesions. Clin Radiol. 2011 Sep;66(9):808–14. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21601184
Santhosh S, Mittal BR, Bhasin D, . Role of (18)F-fluorodeoxyglucose positron emission tomography/computed tomography in the characterization of pancreatic masses: experience from tropics. J Gastroenterol Hepatol. 2013 Feb;28(2):255–61. Duplicate23278193
Santhosh S, Mittal BR, Bhasin D, . Role of (18)F-fluorodeoxyglucose positron emission tomography/computed tomography in the characterization of pancreatic masses: experience from tropics. J Gastroenterol Hepatol. 2013 Feb;28(2):255–61. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23278193
Sasson AR, Gulizia JM, Galva A, . Pancreaticoduodenectomy for suspected malignancy: have advancements in radiographic imaging improved results? Am J Surg. 2006 Dec;192(6):888–93. No comparative specificity data17161114
Satoi S, Yanagimoto H, Toyokawa H, . Pre-operative patient selection of pancreatic cancer patients by multi-detector row CT. Hepatogastroenterology. 2009 Mar–Apr;56(90):529–34. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19579636
Savides TJ, Donohue M, Hunt G, . EUS-guided FNA diagnostic yield of malignancy in solid pancreatic masses: a benchmark for quality performance measurement. Gastrointest Endosc. 2007 Aug;66(2):277–82. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17643700
Schaffner TJ, Richmond BK. Osteoclast-like giant cell tumor of the pancreas with subsequent pulmonary metastases. Am Surg. 2011 Dec;77(12):E275–7. Just a meeting abstract22273195
Schembre D, Brandabur J. Sensitivity of EUS-guided fine needle aspirate vs fine needle biopsy with a newly designed needle for pancreas cancer in a large, referral population. Am J Gastroenterol. 2012;107:S730. Just a meeting abstract
Schieren G, Tokmak F, Lefringhausen L, . C-reactive protein levels and clinical symptoms following gadolinium administration in hemodialysis patients. Am J Kidney Dis. 2008 Jun;51(6):976–86. Not specific to pancreatic cancer, data on harms but is pre-200918501785
Schima W, Fugger R, Schober E, . Diagnosis and staging of pancreatic cancer: comparison of mangafodipir trisodium-enhanced MR imaging and contrast-enhanced helical hydro-CT. AJR Am J Roentgenol. 2002 Sep;179(3):717–24. No data specific to an imaging test of interest12185052
Schmidt J, Fraunhofer S, Fleisch M, . Is peritoneal cytology a predictor of unresectability in pancreatic carcinoma? Hepatogastroenterology. 2004 Nov–Dec;51(60):1827–31. No outcomes of interest15532836
Schneider AR, Adamek HE, Layer G, . Staging of abdominal metastases in pancreatic carcinoma by diagnostic laparoscopy and magnetic resonance imaging. Z Gastroenterol. 2003 Aug;41(8):697–702. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14579851
Schwartz DA, Unni KK, Levy MJ, . The rate of false-positive results with EUS-guided fine-needle aspiration. Gastrointest Endosc. 2002 Dec;56(6):868–72. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12447300
Seo SY, Kim SH, Kim IH, Kim SW, Yu HC, Lee ST, Kim DG, Lee SO. Higher rates of core tissue acquisition of EUS-guided FNB compared with EUS-guided FNS for solid pancreatic mass lesions. Pancreatology. 2013 Jul–Aug;13(4 Suppl):S46. Just a meeting abstract
Seung SL, Jae HB, Beom JP, . Quantitative analysis of diffusion-weighted magnetic resonance imaging of the pancreas: Usefulness in characterizing solid pancreatic masses. J Magn Reson Imaging. 2008 Oct;28(4):928–936. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18821618
Shah N, Sattar A, Benanti M, . Magnetic resonance spectroscopy as an imaging tool for cancer: a review of the literature. J Am Osteopath Assoc. 2006;106(1):23–7. Narrative review16428685
Shah SU, Shields CL, Bianciotto CG, . Pancreatic cancer metastasis to choroid. Ophthalmology. 2011;118(7):1483–1483.e4. Just a meeting abstract21724049
Sheehan M, Latona C, Aranha G, . The increasing problem of unusual pancreatic tumors. Arch Surg. 2000 Jun;135(6):644–650. Not pancreatic adenocarcinoma10843359
Sheng J, Jahromi AH, Takalkar A, . The role of positron emission tomography in the diagnosis and staging of pancreatic lesions. HPB. 2012 Jul;14:70. Just a meeting abstract
Shie R-F, Pan K-T, Chu S-Y, . Immediate adverse drug reactions in computed tomography with slow injection rate: comparing Iothalamate Meglumine with Iopromide. Chin J Radiol. 2008 Dec;33(4):233–238. Not specific to pancreatic cancer, data on harms but is pre-2009
Shin HJ, Lahoti S, Sneige N. Endoscopic ultrasound-guided fine-needle aspiration in 179 cases: the M. D. Anderson Cancer Center experience. Cancer. 2002 Jun 25;96(3):174–80. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12115306
Shrikhande SV, Barreto SG, Goel M, . Multimodality imaging of pancreatic ductal adenocarcinoma: a review of the literature. HPB. 2012 Oct;14(10):658–68. No meta-analysis, and no comprehensive table of study estimates22954001
Siddique K, Ali Q, Mirza S, . Evaluation of the aetiological spectrum of obstructive jaundice. J Ayub Med Coll Abbottabad. 2008 Oct–Dec;20(4):62–6. No outcomes of interest
Siddiqui AA, Brown LJ, Hong SK, . Relationship of pancreatic mass size and diagnostic yield of endoscopic ultrasound-guided fine needle aspiration. Dig Dis Sci. 2011 Nov;56(11):3370–5. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21688127
Siddiqui AA, Kowalski TE, Shahid H, . False-positive EUS-guided FNA cytology for solid pancreatic lesions. Gastrointest Endosc. 2011 Sep;74(3):535–40. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21737075
Siddiqui AA, Lyles T, Avula H, . Endoscopic ultrasound-guided fine needle aspiration of pancreatic masses in a veteran population: comparison of results with 22- and 25-gauge needles. Pancreas. 2010 Jul;39(5):685–6. Just a meeting abstract20562582
Singh A, Kwak NH, Ladha HS, Bhattacharya A, Krishna SG, Ross WA, Bhutani MS, Tamm EP, Bhosale P, Raju GS, Fleming JB, Lee JH. Yield of endoscopic ultrasound in screening for pancreatic cancer at a tertiary cancer center. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB413. Just a meeting abstract
Singh P, Mukhopadhyay P, Bhatt B, . Endoscopic ultrasound versus ct scan for detection of the metastases to the liver: Results of a prospective comparative study. J Clin Gastroenterol. 2009 Apr;43(4):367–373. Not pancreatic adenocarcinoma18981929
Singh S, Reddymasu S, Waheed S, . Endoscopic ultrasonography findings in patients with non-specific changes of the pancreas on computed tomography: a single-center experience. Dig Dis Sci. 2008 Oct;53(10):2799–804. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18320316
Singhal D, Vasdev N, Soin A, . Distinguishing between periampullary carcinoids and carcinomas - Is this possible preoperatively? Indian J Gastroenterol. 2006;25(4):206–207. Just a meeting abstract16974039
Slaar A, Eshuis WJ, van der Gaag NA, . Predicting distant metastasis in patients with suspected pancreatic and periampullary tumors for selective use of staging laparoscopy. World J Surg. 2011 Nov;35(11):2528–34. No data specific to an imaging test of interest21882032
Smith SL, Basu A, Rae DM, . Preoperative staging accuracy of multidetector computed tomography in pancreatic head adenocarcinoma. Pancreas. 2007 Mar;34(2):180–4. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17312455
Smith ZL, Sifuentes H, Deepak P, Ecanow DB, Ehrenpreis ED. Relationship between mesenteric abnormalities on computed tomography and malignancy: Clinical findings and outcomes of 359 patients. J Clin Gastroenterol. May–June 2013;47(5):409–414. Single test of interest and no harms/screening/patient preference data23188076
Snady H. EUS criteria for vascular invasion: analyzing the meta-analysis. Gastrointest Endosc. 2007 May;65(6):798–807. News/opinion/editorial17466198
Sodikoff JB, Johnson HL, Lewis MM, . Increased diagnostic yield of endoscopic ultrasound-guided fine needle aspirates with flow cytometry and immunohistochemistry. Diagn Cytopathol. 2012 Jul 26. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Sofuni A, Iijima H, Moriyasu F, . Differential diagnosis of pancreatic tumors using ultrasound contrast imaging. J Gastroenterol. 2005 May;40(5):518–25. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15942718
Sperti C, Pasquali C, Chierichetti F, . Value of 18-fluorodeoxyglucose positron emission tomography in the management of patients with cystic tumors of the pancreas. Ann Surg. 2001 Nov;234(5):675–80. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11685032
Spier BJ, Johnson EA, Gopal DV, . Predictors of malignancy and recommended follow-up for patients with negative endoscopic ultrasound-guided fine-needle aspiration of suspected pancreatic lesions. Can J Gastroenterol. 2009;23(4):279–286. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19373422
Squillaci E, Fanucci E, Sciuto F, . Vascular involvement in pancreatic neoplasm: a comparison between spiral CT and DSA. Dig Dis Sci. 2003 Mar;48(3):449–58. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12757155
Sreenarasimhaiah J. Efficacy of endoscopic ultrasound in characterizing mass lesions in chronic pancreatitis. J Clin Gastroenterol. 2008 Jan;42(1):81–5. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18097295
Stoita A, Penman ID. EUS FNA for solid pancreatic masses lessons from practice and pitfalls. J Gastroenterol Hepatol. 2012 Oct;27:64. Just a meeting abstract
Strobel K, Heinrich S, Bhure U, . Contrast-enhanced 18F-FDG PET/CT: 1-stop-shop imaging for assessing the resectability of pancreatic cancer. J Nucl Med. 2008 Sep;49(9):1408–13. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18703604
Sugimoto M, Yasuda H, Koda K, . Carbon dioxide-enhanced virtual MDCT cholangiopancreatography. J Hepatobiliary Pancreat Sci. 2010 Sep;17(5):601–10. Only a single imaging test of interest, and N <5019806296
Sugiyama Y, Fujinaga Y, Kadoya M, . Characteristic magnetic resonance features of focal autoimmune pancreatitis useful for differentiation from pancreatic cancer. Jpn J Radiol. 2012 May;30(4):296–309. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22237599
Sumiyoshi T, Shima Y, Okabayashi T, Kozuki A, Nakamura T. Comparison of pancreatic acinar cell carcinoma and adenocarcinoma using multidetector-row computed tomography. World J Gastroenterol. 14 Sep 2013;19(34):5713–5719. Single test of interest and no harms/screening/patient preference data24039366
Tada M, Komatsu Y, Kawabe T, . Quantitative analysis of K-ras gene mutation in pancreatic tissue obtained by endoscopic ultrasonography-guided fine needle aspiration: clinical utility for diagnosis of pancreatic tumor. Am J Gastroenterol. 2002 Sep;97(9):2263–70. Only a single imaging test of interest, and N <5012358243
Tadic M, Kujundzic M, Stoos-Veic T, . Role of repeated endoscopic ultrasound-guided fine needle aspiration in small solid pancreatic masses with previous indeterminate and negative cytological findings. Dig Dis. 2008;26(4):377–82. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19188731
Tae YL, Kim M-H, Do HP, . Utility of18F-FDG PET/CT for differentiation of autoimmune pancreatitis with atypical pancreatic imaging findings from pancreatic cancer. AJR Am J Roentgenol. 2009 Aug;193(2):343–348. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19620430
Takahashi K, Yamao K, Okubo K, . Differential diagnosis of pancreatic cancer and focal pancreatitis by using EUS-guided FNA. Gastrointest Endosc. 2005 Jan;61(1):76–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15672060
Takahashi N, Fletcher JG, Fidler JL, . Dual-phase CT of autoimmune pancreatitis: a multireader study. AJR Am J Roentgenol. 2008 Feb;190(2):280–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18212210
Takahashi N, Fletcher JG, Hough DM, . Autoimmune pancreatitis: differentiation from pancreatic carcinoma and normal pancreas on the basis of enhancement characteristics at dual-phase CT. AJR Am J Roentgenol. 2009 Aug;193(2):479–84. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19620446
Tamm EP, Balachandran A, Bhosale P, . Primary pancreatic adenocarcinoma. Appl Radiol. 2008 Jun;37(6):26–34. Narrative review
Tamm EP, Loyer EM, Faria S, . Erratum to: Staging of pancreatic cancer with multidetector CT in the setting of preoperative chemoradiation therapy. Abdom Imaging. 2011 Feb 25. Just a meeting abstract
Tamm EP, Loyer EM, Faria S, . Staging of pancreatic cancer with multidetector CT in the setting of preoperative chemoradiation therapy. Abdom Imaging. 2006 Sep–Oct;31(5):568–74. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives16465578
Tanaka S, Nakaizumi A, Ioka T, . Periodic Ultrasonography Checkup for the Early Detection of Pancreatic Cancer: Preliminary Report. Pancreas. 2004 Apr;28(3):268–272. No data specific to an imaging test of interest15084969
Tapper EB, Martin D, Adsay NV, . An MRI-driven practice: a new perspective on MRI for the evaluation of adenocarcinoma of the head of the pancreas. J Gastrointest Surg. 2010 Aug;14(8):1292–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20467829
Tatsumi M, Isohashi K, Onishi H, . 18F-FDG PET/MRI fusion in characterizing pancreatic tumors: comparison to PET/CT. Int J Clin Oncol. 2011 Aug;16(4):408–15. No outcomes of interest21347626
Taylor AM, Roberts SA, Manson JM. Experience with laparoscopic ultrasonography for defining tumour resectability in carcinoma of the pancreatic head and periampullary region. Br J Surg. 2001 Aug;88(8):1077–83. No data specific to an imaging test of interest11488793
Tesiram YA, Lerner M, Stewart C, . Utility of nuclear magnetic resonance spectroscopy for pancreatic cancer studies. Pancreas. 2012 Apr;41(3):474–80. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22422139
Tessler DA, Catanzaro A, Velanovich V, . Predictors of cancer in patients with suspected pancreatic malignancy without a tissue diagnosis. Am J Surg. 2006 Feb;191(2):191–7. No outcomes of interest16442944
Thotakura R, Bawany M, De Las Casas L, . Endoscopic ultrasound guided pancreatic fine needle aspiration at a newly established northwest ohio university hospital. Am J Gastroenterol. 2012;107:S111–S112. Just a meeting abstract
Toki M, Yamaguchi Y, Kurata I, Tabei K, Hata H, Hasue T, Nakamura K, Takahashi S. Diabetes mellitus as a risk factor for pancreatic cancer-for realization of efficient screening of pancreatic cancer in patients with diabetes mellitus. Gastroenterology. 2013 May;144(5 Suppl 1):S659. Just a meeting abstract
Topkan E, Parlak C, Yapar AF. FDG-PET/CT-based restaging may alter initial management decisions and clinical outcomes in patients with locally advanced pancreatic carcinoma planned to undergo chemoradiotherapy. Cancer Imaging. 2013;13(3):423–428. Single test of interest and no harms/screening/patient preference data24240137
Touchefeu Y, Le Rhun M, Coron E, . Endoscopic ultrasound-guided fine-needle aspiration for the diagnosis of solid pancreatic masses: the impact on patient-management strategy. Aliment Pharmacol Ther. 2009 Nov 15;30(10):1070–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19735232
Tran Cao HS, Balachandran A, Wang H, Nogueras-Gonzalez GM, Bailey CE, Lee JE, Pisters PW, Evans DB, Varadhachary G, Crane CH, Aloia TA, Vauthey JN, Fleming JB, Katz MH. Radiographic Tumor-Vein Interface as a Predictor of Intraoperative, Pathologic, and Oncologic Outcomes in Resectable and Borderline Resectable Pancreatic Cancer. J Gastrointest Surg. 2013 Oct 16. Single test of interest and no harms/screening/patient preference data
Trifunovic J, Muzikravic L, Prvulovic M, . Evaluation of imaging techniques and CA 19-9 in differential diagnosis of carcinoma and other focal lesions of pancreas. Arch Oncol. 2004 Aug;12(2):104–108. No data specific to an imaging test of interest
Tseng DSJ, Van Santvoort HC, Fegrachi S, Besselink MGH, Borel Rinkes IHM, Van Leeuwen MS, Molenaar IQ. Diagnostic accuracy of contrast-enhanced computed tomography in assessing extra-regional lymphadenopathy in pancreatic and periampullary cancer: A systematic review. Pancreatology. 2013 May–Jun;13(3 Suppl 1):S85. Just a meeting abstract
Tummala P, Agarwal B. Focal non-cystic pancreatic lesions without proximal dilation of pancreatic duct noted on CT/MRI in patients without jaundice: Differential diagnosis and role of EUS. Gastrointest Endosc. 2012 Apr;75(4 Suppl 1): AB198. Just a meeting abstract
Tummala P, Munigala S, Agarwal B. EUS-FNA can obviate a large number of unnecessary surgeries while missing very few potentially resectable pancreatic cancers in jaundiced patients with suspected pancreatic cancer. Pancreas. 2011 Nov;40(8):1359. Just a meeting abstract
Tummala P, Munigala S, Eloubeidi MA, Agarwal B. Patients with obstructive jaundice and biliary stricture + mass lesion on imaging: prevalence of malignancy and potential role of EUS-FNA. J Clin Gastroenterol. 2013 Jul;47(6):532–7. Single test of interest and no harms/screening/patient preference data23340062
Tummala P, Munigala S, Eloubeidi MA, . Patients with obstructive jaundice and biliary stricture+/-mass lesion on imaging: prevalence of malignancy and potential role of EUS-FNA. J Clin Gastroenterol. 2013 Jan 18. No methods statement of the plan to measure harms
Tummala P, Tariq SH, Chibnall JT, . Clinical predictors of pancreatic carcinoma causing acute pancreatitis. Pancreas. 2013 Jan;42(1):108–13. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22722258
Turner BG, Cizginer S, Agarwal D, . Diagnosis of pancreatic neoplasia with EUS and FNA: a report of accuracy. Gastrointest Endosc. 2010 Jan;71(1):91–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19846087
Uehara H, Ikezawa K, Kawada N, . Diagnostic accuracy of endoscopic ultrasound-guided fine needle aspiration for suspected pancreatic malignancy in relation to the size of lesions. J Gastroenterol Hepatol. 2011 Aug;26(8):1256–61. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21501226
Ulla-Rocha JL, Alvarez-Prechous A, Paz-Esquete J, . The global impact of endoscopic ultrasound (EUS) regarding the survival of a pancreatic adenocarcinoma in a tertiary hospital. J Gastrointest Cancer. 2010 Sep;41(3):165–72. Survival data with or without a given test; did not compare survival of those who received one test to the survival of those who received another20165932
Uomo G, Pezzilli R. Pancreatic cancer: The effect of specialization and new medical treatment. JOP. 2004 Sep;5(5):397–399. Narrative review15365212
Uyar Gocun F, Eser EP, Akyol G, . Endoscopic ultrasound-fine needle aspiration (EUS-FNA) for pancreatic lesions: Cytologic and histopathologic correlation. Cytopathology. 2011 Oct;22:178. Just a meeting abstract
Vachiranubhap B, Kim YH, Balci NC, . Magnetic resonance imaging of adenocarcinoma of the pancreas. Top Magn Reson Imaging. 2009 Feb;20(1):3–9. Narrative review19687720
Valls C, Andia E, Sanchez A, . Dual-phase helical CT of pancreatic adenocarcinoma: assessment of resectability before surgery. AJR Am J Roentgenol. 2002 Apr;178(4):821–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives11906855
van Vliet EP, Eijkemans MJ, Kuipers EJ, . Publication bias does not play a role in the reporting of the results of endoscopic ultrasound staging of upper gastrointestinal cancers. Endoscopy. 2007 Apr;39(4):325–32. No data specific to an imaging test of interest17427068
Vanbiervliet G, Fumex F, Saint-Paul M-C, Wangermez M, Fabre M, Bichard P, Subtil C, Koch S, Grandval P, Gincul R, Karsenti D, Heyries L, Duchmann J-C, Bourgaux J-F, Levy M, Calament G, Napoleon B, Pujol B, Lefort C, Poincloux L, Pagenault M, Sakarovitch C, Barthet M. Prospective randomized controlled trial with crossover of endoscopic ultrasound fine needle aspiration (EUS-FNA) using 22g procore and 22g echotip needle for solid pancreatic mass: The “picore” study. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB178. Just a meeting abstract
Varadarajulu S, Bang JY, Hebert-Magee S. Assessment of the technical performance of the flexible 19-gauge EUS-FNA needle. Gastrointest Endosc. 2012 Aug;76(2):336–43. Only a single imaging test of interest, and N <5022817786
Varadarajulu S, Bang JY. Assessment of the technical performance and safety profile of the flexible 19-gauge EUS-FNA platform. Gastrointest Endosc. 2012 Apr;75(4 Suppl. 1):AB191. Just a meeting abstract
Vasile TA, Feier D, Socaciu M, . Contrast enhanced ultrasound and computer tomography diagnosis of solid and mixed pancreatic tumors - analysis of confounders. J Gastrointest Liver Dis. 2012 Sep;21(3):285–292. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Vazquez-Sequeiros E, Gonzalez-Panizo F, Foruny-Olcina JR, Defarges-Pons V, Gonzalez-Garcia C, Gonzalez-Martin JA, Juzgado D, Boixeda-Miquel D, Albillos A. Is it really needed to discontinue antiplatelet agents (APA) prior to EUS-FNA Performance?: A Prospective Comparative Study. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB523. Just a meeting abstract
Vazquez-Sequeiros E. Endoscopic ultrasonography - an established technique with a brilliant future. Rev Esp Enferm Dig. 2009 Sep;101(9):595–600. Narrative review19803661
Verma SR, Sahai SB, Gupta PK, . Obstructive jaundice-aetiological spectrum, clinical, biochemical and radiological evaluation at a tertiary care teaching hospital. Internet J Trop Med. 2011;7(2) Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives
Vilmann P, Saftoiu A, Hollerbach S, Skov BG, Linnemann D, Popescu CF, Wellmann A, Gorunescu F, Clementsen P, Freund U, Flemming P, Hassan H, Gheonea DI, Streba L, Ioncica AM, Streba CT. Multicenter randomized controlled trial comparing the performance of 22 gauge versus 25 gauge EUS-FNA needles in solid masses. Scand J Gastroenterol. July 2013;48(7):877–883. Single test of interest and no harms/screening/patient preference data23795663
Volmar KE, Vollmer RT, Jowell PS, . Pancreatic FNA in 1000 cases: a comparison of imaging modalities. Gastrointest Endosc. 2005 Jun;61(7):854–61. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives15933687
Wakabayashi H, Nishiyama Y, Otani T, . Role of 18F-fluorodeoxyglucose positron emission tomography imaging in surgery for pancreatic cancer. World J Gastroenterol. 2008 Jan 7;14(1):64–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18176963
Wakabayashi T, Kawaura Y, Satomura Y, . Clinical and imaging features of autoimmune pancreatitis with focal pancreatic swelling or mass formation: comparison with so-called tumor-forming pancreatitis and pancreatic carcinoma. Am J Gastroenterol. 2003 Dec;98(12):2679–87. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14687817
Walters DM, Lapar DJ, de Lange EE, . Pancreas-protocol imaging at a high-volume center leads to improved preoperative staging of pancreatic ductal adenocarcinoma. Ann Surg Oncol. 2011 Oct;18(10):2764–71. No data specific to an imaging test of interest21484522
Wang KX, Ben QW, Jin ZD, . Assessment of morbidity and mortality associated with EUS-guided FNA: A systematic review. Gastrointest Endosc. 2011 Feb;73(2):283–90. No reviewer estimates of sensitivity and specificity21295642
Wang W, Shpaner A, Krishna SG, Ross WA, Bhutani MS, Tamm EP, Raju GS, Xiao L, Wolff RA, Fleming JB, Lee JH. Use of EUS-FNA in diagnosing pancreatic neoplasm without a definitive mass on CT. Gastrointest Endosc. 2013 Mar 21. Single test of interest and no harms/screening/patient preference data
Wang X, Gao J, Ren Y, . Detection of KRAS gene mutations in endoscopic ultrasound-guided fine-needle aspiration biopsy for improving pancreatic cancer diagnosis. Am J Gastroenterol. 2011 Dec;106(12):2104–2111. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21876563
Wang X, Xue HD, Jin ZY, . Quantitative hepatic CT perfusion measurement: comparison of Couinaud’s hepatic segments with dual-source 128-slice CT. Eur J Radiol. 2013 Feb;82(2):220–6. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives23083523
Wani S, Early D, Kunkel J, . Diagnostic yield of malignancy during EUS-guided FNA of solid lesions with and without a stylet: a prospective, single blind, randomized, controlled trial. Gastrointest Endosc. 2012 Aug;76(2):328–35. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22695205
Weilert F, Bhat YM, Binmoeller K, Kane S, Jaffee IM, Cameron RG, Hashimoto Y, Shah JN. EUS-FNA is superior to ERCP tissue sampling in suspected malignant biliary obstruction. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB423. Just a meeting abstract
Weisbord SD, Mor MK, Resnick AL, . Prevention, incidence, and outcomes of contrast-induced acute kidney injury. Arch Intern Med. 2008 Jun 23;168(12):1325–32. Not specific to pancreatic cancer, data on harms but is pre-200918574090
Weiser MA, Cabanillas M, Vu K, . Diagnostic evaluation of patients with a high suspicion of malignancy: Comorbidities and clinical predictors of cancer. Am J Med Sci. 2005 Jul;330(1):11–18. No statement in the methods about plan to capture harms16020994
Wiggermann P, Grutzmann R, Weissenbock A, . Apparent diffusion coefficient measurements of the pancreas, pancreas carcinoma, and mass-forming focal pancreatitis. Acta Radiol. 2012 Mar 1;53(2):135–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22262868
Will U, Mueller A, Topalidis T, . Value of endoscopic ultrasonography-guided fine needle aspiration (FNA) in the diagnosis of neoplastic tumor(-like) pancreatic lesions in daily clinical practice. Ultraschall Med. 2010 Apr;31(2):169–74. Non-English19899026
Wilson JL, Kalade A, Prasad S, . Diagnosis of solid pancreatic masses by endoscopic ultrasound-guided fine-needle aspiration. Intern Med J. 2009 Jan;39(1):32–7. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives18422561
Woo YS, Lee S-O, Kang KJ, Lee KH, Lee JK, Lee KT, Rhee P-L. Endoscopic ultrasound-guided fine needle aspiration of solid masses: Histological and immunohistochemical evaluation. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB402. Just a meeting abstract
Woolf KM, Liang H, Sletten ZJ, Russell DK, Bonfiglio TA, Zhou Z. False-negative rate of endoscopic ultrasound-guided fine-needle aspiration for pancreatic solid and cystic lesions with matched surgical resections as the gold standard: one institution’s experience. Cancer Cytopathol. 2013 Aug;121(8):449–58. Single test of interest and no harms/screening/patient preference data23677908
Woolf KMW, Liang H, Sletten ZJ, Russell DK, Bonfiglio TA, Zhou Z. False-negative rate of endoscopic ultrasound-guided fine-needle aspiration for pancreatic solid and cystic lesions with matched surgical resections as the gold standard. Cancer Cytopathol. August 2013;121(8):449–458. Single test of interest and no harms/screening/patient preference data23677908
Wright G, Shaheen M, Baatenburg L, . Accuracy of endoscopic ultrasound in the evaluation of suspected pancreatic malignancy: A community hospital experience. HPB. 2012 Jul;14:587. Just a meeting abstract
Wu H, Cheng NS, Zhang YG, . Improved early diagnosis of cystadenocarcinoma of the pancreas. Hepatobiliary Pancreat Dis Int. 2007 Feb;6(1):87–91. Cystadenocarcinoma is not a common pancreatic adenocarcinoma17287173
Wu WC, Yao XZ, Jin DY, Wang DS, Lou WH, Qin XY. Clinical strategies for differentiating autoimmune pancreatitis from pancreatic malignancy to avoid unnecessary surgical resection. J Dig Dis. September 2013;14(9):500–508. Not one of the 4 imaging tests of interest (CT, EUS-FNA, MRI, or PET-CT)23692995
Wylie N, Adib R, Barbour AP, . Surgical management in patients with pancreatic cancer: a Queensland perspective. ANZ J Surg. 2012 Oct 24. No outcomes of interest
Xu AM, Cheng HY, Jiang WB, . Multi-slice three-dimensional spiral CT cholangiography: a new technique for diagnosis of biliary diseases. Hepatobiliary Pancreat Dis Int. 2002 Nov;1(4):595–603. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives14607694
Xu C, Zhu M, Yu J, Wu Y, Jin Z, Li Z. EUS image based digital imaging processing technology in the differentiation of pancreatic cancer and mass forming autoimmune pancreatitis. Gastrointest Endosc. 2013 May;77(5 Suppl 1):AB414–5. Just a meeting abstract
Xu J, Liang Z, Hao S, . Pancreatic adenocarcinoma: dynamic 64-slice helical CT with perfusion imaging. Abdom Imaging. 2009 Nov;34(6):759–66. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19672566
Yamada Y, Mori H, Matsumoto S, . Pancreatic adenocarcinoma versus chronic pancreatitis: differentiation with triple-phase helical CT. Abdom Imaging. 2010 Apr;35(2):163–71. No data specific to an imaging test of interest19771464
Yang S-C, Liu S-H, Chang K-M. Iothalamate Meglumine induced transient tachycardia during intravenous bolus injection for CT and parameters related to its discomfort. Chin J Radiol. 2008 Sep;33(3):131–136. Not specific to pancreatic cancer, data on harms but is pre-2009
Yao XZ, Yun H, Zeng MS, . Evaluation of ADC measurements among solid pancreatic masses by respiratory-triggered diffusion-weighted MR imaging with inversion-recovery fat-suppression technique at 3.0T. Magn Reson Imaging. 2012 Nov 29. Not pancreatic adenocarcinoma
Yen RD, Mullady D, Early DS, Rastogi A, Wang JF, Collins BT, Sams SB, Marshall C, Rizeq M, Romanas MM, Ulusarac O, Brauer BC, Amateau SK, Gaddam S, Siller BA, Hollander TG, Johnson S, Kohlmeier C, Azar RR, Das A, Fukami N, Shah RJ, Edmundowicz SA, Wani S. Predictors for diagnosis of malignancy in endoscopic ultrasonography-guided fine needle aspiration (EUS-FNA) of pancreatic masses: Results from a multicenter, prospective randomized controlled trial. Gastroenterology. 2013 May;144(5 Suppl 1):S567. Just a meeting abstract
Ylagan LR, Edmundowicz S, Kasal K, . Endoscopic ultrasound guided fine-needle aspiration cytology of pancreatic carcinoma: a 3-year experience and review of the literature. Cancer. 2002 Dec 25;96(6):362–9. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12478684
Yoon SH, Lee JM, Cho JY, . Small (<= 20 mm) pancreatic adenocarcinomas: analysis of enhancement patterns and secondary signs with multiphasic multidetector CT. Radiology. 2011 May;259(2):442–52. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives21406627
Yoshinaga S, Suzuki H, Oda I, . Role of endoscopic ultrasound-guided fine needle aspiration (EUS-FNA) for diagnosis of solid pancreatic masses. Dig Endosc. 2011 May;23: Suppl 1:29–33. Narrative review21535197
Yun SS, Remotti H, Vazquez MF, . Endoscopic ultrasound-guided biopsies of pancreatic masses: comparison between fine needle aspirations and needle core biopsies. Diagn Cytopathol. 2007 May;35(5):276–82. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17427217
Zamboni GA, Kruskal JB, Vollmer CM, . Pancreatic adenocarcinoma: value of multidetector CT angiography in preoperative evaluation. Radiology. 2007 Dec;245(3):770–8. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives17951353
Zanello A, Nicoletti R, Brambilla P, . Magnetic resonance with manganese-DPDP (mangafodipir) of focal solid pancreatic lesions. Radiol Med. 2004 Sep;108(3):194–207. Non-English15343134
Zhang L, Jin H, Guo X, . Distinguishing pancreatic cancer from chronic pancreatitis and healthy individuals by (1)H nuclear magnetic resonance-based metabonomic profiles. Clin Biochem. 2012 Sep;45(13–14):1064–9. No data specific to an imaging test of interest22613268
Zhang MM, Yang H, Jin ZD, . Differential diagnosis of pancreatic cancer from normal tissue with digital imaging processing and pattern recognition based on a support vector machine of EUS images. Gastrointest Endosc. 2010 Nov;72(5):978–85. No data specific to an imaging test of interest20855062
Zhang S, Defrias DVS, Alasadi R, . Endoscopic ultrasound-guided fine needle aspiration (EUS-FNA): Experience of an academic centre in the USA. Cytopathology. 2010 Feb;21(1):35–43. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives19843142
Zhang WX, Shi H, Xu JM. Survival and prognosis of patients with pancreatic carcinoma: An analysis of 156 cases. World Chin J Digestol. 2011;19(34):3526–31. Non-English
Zhang Y, Garcia-Buitrago M, Ganjei P, . Detection of chromosomal abnormalities by fluorescence in situ hybridization on ultrasound guided fine-needle aspiration samples from pancreas. Lab Invest. 2012 Feb;92:112A. Just a meeting abstract
Zheng M, Liu LX, Zhu AL, . K-ras gene mutation in the diagnosis of ultrasound guided fine-needle biopsy of pancreatic masses. World J Gastroenterol. 2003 Jan;9(1):188–91. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives12508380
Zheng YL, Yin XY, Xie XY, . Value of contrast-enhanced ultrasonography in assessing the vascularity of liver metastases: comparison with contrast-enhanced computed tomography. J Ultrasound Med. 2010 Oct;29(10):1403–10. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives20876893
Zhong L, Yao QY, Li L, . Imaging diagnosis of pancreato-biliary diseases: a control study. World J Gastroenterol. 2003 Dec;9(12):2824–7. No outcomes of interest14669343
Zihao G, Jie Z, Yan L, . Analyzing S100A6 expression in endoscopic ultrasonography-guided fine-needle aspiration specimens: a promising diagnostic method of pancreatic cancer. J Clin Gastroenterol. 2013 Jan;47(1):69–75. Only a single imaging test of interest, and did not meet criteria for harms/screening/patient perspectives22914344
Zubarik R, Gordon SR, Lidofsky SD, . Screening for pancreatic cancer in a high-risk population with serum CA 19-9 and targeted EUS: a feasibility study. Gastrointest Endosc. 2011 Jul;74(1):87–95. Only a single imaging test of interest, and N <5021704809