# Appendix A Search Strategy

Table A-1 Search strategy

Set Number | Concept | Search Statement
1 | Pancreatic Cancer/pancreas | exp pancreatic neoplasms/ or pancreas cancer/ or pancreatic cyst/
2 | | ((exp pancreas/ or exp pancreas, exocrine/) and (neoplasm/ or adenocarcinoma/ or neoplasms/)) or pancreas tumor/ or Pancreatic neuroendocrine tumor/
3 | | (Pancrea$ adj3 (mass$ or cancer$ or tumo?r$ or sarcoma$ or neoplasm$ or carcinoma$ or adenocarcinoma$)).mp.
4 | | neuroendocrine tumors/ and pancrea$.ti,ab.
5 | | Pancreatic neoplasms
6 | | 4 not 5
7 | | 1 or 2 or 3 or 6
8 | Imaging | Endosonography/ or exp fluorodeoxyglucose F18/ or exp magnetic resonance imaging or exp positron-emission tomography/ or exp tomography, x-ray computed/ or exp ultrasonography/ or endoscopic echography/ or ultrasound/
9 | | Computer assisted emission tomography/ or computer assisted tomography/ or nuclear magnetic resonance imaging/ or positron emission tomography/
10 | | Exp Diagnostic imaging/ or exp magnetic resonance imaging/ or pancreas/ra or pancreas/us or pancreatic ducts/ra or pancreatic ducts/us
11 | | (“computed tomography” or “positron emission” or “positron-emission” or “magnetic resonance” or “endoscopic ultraso$” or “computer assisted emission tomography” or “computer assisted tomography” or computer-assisted tomography).ti,ab.
12 | | (SDCT or MDCT or FDG-PET or CT or PET or PET/CT or MRI or EUS).mp.
13 | | “Fludeoxyglucose positron emission tomography”.mp.
14 | | ((single?detector or multi?detector or multi?dimensional) adj (CT or “computed tomography”)).mp.
15 | | (Endoscop$ adj (ultrasound or ultrasonograph$ or echograph$)).ti,ab.
16 | | Or/8–15
17 | Pancreatic cancer and imaging | 7 and 16
18 | Diagnosis | exp pancreatic neoplasms/di or pancreatic cyst/di
19 | | Diagnos$.mp. or early diagnosis/ or diagnosis, differential/ or diagnosis/ or neuroendocrine tumor/di [Diagnosis]
20 | | pancreatic neoplasms/di, pa, us [Diagnosis, Pathology, Ultrasonography] or pancreas tumor/di [Diagnosis] or pancreas cancer/di
21 | | pancreatitis, chronic/di, pa, us [Diagnosis, Pathology, Ultrasonography] or chronic pancreatitis/di [Diagnosis]
22 | | 17 and di.fs.
23 | | Or/18–22
24 | Pancreatic cancer and imaging and diagnosis | 17 and 23
25 | Staging | Cancer staging/ or Neoplasm staging/
26 | | ((mass$ or cancer$ or tumo?r$ or sarcoma$ or neoplasm$ or carcinoma$ or adenocarcinoma$) and (biopsy or category or classification or classify or detect$ or stage or diagnos$ or staging)).ti,ab.
27 | | ((mass$ or cancer$ or tumo?r$ or sarcoma$ or neoplasm$ or carcinoma$ or adenocarcinoma$) and (“fine needle” or fine-needle or FNA or FNB or specimen or sample or sampling)).ti,ab.
28 | | Or/25–27
29 | Pancreatic cancer and imaging and staging | 17 and 28
30 | Diagnosis test – accuracy, specificity | 17 and (exp diagnosis/ or di.fs.)
31 | | 17 and (receiver operating characteristic/ or ROC curve/ or diagnostic accuracy/ or accuracy/)
32 | | 17 and (precision or sensitivity or specificity or predict$ or forecast$ or likelihood or ((false or true) adj (positive or negative))).mp.
33 | | 17 and (predictive value of tests/ or exp diagnostic errors/ or exp diagnostic error/)
34 | Pancreatic cancer and imaging and diagnostic testing | Or/29–33
35 | Screening | mass screening/ or early detection of cancer/ or population surveillance/
36 | | Cancer screening/ or cancer risk/ or risk factors/
37 | | (risk$ or screen$ or hereditary or inherit$ or gene$ or family history).ti,ab.
38 | | or/ 35–37
39 | Pancreatic cancer and imaging and screening | 17 and 38
40 | Prognosis/survival | incidence/ or mortality/ or follow up studies/ or prognos$.mp.or predict$.mp. or course$.mp. or (first and episode).ti,ab. Or cohort.ti,ab.
41 | | Exp “prediction and forecasting”/ or exp prognosis/ or exp survival rate/ or surviv$.mp.
42 | | 40 or 41
43 | Pancreatic cancer and imaging and prognosis/survival | 17 and 42
44 | Combine sets to review | 24 or 29 or 34 or 39 or 43
45 | Limit by date | Limit 44 to yr=“1990–2013”
46 | Limit | Limit 45 to humans
47 | Limit | Limit 46 to English language
48 | Remove duplicates | Remove duplicates from 47