# Abbreviations and Acronyms

95% CI: 95% confidence interval
AJCC: American Joint Committee on Cancer
BD-IPMN: branch duct intraductal papillary mucinous neoplasia
CER: comparative effectiveness review
CINAHL: Cumulative Index to Nursing and Allied Health Literature database
CKD: chronic kidney disease
cm: centimeter
CT: computed tomography
EPC: Evidence-based Practice Center
ERCP: endoscopic retrograde cholangiopancreatography
EUS: endoscopic ultrasound
EUS-FNA: endoscopic ultrasound with fine-needle aspiration
FDA: U.S. Food and Drug Administration
FDG: ^18^F-fluorodeoxyglucose
GBCA: gadolinium-based contrast agent
HRI: high-risk individual
IPMN: intraductal papillary mucinous neoplasia
IV: intravenous
kg: kilogram
KQ: Key Question
M stage: metastases stage
MDCT: multidetector computed tomography
MD-IPMN: main duct intraductal papillary mucinous neoplasia
MHz: megahertz
mg: milligram
mL: milliliter
mm: millimeter
mm Hg: millimeters of mercury
MRCP: magnetic resonance cholangiopancreatography
MRI: magnetic resonance imaging
N: number
N stage: nodal stage
NA: not applicable
NR: not reported
NS: not significant
NSF: nephrogenic systemic fibrosis
p: probability value
PanIN: pancreatic intraepithelial neoplasia
PET: positron emission tomography
PET/CT: positron emission tomography–computed tomography
QUADAS: quality assessment tool for diagnostic accuracy studies
SD: standard deviation
SEER: Surveillance Epidemiology and End Results (National Cancer Institute)
SMA: superior mesenteric artery
SMV: superior mesenteric vein
T stage: tumor stage
T: Tesla