# Results

## Search Results

Our search identified 1,521 citations, of which 38 required full-text review after title and abstract screening (Figure 1). Of the 38 full text articles screened, we identified 11 eligible studies representing 11 unique reports of original research10-20 and two relevant systematic reviews.21, 22 Studies excluded after full-text review are listed in Appendix E along with exclusion reasons.

Figure 1 Literature flow diagram

Figure 1 describes the results of the literature search and screening process that led to the inclusion of eligible studies. Exact numbers are mentioned in the text.

We categorized studies into groups for synthesis based on CUR etiology:

- CUR from obstructive causes
- CUR from non-obstructive causes
- CUR in mixed populations/unknown causes

Eligible studies rarely specified CUR duration. We included any study that treated CUR related to chronic conditions or that specified persistent or multiple measurements. The appendices of this report provide detailed information about the included studies: characteristics of the individual studies (Appendix F); risk of bias and quality assessments of original research and systematic reviews (Appendix G); summaries of included studies, analysis, and detailed outcomes tables (Appendix H); and detailed strength of evidence assessments (Appendix I).

## Comparative Effectiveness of Treatments for CUR: Obstructive Causes

We identified three eligible studies for treatment of CUR from obstructive causes; all three were RCTs that compared treatments for CUR in men with bladder outlet obstruction due to benign prostatic enlargement.12, 13, 19 All defined CUR as persistent PVR >300ml. Participants also had to have other lower urinary tract symptoms. The mean age of the 243 men enrolled was 71 years. Two studies reported mean baseline International Prostate Symptom Scores (IPSS) and PVR volumes with a mean baseline total IPSS of 21.4 (indicating severe symptoms) and mean baseline PVR volume of 626 ml. All three trials compared surgery (transurethral resection of the prostate [TURP] or prostate enucleation) to a less invasive intervention (laser, microwave, clean intermittent sterile catheterization [CISC]). Two trials were conducted in Europe and one in Asia. All trials measured outcomes at 6 to 7.5 months. All three demonstrated methodological problems (i.e., inability to blind patient and provider, allocation concealment) and each was assessed as having overall moderate risk of bias. Table 2 provides a summary of primary outcomes and adverse effects.

Table 2 Summary outcomes and strength of evidence: treatments for obstructive chronic urinary retention

Study (n); Comparison; Inclusion Criteria; Design | Outcomes | Results | Strength of Evidence (Explanation for Assessment)
Schelin 2006^12^ (n=120) TURP or prostate enucleation surgery vs. microwave therapy Men ≥45 years of age with symptomatic BPH and PVR >300mL RCT | Primary outcomes
Schelin 2006^12^ (n=120) TURP or prostate enucleation surgery vs. microwave therapy Men ≥45 years of age with symptomatic BPH and PVR >300mL RCT | Urinary tract infection | NS RR 1.49 [0.82 to 2.71] | Insufficient (moderate risk of bias, imprecise, unclear consistency)
Schelin 2006^12^ (n=120) TURP or prostate enucleation surgery vs. microwave therapy Men ≥45 years of age with symptomatic BPH and PVR >300mL RCT | TWOC | NS RR 0.89 [0.76 to 1.05] | Low (moderate risk of bias, unclear consistency)
Schelin 2006^12^ (n=120) TURP or prostate enucleation surgery vs. microwave therapy Men ≥45 years of age with symptomatic BPH and PVR >300mL RCT
Schelin 2006^12^ (n=120) TURP or prostate enucleation surgery vs. microwave therapy Men ≥45 years of age with symptomatic BPH and PVR >300mL RCT | Adverse effects
Schelin 2006^12^ (n=120) TURP or prostate enucleation surgery vs. microwave therapy Men ≥45 years of age with symptomatic BPH and PVR >300mL RCT | Serious adverse events | NS | NA
Ghalayini 2005^13^ (n=51) TURP vs. CISC Men with LUTS, baseline IPSS >7 and PVR >300 mL RCT | Primary outcomes
Ghalayini 2005^13^ (n=51) TURP vs. CISC Men with LUTS, baseline IPSS >7 and PVR >300 mL RCT | None reported | NR | Insufficient (no data)
Ghalayini 2005^13^ (n=51) TURP vs. CISC Men with LUTS, baseline IPSS >7 and PVR >300 mL RCT
Ghalayini 2005^13^ (n=51) TURP vs. CISC Men with LUTS, baseline IPSS >7 and PVR >300 mL RCT | Adverse effects
Ghalayini 2005^13^ (n=51) TURP vs. CISC Men with LUTS, baseline IPSS >7 and PVR >300 mL RCT | Complication rate | NS | NA
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | Primary outcomes
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | Urinary tract infection | NS RR 1.73 [0.16 to 18.31] | Insufficient (moderate risk of bias, imprecise, unclear consistency)
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | Surgical intervention | NS RR 0.12 [0.01 to 2.32] | Insufficient (moderate risk of bias, imprecise, unclear consistency)
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | IPSS Category (Good, Fair, Poor) | NS RR 1.27 [95% CI 0.97 to 1.68] | Insufficient (high risk of bias, unclear consistency)
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | IPSS Category (Good, Fair, Poor) adjusted^**^ | TURP ↑ RR 3.9 [95% CI 1.0 to 14.3] | Low (moderate risk of bias, unclear consistency)
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | Adverse effects
Gujral 2000^19^ (n=82) TURP vs. laser therapy Men with LUTS and baseline IPSS ≥8 and PVR >300mL RCT | Complication rate | TURP ↑ | NA

BPH = benign prostatic hyperplasia; CI= confidence intervals; CISC = clean intermittent self-catheterization; IPSS = International Prostate Symptom Score (range 0 [mild symptoms] to 35 [severe symptoms]); LUTS = lower urinary tract symptoms; MD = mean difference; NA = not assessed; NR = not reported; NS = no statistically significant difference; PVR = post void residual; QoL = quality of life; RCT = randomized controlled trial; RR = risk ratio; TURP = transurethral resection of the prostate; TWOC = trial without catheter

** Adjustment for differences between groups at baseline in marital status and prostate volume

### Benefits

Two of the three RCTs reported on five primary outcomes (UTI, treatment failure, TWOC, need for surgical intervention, and International Prostate Symptom Score (IPSS) category).12, 19 The third RCT assessed only intermediate outcomes, analysis of which is not included here.13 Schelin et al., reported that 33 percent of the microwave therapy group and 22 percent of the TURP group experienced a UTI (diagnostic criteria not specified); 79 percent of the microwave therapy group and 88 percent of the TURP group were catheter free at 6 months; 7 percent of the microwave therapy group and 4 percent of the TURP group maintained PVR volumes above 300 ml.12 Neither trial self-identified as testing for equivalence or noninferiority. Low-strength evidence suggested that the rates at which men were catheter free at 6 months were similar between TURP and microwave therapy. Data was not available to prespecify a minimum important difference in the group proportions for this population-treatment-outcome, but equivalence could be inferred at any MID at or above a 25 percent differential (α=.05; β=.80).

Gujral, et al., reported that 5 percent of TURP and 3 percent of laser therapy groups had experienced UTIs at 7.5 months.19 No one in the TURP group and three in the laser group required surgery. Neither of these differences was statistically significant.

The third trial compared TURP to clean intermittent self-catheterization but did not evaluate any of our primary outcomes.13

All treatments tested in the three trials reduced PVR volumes, and the trials reported no statistically significant differences between comparisons.

### Harms

Each study measured adverse effects differently, reporting either incidence of specific adverse effects, incidence of serious adverse effects, or postsurgical complication rates. Reported harms included death, septicemia, bleeding, blood transfusions, and surgical complications. Harms did not differ between surgery versus microwave therapy or between surgery (TURP or prostate enucleation) versus clean intermittent self-catheterization, but a larger proportion of patients in the TURP group experienced complications (death, septicemia, bleeding, blood transfusions, and surgical complications) than in the laser group.19

## Comparative Effectiveness of Treatments for CUR: Non-Obstructive Causes

Four small efficacy studies and one systematic review compared treatments for CUR attributed to non-obstructive causes in adults. The systematic review, conducted by the Cochrane Incontinence Group, was assessed as having good quality.21 Herbison et al. reviewed sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults.21 We report the conclusion from that review in lieu of de novo abstraction and analysis of the original research (Table 3).17,18, 20

Table 3 Description and conclusions from previous systematic review relevant to treatment for CUR from non-obstructive causes

Study Information | Literature Through; SR Quality | Population; Relevant Comparison | Results; Conclusion Strength of Evidence
Herbison 2009^21^ (Cochrane Incontinence Group) Sacral neuromodulation with implanted devices for urinary storage and voiding dysfunction in adults 1 RCT | Literature search through February, 2009 Good | Patients with complete or partial idiopathic urinary retention Immediate/delayed implant (1 trial with CUR patients) | Catheter free: Early>Delay PVR: Early>Delay Low

RCT = randomized controlled trial; PVR = post void residual; SR = systematic review; UTI = urinary tract infection

Original research included three RCTs with moderate risk of bias and one prospective cohort design. Studies enrolled a total of 139 patients with sample sizes ranging from 13 to 86. The mean age of enrolled patients was 54, with a range from 46 to 66. Fifty-one percent of subjects were men. Baseline mean IPSS score was 21.4 across the two studies that measured IPSS, suggesting a severe level of symptoms. Neurogenic disorders among the patients included multiple sclerosis (64 percent), spinal cord injury (7 percent), and other conditions such as stroke or traumatic brain injury (29 percent). In the three studies reporting condition duration, patients had been living with these neurogenic disorders for an average of 13 years. Trials were conducted in Europe and Asia. Three studies compared botulinum A injected into the urethral sphincter to an inactive control (placebo, lidocaine, usual care). The fourth study compared bethanechol/prostaglandin (BC/PGE2) to placebo.

### Benefits

Herbison et al. addressed one comparison relevant to our review—early (immediate) implant versus a delayed implant (waitlist) in treating CUR from non-obstructive retention.21 Low-strength evidence suggests that early sacral neuromodulation with implanted devices is effective in achieving catheter-free status and reducing PVR in patients with idiopathic non-obstructive CUR. Remaining evidence was insufficient due to indirect outcomes and imprecise estimates created by the wide confidence intervals of underpowered studies (Table 4).

Table 4 Summary outcomes, adverse events, and strength of evidence assessments of treatments for CUR from non-obstructive causes

Study (n); Comparison; Inclusion Criteria; Design | Outcomes | Results | Strength of Evidence
Gallien 2005^14^ (n=86) Botulinum A toxin vs. Placebo MS patients with DSD. Patients with CUR had PVR of 100 to 500 ml RCT | Primary outcomes
Gallien 2005^14^ (n=86) Botulinum A toxin vs. Placebo MS patients with DSD. Patients with CUR had PVR of 100 to 500 ml RCT | Urinary tract infection | NS RR 1.21 [95% CI 0.66 to 2.25] | Insufficient (moderate risk of bias, indirect, imprecise, unclear consistency)
Gallien 2005^14^ (n=86) Botulinum A toxin vs. Placebo MS patients with DSD. Patients with CUR had PVR of 100 to 500 ml RCT | Adverse effects
Gallien 2005^14^ (n=86) Botulinum A toxin vs. Placebo MS patients with DSD. Patients with CUR had PVR of 100 to 500 ml RCT | Serious adverse events | NS | NA
Hindley 2004^15^ (n=19) Bethanechol chloride plus prostaglandin E2 vs. placebo Patients with suspected detrusor under-activity, defined as PVR >300 mL in the absence of BPO RCT | Primary outcomes
Hindley 2004^15^ (n=19) Bethanechol chloride plus prostaglandin E2 vs. placebo Patients with suspected detrusor under-activity, defined as PVR >300 mL in the absence of BPO RCT | TWOC | NS | Insufficient (moderate risk of bias, indirect, imprecise, unclear consistency)
Hindley 2004^15^ (n=19) Bethanechol chloride plus prostaglandin E2 vs. placebo Patients with suspected detrusor under-activity, defined as PVR >300 mL in the absence of BPO RCT | Adverse effects
Hindley 2004^15^ (n=19) Bethanechol chloride plus prostaglandin E2 vs. placebo Patients with suspected detrusor under-activity, defined as PVR >300 mL in the absence of BPO RCT | Any adverse events | NS | NA
de Sèze 2002^17^ (n=13) Botulinum A toxin vs. Lidocaine Patients with DSD. CUR defined as PVR >100 ml RCT | Primary outcomes: None reported | NR | Insufficient (no data)
de Sèze 2002^17^ (n=13) Botulinum A toxin vs. Lidocaine Patients with DSD. CUR defined as PVR >100 ml RCT | Adverse effects:
de Sèze 2002^17^ (n=13) Botulinum A toxin vs. Lidocaine Patients with DSD. CUR defined as PVR >100 ml RCT | Any adverse events | NS | NA
Chen 2004^16^ (n=21) Botulinum A toxin vs. usual care Patients with urethral sphincter pseudodyssynergia due to chronic cerebrovascular accidents or intracranial lesions Prospective cohort study | Primary outcomes:
Chen 2004^16^ (n=21) Botulinum A toxin vs. usual care Patients with urethral sphincter pseudodyssynergia due to chronic cerebrovascular accidents or intracranial lesions Prospective cohort study | None reported | NR | Insufficient (no data)
Chen 2004^16^ (n=21) Botulinum A toxin vs. usual care Patients with urethral sphincter pseudodyssynergia due to chronic cerebrovascular accidents or intracranial lesions Prospective cohort study | Adverse effects:
Chen 2004^16^ (n=21) Botulinum A toxin vs. usual care Patients with urethral sphincter pseudodyssynergia due to chronic cerebrovascular accidents or intracranial lesions Prospective cohort study | Serious adverse events | NS | NA

BPO = Benign Prostatic Obstruction; CI = confidence intervals; DSD = detrusor sphincter dyssynergia; IPSS = International Prostate Symptom Score (range 0 [mild symptoms] to 35 [severe symptoms]); MD = mean difference; MS = multiple sclerosis; NA = not assessed; NR = not reported; NS = no statistically significant difference; PVR = post void residual ; QoL = quality of life; RCT = randomized controlled trial; RR = risk ratio; TWOC = trial without catheter

### Harms

None of these studies found differences in the rates of serious or any adverse effects between treatment groups, though studies were not adequately powered to detect these.

## Comparative Effectiveness of Treatments for CUR: Mixed Populations/Unknown Causes

Four studies (original research) and one systematic review addressed six different comparisons for treatments for CUR in mixed populations or CUR from unknown causes. One comparison was adequately addressed by a previous systematic review.21, 22 The systematic review was conducted by the Cochrane Incontinence Group and assessed as being of good quality. We report conclusions from that review in lieu of de novo abstraction and analysis of the original research (Table 5).18, 20

Table 5 Description and conclusions from previous systematic reviews of treatments for CUR in mixed populations or unknown causes

Study Information | Literature Through; SR Quality | Population; Relevant Comparison | Results; Conclusion Strength of Evidence
Moore 2009 22 (Cochrane Incontinence Group) Long-term bladder management by intermittent catheterization in adults and children 3 RCTs | Literature search through June 2007 Good | Adults and children with incomplete bladder emptying Sterile technique/clean technique (3 trials; only one with only CUR population) | The evidence was insufficient to permit a conclusion for rates of UTI

PVR = post void residual; SR=systematic review; UTI = urinary tract infection

### Benefits

Moore et al. compared clean versus sterile catheterization technique.22 They found data from three studies insufficient to draw conclusions. Only one of these trials had CUR as an enrollment criterion and was eligible for our review.20 Because the results from the three trials eligible for the Cochrane review were consistent and the data were assessed as insufficient, we reiterate their conclusion of insufficient evidence for this comparison.

Two small RCTs studied efficacy and comparative effectiveness of CUR interventions in populations with CUR from mixed obstructive and non-obstructive or unknown causes (Table 6). In one study of 19 women with obstructed voiding or retention associated with Fowler's syndrome, evidence for treating CUR with sildenafil was insufficient to draw conclusions about effectiveness. The other RCT evaluated intermittent versus indwelling catheterization among elderly women with CUR admitted to a geriatric rehabilitation ward. This study provided insufficient information to draw conclusions about the rates of UTI with intermittent versus indwelling catheterization but provided low-strength evidence of no difference between the proportion of patients able to go without catheter after intermittent or indwelling catheter treatment. However, we could not determine whether these patients were truly CUR patients and not suffering from transient urinary retention.

Table 6 Summary outcomes, adverse events, and strength of evidence of treatments for CUR in mixed populations or unknown causes

Study (n); Comparison; Inclusion Criteria; Design | Outcomes | Result | Strength of Evidence
Datta 2007^10^ (n=19) Sildenafil vs. Placebo Women with obstructed voiding or retention associated with Fowler's Syndrome RCT | Primary outcomes
Datta 2007^10^ (n=19) Sildenafil vs. Placebo Women with obstructed voiding or retention associated with Fowler's Syndrome RCT | Urinary tract infection | NS | Insufficient (moderate risk of bias, imprecise, unclear consistency)
Datta 2007^10^ (n=19) Sildenafil vs. Placebo Women with obstructed voiding or retention associated with Fowler's Syndrome RCT
Datta 2007^10^ (n=19) Sildenafil vs. Placebo Women with obstructed voiding or retention associated with Fowler's Syndrome RCT | Adverse effects
Datta 2007^10^ (n=19) Sildenafil vs. Placebo Women with obstructed voiding or retention associated with Fowler's Syndrome RCT | Death Clinical deterioration (Total not reported) | NS | NA
Tang 2006^11^ (n=81) Intermittent urinary catheterization vs. indwelling urinary catheterization Elderly women admitted to a female geriatric rehabilitation ward. Patients with a PVR >150 ml were regarded as having urinary retention. If PVR remained ≥300 ml, the subjects were then randomized RCT | Primary outcomes
| Urinary tract infection | NS | Insufficient (moderate risk of bias, imprecise, unclear consistency)
| TWOC | NS RR 0.86 [95% CI 0.59 to 1.25] | Low (moderate risk of bias, unclear consistency)
| Adverse effects
| Total adverse effects | NS | NA

CI = confidence interval; NA = not assessed; NR = not reported; NS = no statistically significant difference; PVR = post void residual; RCT = randomized controlled trial; RR = risk ratio; TWOC = trial without catheter

### Harms

Adverse effects were measured differently in each RCT. These events were rare, and results did not differ between treatment groups, though studies were not adequately powered to detect such differences.